# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Noel S. Weiss, M.D., Dr.P.H., for his assistance with report conceptualization and development, as well as input on clinical epidemiology and research methods throughout the process; Rita F. Redberg, M.D., M.Sc., for her participation in team discussions to enhance the team's understanding of clinical aspects of this project and assistance with review of the report for clinical accuracy; Elisabeth U. Kato, M.D., M.R.P., AHRQ Task Order Officer; and Timothy J. Wilt, M.D., M.P.H., EPC Program Associate Editor. We also thank Elaine Graham, M.L.S., for program guidance and collaborative support; Andrew Hamilton, M.L.S., for assistance with the literature search; Leah Williams, B.S., for editorial assistance; Krystle Pagarigan, B.S., Katie Moran, B.S., and Erin Anthony-Fick for assistance with data abstraction.