# Discussion

## Key Findings and Strength of Evidence

Evidence to determine the comparative effectiveness and safety of different noninvasive testing strategies for coronary artery disease (CAD) is limited. While there is a robust body of literature on the diagnostic performance of these tests based on traditional measures of test accuracy (e.g., sensitivity, specificity), only a small number of studies were identified that evaluated the impact of noninvasive testing on clinical outcomes measures in the population of interest for this report. The key findings and strength of evidence for the outcomes identified as being most clinically important are summarized in Tables 8–15 in the Results section; factors used to determine the overall strength of evidence are summarized in Appendix J.

A total of 24 comparative studies that evaluated the impact of noninvasive testing on clinical outcomes and/or clinical management outcomes in the population of interest for this report formed the basis of this review: 14 randomized controlled trials (RCTs) (2 good quality, 9 fair quality, and 3 poor quality)75-88 and 10 comparative observational studies (7 fair quality and 3 poor quality).90,92-97,100,102,104-107 Common methodological shortcomings in the RCTs include unclear description of randomization sequence and/or test allocation and lack of blinded outcomes assessment. In the observational studies, lack of controlling for confounding and/or blinding of outcomes assessment were common methodological shortcomings. The comparative studies served as the basis of the report and were stratified based on pretest risk, test type (anatomic or functional), and setting. For most outcomes reported in trials, the strength of evidence was rated as low (meaning that our confidence in the estimates of effect is low) based on concerns related to precision and study limitations. However, for some outcomes reported by trials, the strength of evidence was found to be moderate or high. For the majority of outcomes reported by comparative observational studies, the strength of evidence was found to be insufficient because of study limitations, although some outcomes were graded as low strength of evidence when the estimates were considered to be at low risk for imprecision and confounding was controlled. Eight RCTs and one observational study were conducted in emergency department (ED) settings or specialized chest pain clinics82 and compared coronary computed tomography (CCTA) with functional testing77-79,82 or usual care.75,80,81,83,92,94 In these studies, most of the available data were reported for the index ED visit, and with the exception of two trials reporting 12-month followup, the maximum followup in ED studies was 6 months. The remaining 5 trials76,84-87 and 13 comparative observational studies were conducted in outpatient, various, or unspecified settings; in general, these studies had longer followup periods, which ranged from a mean of 55 days to 30 months. Pretest risk could not be standardized across studies and was variably determined and defined across studies. Thus, categories of pretest risk used here are based on how the study authors defined risk.

### Clinical Outcomes

There was no clear difference in myocardial infarction (MI) or in all-cause mortality between different testing strategies across settings and pretest risk groups that included patients with intermediate pretest risk based on low- to moderate-strength evidence from eight trials. The definition of intermediate pretest risk was broad. The frequency of all-cause mortality was low across studies in all settings. In trials enrolling outpatients, the frequency of all-cause mortality ranged from 0 to 1.5 percent for a variety of noninvasive testing strategies and the frequency in trials in the ED setting past the initial index visit ranged from 0 to 1.08 percent, across a variety of noninvasive testing or usual-care strategies, with no statistical difference between any groups. Similarly, the frequency of MI was low, ranging from 0 to 0.8 percent (up to median of 25 months) in outpatient settings and 0 to 3 percent (up to 12 months) in ED settings, with no statistical differences between groups. The strongest evidence came from three trials: one that compared CCTA with functional testing in an outpatient setting76 and two that compared CCTA with single photon emission computed tomography (SPECT) in an ED setting.77,78 For the trial of CCTA versus functional testing, which was also the largest trial (N=10,003), there were no differences in all-cause mortality between groups through 12 months (0.42% vs. 0.64%) or at a median of 25 months followup (1.48% vs. 1.50%) or in nonfatal MI at 12 months (0.36% vs. 0.54%, risk difference [RD] -0.18, 95% confidence interval [CI] -0.44 to 0.08 per 100 people) or at a median of 25 months followup (0.60% vs. 0.80%, RD -0.20, 95% CI -0.53 to 0.13 per 100 people)76 (moderate strength of evidence for both outcomes). Across the two trials comparing CCTA with SPECT in an ED setting, there was low-strength evidence that no difference was found between tests for mortality or MI; there were no deaths or MIs reported through a mean of 6 months past the initial ED visit.77,78 Across the remaining trials, no difference was found between tests because of lack of precision and study limitations (low strength of evidence). Higher-quality observational studies (i.e., those that controlled for confounding) supported these findings. No conclusions can be drawn regarding the impact of testing on clinical outcomes for patients at low risk or high risk (without ECG changes or troponin elevation or other characteristics of acute coronary syndrome [ACS]), as only subanalyses of fewer than 100 patients were available.

Several factors may have contributed to finding no statistical differences between tests on clinical outcomes. Given the low incidence of mortality and MI in the studies previously noted, sample sizes in even the largest trials may have been too small to detect differences between tests. The low incidence of mortality and MI suggests that study populations may generally have been at the lower end of the intermediate pretest risk range. Improvements in medical therapy in the past few decades, including use of statins, may have contributed to the low incidence of these outcomes. An additional consideration is the possibility that differences between tests in true sensitivity to detect treatable CAD or ability to identify high-risk disease are not large. Small differences in sensitivity may have little impact on the probability of disease when the pretest probability is low. Even if two tests do not have the same sensitivity, the lack of difference in the occurrence of outcome events in most studies between people who were assigned to receive different tests could result from either the lack of efficacy of treatments administered to test-positive people or the lack of difference in the receipt of effective treatments between test-positive and test-negative people. Given that included studies did not present data on treatments administered to individual study participants (or how testing directed those decisions), we could not distinguish between these alternatives. Furthermore, information on post-test risk stratification or treatment based on such stratification was not reported in most studies. Information on clinical decisions and outcomes based on whether tests were positive, negative, or indeterminate was not given in most comparative studies. It is possible that over- or undertreatment may have contributed to similarity in clinical findings. Length of followup may have also impacted the findings of no difference in clinical outcomes. Two larger trials in outpatient settings (SPECT vs. stress electrocardiography [ECG]87 and CCTA vs. functional testing76) followed patients for 2 or more years. Most studies in the ED setting did not provide data beyond 6 months of the ED visit; testing was only able to affect clinical events after the index visit, and consequently there was insufficient evidence to draw conclusions regarding longer-term clinical outcomes.

### Referral for Invasive Coronary Angiography

There was some variability in conclusions regarding invasive coronary angiography (ICA) referral following noninvasive testing. In most studies, ICA was more common following CCTA than following various functional tests. The strongest evidence came from one good-quality trial that compared CCTA with functional testing in outpatients. The trial found that ICA was significantly more common in the CCTA group than the functional testing group by 90 days (12.19% vs. 8.11%, RD 4.08, 95% CI 2.90 to 5.26 per 100 people) (high strength of evidence). Interestingly, fewer catheterizations in the CCTA group showed no obstructive CAD (3.4% vs. 4.3%),76 perhaps because of to a lower false positive rate with CCTA. The strength of the quality of evidence regarding ICA referral was low across the remaining trials. Two fair-quality trials comparing CCTA with exercise ECG suggested that ICA referral is more common following CCTA up to 12 months following an initial ED visit in one trial of low- to intermediate-risk patients (RD 4.8, 95% CI 0.8 to 8.9 per 100 people) and in the other trial of mixed-risk patients (RD 6.3, 95% CI -1.2 to 13.9 per 100 people); statistical significance was not reached and strength of evidence was low because of study limitations and lack of precision.

A large administrative data study in Medicare patients found that ICA was significantly more common following CCTA compared with nuclear myocardial perfusion imaging (MPI) (22.94% vs. 12.13%, adjusted odds ratio [OR] 2.19, 95% CI 2.08 to 2.32) (low strength of evidence).102 In contrast, across studies comparing CCTA with usual care there were no statistical differences between testing strategies in any of the trials regardless of pretest risk or setting, however in the small high-risk group from one trial, fewer CCTA patients had ICA at the index visit (RD -18, 95% CI -37 to 0.8, p=0.0714) (low strength of evidence). Evidence from observational studies for comparisons of CCTA with other tests was considered insufficient because of study limitations and lack of precision. Regarding comparisons of functional tests, two RCTs85,87 and one large administrative database study102 provided low-strength evidence on ICA referral in outpatient settings. One trial comparing SPECT with exercise ECG in intermediate-risk women reported a 6 percent referral for ICA in each test group by 24 months. However, the other trial making this comparison reported a significantly lower frequency of ICA referral by 22 months following SPECT in a subgroup of patients with intermediate pretest risk (RD -32, 95% CI -43 to -22 per 100 people) as well as in a subgroup of high-risk patients (RD -41, 95% CI -58 to -24 per 100 people).85 This same trial used Bayesian methods to model post-test risk and reported that 86 percent of those with low pretest risk finished with low post-test risk. Patients in either arm whose tests were normal or indicated low risk test did not receive ICA; 3 percent and 38 percent in the intermediate and high post-test risk groups had ICA following SPECT compared with 13 percent and 85 percent in the intermediate and high post-test groups following exercise ECG. This type of modeling is not a standard approach to post-test risk assessment, so the generalizability of these results is not clear. The administrative database study of Medicare patients reported that, compared with nuclear MPI, ICA referral was lower following exercise ECG (OR 0.72, 95% CI 0.70 to 0.75) and stress echocardiography (OR 0.78, 95% CI 0 .76 to 0.81)102 (low strength of evidence). Evidence from the remaining observational studies was considered insufficient.

None of the studies provided analysis or explicit information regarding unnecessary treatment or testing.

### Revascularization

Findings were inconsistent across diagnostic strategies with regard to revascularization referral. There was high-strength evidence from one large trial that any revascularization within 90 days was more common following CCTA compared with functional testing (RD 3.07, 95% CI 2.24 to 3.90 per 100 patients); the same was true for percutaneous coronary intervention (PCI) specifically (RD 2.4, 95% CI 1.7 to 3.1 per 100 patients)76 (high strength of evidence). Revascularization was also more common 6 to 12 months following CCTA compared with exercise ECG across two studies (1 RCT, 1 observational study)82,102 of mixed risk ED patients (low strength of evidence), as well as across two observational studies comparing CCTA with nuclear MPI102,105 in an outpatient setting up to 1.4 years (low strength of evidence). In contrast, the frequency of revascularization was similar for CCTA and SPECT (pooled RD 2 per 100 patients, 95% CI 0 to 4 per 100 patients) at the index ED visit and at 6 months (pooled RD 0, 95% CI 0 to 1 per 100 patients) across two trials (moderate strength of evidence).77,78 PCI and coronary artery bypass graft (CABG) frequencies in these trials were also similar between tests (moderate strength of evidence). Further, there was low-strength evidence of no statistical differences in revascularization frequency between CCTA and usual care at the index visit or at 1 to 3 months followup based on data from four trials.75,80,81,83 Evidence comparing functional tests was inconsistent, with one small trial reporting fewer revascularizations following SPECT than exercise ECG (RD -7.1, 95% CI -13.6 to -0.6 per 100 patients)85 (low strength of evidence), and one large Medicare administrative database study reporting a similar frequency of revascularization, including PCI and CABG, for exercise ECG (4.31%, vs. 4.59%) and stress echocardiography (4.22% vs. 4.59%) as for nuclear MPI (low strength of evidence). For the latter study, although the differences between groups were statistically significant for both comparators, they may not be clinically significant. Studies did not describe post-test reclassification of risk or decisionmaking for treatment.

### Additional Noninvasive Testing

Additional noninvasive testing, which impacts the cost and efficiency of care, was common in most studies. In the ED setting, there was high-strength evidence from two trials of patients with low to intermediate risk that additional noninvasive testing was significantly more common following CCTA than SPECT at the index visit (RD for largest trial 9.4, 95% CI 6.1 to 12.7 per 100 patients).77,78 In the same setting, there was moderately strong evidence that CCTA was associated with less frequent noninvasive testing compared with usual care at the index visit in one trial81 and compared with exercise ECG through 12 months past the index ED visit82 in another trial. In intermediate-risk patients, the frequency of additional testing following CCTA was similar to the frequency following usual care up to 1 month past the ED visit in one trial (low strength of evidence), possibly because many in the usual-care group also received noninvasive imaging.80 In outpatient settings, the strength of evidence was moderate that SPECT was associated with significantly less additional noninvasive testing compared with exercise ECG through 22 months based on one large trial of intermediate-risk women (RD -9, 95% CI -14 to -4 per 100 patents)87 as well as a from a subgroup of intermediate-risk patients in another trial (RD -38, 95% CI -48 to -29 per 100 patients).85 These results likely indicate greater clinician confidence when stress testing is paired with imaging based on general understanding from accuracy studies that positive and negative predictive values are better for SPECT than for stress testing. In the Medicare administrative database study, both CCTA and stress echocardiography were associated with a significantly higher frequency of additional noninvasive testing compared with nuclear MPI (OR 1.52, 95% CI, 1.37 to 1.69 and OR 1.92, 95% CI 1.83 to 2.0, respectively), but strength of evidence was low. Studies generally did not describe post-test reclassification of risk or decisionmaking for related further testing.

### Hospitalization

Cardiovascular-related hospitalizations varied somewhat among pretest risk groups across studies. There was moderate-strength evidence from one large trial of ED patients with low to intermediate risk that the CCTA group was significantly less likely than the usual-care group to be hospitalized or admitted for observation at the index visit (RD -26.8, 95% CI -31.9 to -21.8 per 100 patients), but that after this visit through 1 month, there was no difference (3% for CCTA vs. 2% for usual care).81 Low-strength evidence from a large trial of intermediate-risk ED patients suggested that there were fewer hospitalizations following CCTA compared with usual care at the index visit (RD -33, 95% CI -39 to -28 per 100 patients).80 These data imply clinician confidence in the negative predictive value of the anatomic test, yet there is a predisposition of patients to return with unexplained symptoms that can be from a variety of other causes of chest pain, including vasospasm and microvascular dysfunction. In contrast, no statistical differences between CCTA and usual care were identified for ACS hospitalization at the index visit based on subgroups of low- or high-risk patients in one trial,75 but strength of evidence was low. There was moderate-strength evidence that there was no difference in cardiovascular hospitalizations between CCTA and functional testing groups in low- to intermediate-risk ED patients within 6 months (0% in both groups) based on one trial,77 and through 30 months based on one observational study90 that compared CCTA with SPECT. In another trial of mixed pretest risk patients presenting to specialized chest pain clinics, moderate-strength evidence suggested that hospitalization for cardiac causes occurred less frequently in the CCTA group compared with the exercise ECG group (RD -6.1, 95% CI -9.5 to -2.7 per 100 people) through 12 months.82 Two trials conducted in outpatient settings reported no differences in cardiac-related hospitalizations between groups. The strongest evidence came from the large trial comparing CCTA with functional testing, which reported no differences at a median of 25 months (RD -0.30, 95% CI -0.10 to 0.71 per 100 people)76 (moderate strength of evidence). The trial of SPECT versus exercise ECG in women also found no difference between groups (low strength of evidence).87

### Special Populations

With regard to evaluation of special populations, one good-quality trial comparing CCTA with functional testing reported that none of the prespecified subgroups modified the primary composite outcome (all-cause death, nonfatal MI, hospitalization for unstable angina or a major procedural complication such as stroke, major bleeding, anaphylaxis, and renal failure requiring dialysis). Results across subgroups were consistent with those for the entire study population. Subgroups examined included age, sex, race, pretest risk assessment, CAD equivalence, and pretest probability of CAD.76 None of the other studies identified evaluated differential effectiveness or safety for the primary clinical outcomes (e.g., mortality and MI). As previously noted, one fair-quality trial of exercise SPECT compared with exercise ECG in women found no differences between tests for mortality, ICA referral, revascularization, or hospitalization, but the trial reported a significantly lower use of additional noninvasive testing following SPECT.87 The strength of evidence was moderate for additional testing and low for other outcomes. An additional small poor-quality RCT in women compared stress echocardiography with exercise ECG; this trial reported similar frequency of a composite outcome which included cardiac death, MI, unstable angina, or coronary angiography, demonstrating 50 percent or more luminal narrowing (7.7% vs. 7.4%).86 However, the strength of evidence was insufficient because of high risk of bias, lack of precision, and unknown consistency. Also as noted earlier, a large, fair-quality administrative data study in the Medicare population was identified.102 Consistent with findings in other studies, this study found no differences in adjusted effect estimates for all-cause mortality for the comparisons of nuclear MPI with stress echocardiography, exercise ECG, or CCTA. CCTA was significantly associated with increased referral for ICA and revascularization (particularly PCI) and use of additional noninvasive testing compared with nuclear MPI (strength of evidence was low for these outcomes and comparisons).

### Harms and Consequences of Testing

Harms of testing were rarely reported and details on comparisons of harms for tests were sparse with many studies stating only that no harms were observed and not providing further detail; 16 of the 27 comparative studies made no mention of evaluation of harms. There were no compelling safety outcomes data that can be used to recommend one approach versus another (low or insufficient strength of evidence). No differences in major procedural complications were identified in the trial comparing CCTA with functional imaging although mild contrast reactions were significantly more common in the CCTA group than in the functional testing group (moderate strength of evidence).76 No differences were reported between CCTA and usual care in bradyarrhythmia in one trial81 or periprocedural complications in another80 (low strength of evidence for both). A third trial reported that there was no clinical or laboratory evidence of contrast-induced nephropathy in either the CCTA or the usual care group.75 One observational study reported incidental findings requiring further investigation in 7.1 percent of those receiving CCTA (insufficient evidence).90 Evidence from observational studies regarding test-related harms and impact of incidental findings following CCTA was insufficient to draw conclusions.

An important patient safety concern related to noninvasive testing is exposure to low to moderate levels of ionizing radiation, which add to cumulative lifetime radiation exposure. To the extent that noninvasive tests for CAD reduce the need for conventional angiography, cumulative exposure might be reduced. To the extent that they result in the need for additional testing, it may be increased. The true attributable risk from radiation-based diagnostic tests cannot be determined. Some experts consider the potential for harm from radiation exposure (based on either deterministic or stochastic modeling) to be clinically significant, particularly since patients may be likely to have additional tests using radiation over many years. Estimates of radiation exposure from included studies are provided in Appendix G (Table G4); the introduction provides contextual information on radiation exposure ranges for testing. Radiation exposure from included studies for initial testing strategies ranged from 3.8 to 17 mSv for CCTA and 10.5 to 38 for SPECT. One study reported a mean of 4.0 mSv for positron emission tomography (PET)95 and another study80 reported a mean of 4.7 mSv for usual care. Consideration of cumulative radiation exposure related to downstream testing and intervention is important when discussing with patients the benefits and consequences of the different noninvasive tests and their contribution to lifetime radiation exposure. Higher mean cumulative radiation accounting for additional testing was seen in single trials following CCTA compared with usual care (14.3 ± 10.9 vs. 5.3 ± 9.6 mSv)80 and functional testing (12.0 ± 8.5 vs. 10.1 ± 9.0 mSv).76 One study reported higher cumulative exposure following CCTA than following SPECT in patients referred for ICA (medians 15.2 mSv, interquartile range 12.7 to 17.1 vs. median 10.8 mSv, interquartile range 10.2 to 11.7).104 By contrast, another trial reported lower cumulative exposure for additional testing following CCTA versus SPECT (median 7.3 mSv, interquartile range 5.1 to 13.7 vs. median 13.3 mSv, interquartile range13.1 to 38.0).84 One observational study of CCTA and exercise ECG reported higher exposure to index and downstream testing for CCTA for patients whose tests were negative, positive, or inconclusive. However, among those who tested positive and had revascularization, mean cumulative exposure was slightly higher in the ECG group (28 vs. 32 mSv).100 Consideration of patient preferences with regard to the impact of radiation exposure should be part of shared decisionmaking around noninvasive testing.

## Findings in Relationship to What Is Already Known

Few prior reviews have evaluated the impact of noninvasive testing on clinical and management outcomes. Systematic reviews and studies on noninvasive testing for CAD identified from our search focused on traditional measures of test performance (e.g., sensitivity, specificity) compared with ICA. They generally did not directly compare the effectiveness and safety of different modalities with regard to impact on clinical outcomes specifically in the population of interest in this report. Consistent with this review, prior systematic reviews126,127 have reported few or no comparative studies evaluating the impact of noninvasive tests on clinical outcomes, decisionmaking, or use of additional testing, and they note that harms are rarely reported. Relevant studies from these reports were included in this systematic review. The recent Agency for Healthcare Research and Quality (AHRQ) report on noninvasive testing for CAD in women reported that there was insufficient evidence from three studies that treatment decisionmaking and clinical outcomes were impacted by noninvasive testing;128 consistent with our report, there were no differences in clinical events or hospitalization in studies comparing noninvasive tests. The authors also concluded that studies were underpowered to detect clinical outcomes.

## Applicability

A number of factors that impact the applicability of this report's findings are discussed in this section.

### Patients

Eight of the 13 trials identified were in patients presenting to the ED with CAD symptoms; however, the largest trial was in an outpatient setting. Patients presenting to the ED represent a broad spectrum of pretest risk probabilities, including those at low or intermediate risk as well as those at high risk for CAD. The severity, newness, and duration of symptoms may differ from those seen in outpatient settings, in which patients generally present with more mild to moderate symptoms. Definitions of pretest risk varied across included studies, and some did not report or stratify by pretest risk, making it difficult to fully evaluate results based on pretest risk across settings. It is likely that the patients enrolled in the included studies are representative of those in the broad range of clinical practice regardless of setting.

### Interventions and Comparators

The evidence may be skewed toward newer testing modalities, and studies of established tests may not reflect current technology and diagnostic performance. CCTA was the noninvasive test most often assessed, accounting for 48 percent of included studies. The high proportion of studies dealing with CCTA may be because it is a newer modality and thus is compared with established tests such as stress echocardiography and MPI. Few studies comparing different types of functional testing, particularly established functional tests such as stress echocardiography, exercise ECG, and nuclear stress testing, were identified. A recent systematic review suggested that over the past 2 decades, there has been substantial decline in investigations related to echocardiography and nuclear cardiology, compared with a marked increase in cardiac CT imaging studies.129 Input from clinical team members and the Technical Expert Panel suggested that there is substantial variation in clinical practice with regard to which test may be ordered as an initial test based on patient presentation, testing availability, and clinical perspective. The applicability of this report may be impacted by lack of clarity on the extent to which CCTA may or may not be the initial noninvasive test for first-line evaluation of symptomatic patients without known CAD after a resting ECG. None of the included studies included a no testing arm. To the extent that clinical decisionmaking is based on clinical evaluation and judgment without testing, findings in this report may be less applicable to settings in which testing is not routinely done.

### Outcomes

Findings related to rare outcomes of death, MI, or hospitalization may not be fully applicable to broader clinical populations in part because of small study sizes and inability to fully characterize such outcomes, particularly over the longer term. Moreover, the impact of a negative test or the treatment downstream from a positive test may extend beyond traditional major adverse coronary events to quality of life, reduction in symptoms, and level of activity. These outcomes were not examined in the majority of included studies. The majority of trials reported outcomes at the time of an index ED visit. The clinical management objectives are somewhat different in an ED setting than in an outpatient setting.

### Settings

Most RCTs were conducted in the ED, where test data help determine immediate disposition for discharge or the need for additional evaluation and/or hospitalization. The initial goal is to make a diagnosis for the cause of chest pain in order to inform appropriate treatment and next steps at the index visit. Thus, MI reported at the index visit may reflect a test's ability to make the diagnosis for immediate decisionmaking but not the test's ability to impact future clinical outcomes. Testing is able to affect events only after the index visit, and long-term followup from ED studies was limited. Thus the applicability of findings from ED studies to general outpatient settings over the long term is likely limited. Six RCTs evaluating CCTA were multi-center studies and five were in single-center sites. It is possible that results from single-center trials may be different and less generalizable than results from multicenter trials. Assessing discernible patterns between the multi-center and single-center site studies in this report was a challenge given the heterogeneity across studies with regard to pretest risk and how comparators such as usual care are defined.

## Implications for Clinical and Policy Decisionmaking

The 2012 American College of Cardiology Foundation (ACCF)/American Heart Association (AHA) Guideline states that diagnostic testing is most valuable when the pretest probability of ischemic heart diseases is intermediate (10%–90%) and provides a range of options for which test may be used in a given scenario.8 However, the effectiveness of different modalities with regard to impact on clinical outcomes is not compared. Currently, a variety of tests as the initial (and additional) diagnostic tests for patients at intermediate pretest risk of CAD are employed, and there is uncertainty regarding which tests, if any, may be most suitable and beneficial in patients who present with symptoms suggestive of CAD but have no prior history of it. Although several ACCF/AHA Appropriate Use Criteria are available, including the 2013 multi-modality imaging Appropriate Use Criteria,130 they do not explicitly compare multiple noninvasive testing modalities nor do they make specific recommendations for the timing and sequencing of tests or for repeat testing based on pretest risk group.

Low- to moderate-strength evidence from nine trials suggested that there is no clear difference in MI or in all-cause mortality between different testing strategies across settings and pretest risk grouping that included those at intermediate risk. Possible contributors to this finding, including lack of power to detect a difference, were previously described. Information from two studies that provided data on groups with low and high pretest risk (without ACS) do not provide insight into best testing strategies in those groups and the strength of evidence was insufficient for the few outcomes reported and no conclusion can be drawn. Across studies that enrolled intermediate-risk groups, no clear benefits of one testing strategy versus another were seen and no clear picture of harms for various tests was available from included studies. One apparent trend uncovered by the review is that tests that evaluate coronary anatomy such as CT result in a greater likelihood of referral for ICA and subsequent intervention than functional tests do; however, the strength of evidence varied from high to low depending on the comparator and the impact on clinical outcomes is not known as most studies did not present data on treatments administered to individual study participants. Thus, it is not clear if the increased referrals were helpful or not with regard to influencing clinical outcomes. In addition, potential harm from use of invasive treatments (which carry specific risks) if clinical benefit is not clear was not described. Only two studies provided limited information on the overall impact of testing and resulting treatment strategies on patient symptoms and quality of life. No studies that compared testing with an arm that received no testing were identified, so the impact of any of the noninvasive testing pathways on clinical evaluation is not known.

As defined in the ACCF/AHA Guideline, the intermediate pretest group is broad and heterogeneous (10%–90%), and in the absence of information on post-test risk, the value of the various tests for influencing important management decisions at each end of the spectrum was not clear. The ACCF/AHA Guideline and various Appropriate Use Criteria20,131-133 provide general recommendations for testing and treatment.

In general, next steps following a positive result from an initial noninvasive test is in part based on the post-test annual predicted rate of cardiac mortality as described in the 2012 ACCF/AHA Guideline: low risk (<1% per year), intermediate risk (1%–3% per year), or high risk for cardiac mortality (>3% per year).8 Clinical presentation and test results are both considered in this determination. In general, indications for revascularization are based on the clinical presentation (ACS or stable angina), the severity of the angina (based on Canadian Cardiovascular Society Classification), the extent of ischemia on noninvasive testing, and the presence or absence of other prognostic factors including congestive heart failure, depressed left ventricular function, diabetes, the extent of medical therapy, and the extent of anatomic disease.134,135

Thus, post-test disease probability is an important factor in determining next steps for testing and treatment. From the included studies, however, it is not clear how post-test risk was assessed, which clinical pathways were followed after the initial test, which test(s) may lead to the most appropriate treatment give the post-test risk, or whether the treatments impacted outcomes. While the ACCF/AHA Guidelines and various Appropriate Use Criteria provide a range of options for which test may be used in a given scenario and treatment initiated, the effectiveness of different testing modalities leading to appropriate treatment are not compared with regard to impact on clinical outcomes.

In the absence of high-strength evidence regarding testing options, including the possibility of not testing, decisions must necessarily be made on the basis of other factors related to the initial test and potential followup. The ability of a test to accurately diagnose treatable CAD is important; so too are the costs and consequences beyond the initial test, such as followup of false negative results (e.g., tests with high false-positive rates in a population with low pretest risk) and the costs and consequences of missing significant disease (e.g., dismissal from the ED of patients with CAD needing treatment). The costs and consequences depend to some extent on the role a test plays in the diagnostic work-up pathway as well as the availability and convenience of a test. Patient pretest probability of disease and consideration of the likelihood ratios with regard to goals of ruling in or ruling out CAD should be a part of the decisionmaking process. Consequences of testing that need to be considered include those related to patient anxiety and patient quality of life and those related to radiation exposure of the index test, as well as potential downstream exposure from additional testing resulting from the initial test and future testing and/or treatment. Consideration of patients' preferences based on their understanding the range of consequences of initial and downstream testing is an important part of shared decisionmaking for initiating noninvasive testing.

## Limitations of the Systematic Review Process

This review has some potential limitations. Stratifying by pretest risk, which was in keeping with the intent of Key Questions, may have resulted in fewer studies to pool and left single studies for most comparisons. This, combined with substantial heterogeneity in how pretest risk was defined, the time frames over which outcomes were evaluated, and clinical heterogeneity between the tests evaluated, resulted in too few studies for head-to-head meta-analysis for most outcomes and network meta-analysis was not feasible.

Variable reporting on patient symptoms and characteristics related to CAD risk precluded application of a standardized method for calculating or assigning pretest risk across studies. In light of this, test comparisons were evaluated according to pretest risk as specified by authors to discern patterns within and across pretest risk levels and setting, and qualitatively synthesize outcomes in which pooling was not possible. This approach resulted in limited ability to truly examine the evidence by pretest risk.

Inclusion was restricted to studies published in English; however, this is not likely to have impacted the evidence base, as few potential non-English-language studies were seen in the searches. Given the paucity of RCTs, comparative observational studies were included. Despite a focus on outcomes where authors controlled for confounding, there was a possibility that residual confounding influenced reported results, lowering confidence in effect estimates. The comparative studies included may not have adequately captured harms safety issues in the population of interest. The focused criteria on inclusion of studies comparing established first-line test (beyond a resting ECG) narrowed the review scope substantially, but this focus was intended to provide a clearer approach to addressing the areas of uncertainty. It is possible that older historical studies outside of our population of interest could provide more detailed information about the safety of various tests, particularly more established tests.

There were too few studies of any given comparison to meaningfully evaluate reporting and publication bias. Where available, protocols of trials were reviewed to consider the extent to which outcomes were reported selectively and information from Scientific Information Packets requested from stakeholders was evaluated; while overt publication bias was not detected, there is always the possibility it may be present. This review provides a snapshot of currently available evidence on the questions posed. Included studies may not reflect technological advances that have been made in the various testing modalities.

## Limitations of the Evidence Base

Important limitations of the evidence base include the paucity of studies that compared the impact of different noninvasive tests on hard clinical outcomes such as mortality and MI, and few RCTs were available, in particular for comparisons of established functional tests in the population of interest. No trials that included a no testing arm were identified. Methods for assessing pretest risk, defining cardiovascular outcomes, and defining usual care were poorly reported and not standardized. The variable methods for determination and classification of pretest risk across studies and inability to implement a standardized method for assessing pretest risk across studies precluded detailed evaluation of testing strategies by pretest risk level to determine the comparative values of tests for a given pretest risk. The intermediate risk range was broad (10%–90%). Studies did not provide information on the impact of test results on post-test risk stratification or clinical decisionmaking for treatment or further testing precluding evaluation of the impact of testing in this group. Some studies reported composite cardiovascular outcomes, which can be misleading depending on the effects on the individual components.136 Studies did not evaluate aspects of unnecessary testing. Reporting of harms was suboptimal; 16 of the 27 comparative studies made no mention of evaluation of harms and another 3 merely stated that there were no adverse events. With the exception of one study, authors reported few details about harms. As mentioned previously, study sample sizes and short-term followup may preclude evaluation of rare events. Studies did not describe the impact of testing on treatment choices. Few studies on PET, CACS, and established tests such as stress echocardiography were identified.

## Research Gaps and Recommendations

The gaps in the available evidence are many. Two primary issues relate to the need to improve reporting and standardization of pretest CAD risk and to enhance the evidence linking testing strategies and clinical pathways with clinical outcomes. Use of standardized risk models that refine and narrow the currently broad “intermediate-risk” group is needed. For example, because of health care trends to streamline and reduce the cost of care, newer risk models such as the Duke Clinical Score have narrowed the intermediate range and tend to reclassify many of those classified as “intermediate risk” in the Diamond and Forrester model to “low risk”.137 Documentation of post-test risk stratification and its impact on clinical management (treatment and referral for additional testing) is needed to determine optimal testing strategies and roles of tests in different pretest risk groups. This may facilitate comparison of tests to effectively parse out patients at the highest risk end and those at the lower risk end, as well as evaluation of the impact of management decisions in these groups, as they likely will differ. Documentation of management of those who test positive compared with those who test negative and followup of these groups for sufficient time to evaluate clinical outcomes are needed. Prospective cohort studies that address selection bias and confounding by indication have the potential to enhance the evidence base and may be more feasible than RCTs for some settings. Studies comparing testing versus clinical evaluation without testing would provide valuable information for assessing the need for testing, possible overuse of testing, and impact of testing in general. Comparative studies (RCTs, pragmatic trials, or prospective cohorts) of functional tests that reflect technological advances as applied to symptomatic patients without known CAD would update the evidence base. Meta-analysis of patient-level data from existing trials may allow for more specific stratification by pretest probability or specific risk factors. Important insights into the overall impact of testing on long-term outcomes could come from studies that (1) document how test results specifically influence decisionmaking regarding further testing and treatment strategies and (2) follow patients to evaluate the impact of the testing pathway. Future research also needs to incorporate evaluation of patient-centered outcomes, such as quality of life, symptom status, and the impact of testing.

Primary gaps and considerations for future research are summarized in Table 16.

Table 16 Overview of research gaps and recommendations

Research Components | Evidence Gap | Future Research Recommendations
Study Design Methods and Reporting | Gaps include lack of a standardized approach to determining and reporting pretest risk across studies; variable definitions of pretest risk, which precluded effective stratification by pretest risk; the large range of pretest likelihoods for “intermediate” risk patients (10%–90%), which precluded detailed evaluation of the impact of testing for patients at the lowest and highest ends of the range. | A standardized approach for determination of pretest risk that can be applied across study designs is needed. Future research should use risk models that further refine the range of pretest probability for those at intermediate risk (e.g., the Duke Clinical Score) to delineate the impact of testing on clinical decisionmaking at the lower and higher ends of the range. Tools that refine the range may also be clinically useful.
Study Design Methods and Reporting | Studies describing outcomes at the index ED visit do not allow conclusions regarding the impact of testing on clinical outcomes over the longer term. | Longer followup (>12 months) and documentation of the impact of testing on treatment decisions and hard clinical outcomes are needed. RCTs, pragmatic trials, or prospective cohort studies that address selection bias and confounding by indication could be employed.
Study Design Methods and Reporting | None of the included studies evaluated issues of unnecessary testing or treatment in patients without known CAD. | As a first step, a priori definitions for necessary vs. unnecessary testing or treatment are needed and they should be evidence-based. Given the variability of clinical practice and medico-legal concerns, this may be challenging. Evaluation of Appropriate Use Criteria and examination of evidence on the clinical outcomes based on application of such criteria may help further define necessary vs. unnecessary.
Patient Populations | There is a paucity of studies on patients with low or very low pretest probability of CAD and the value of testing is not clear for this population. | Studies (RCTs, pragmatic trials or methodologically rigorous comparative cohort studies) that compare a testing strategy (and related clinical management) with a strategy of no testing (and related clinical management) are needed. Sufficient sample size may be a challenge given the low prevalence of CAD that is likely in this group.
Patient Populations | Few active trials listed in ClinicalTrials.gov pertain to symptomatic patients without known CAD, yet this group of patients commonly presents for evaluation and testing, particularly in outpatient settings. (See Appendix K). | Future studies focused on those without known/prior CAD history or studies that analyze outcomes for this group of patients separately from those with known CAD are needed.
Patient Populations | There is a paucity of high-quality studies comparing various testing strategies in outpatient clinic populations. | Studies of patients who typically present in outpatient settings are needed. Greater integration of cardiologists into hospital settings may facilitate the conduct of studies of outpatients and enhance opportunities for followup of patients initially presenting to the ED.
Patient Populations | Studies do not generally report the extent to which clinical decisionmaking and clinical outcomes may be modified by patient characteristics, sociodemographic factors (e.g., age, sex, race, ethnicity, education, socioeconomic status) or provider characteristics. | RCTs or pragmatic trials with sufficient sample size to compare differential effectiveness and safety of testing strategies based on prespecified analyses are needed.
Interventions and Comparators | There is a lack of studies comparing outcomes following testing and resulting treatment strategies vs. a strategy of clinical evaluation without testing and resultant treatment strategies. | Studies (RCTs, pragmatic trials or methodologically rigorous comparative cohort studies) that compare a testing strategy (and related clinical management) with a strategy of no testing (and related clinical management) are needed.
Interventions and Comparators | Older studies of established tests (particularly functional tests) may not be as applicable in light of advances in technology. There was a paucity of studies comparing functional tests with each other. | Studies (RCTs, pragmatic trials or methodologically rigorous comparative cohort studies) that compare functional tests using more state of the art technology and methods with each other and with anatomic tests are needed. New studies should focus on the impact each test makes on clinical decisionmaking and hard clinical outcomes.
Outcome Measures | Studies comparing of the impact of noninvasive testing on hard clinical outcomes in those without known CAD are few compared with studies of test accuracy. | Additional sufficiently powered studies examining the impact of testing on hard clinical outcomes (death, MI) at longer-term followup (>12 months) are needed.
Outcome Measures | There is limited high-quality comparative evidence linking established tests with clinical decisionmaking and subsequent outcomes in the population of interest by pretest risk, particularly in nonemergent settings and over the longer term. Further, there is limited evidence on the impact of tests on post-test risk stratification and the best testing strategy(ies) for post-test risk stratification to identify patients who may be at highest risk and may benefit most from various treatment strategies. It is not clear whether the individuals who would most benefit from given treatment strategies were referred to those strategies and whether the strategies were effective. | Studies that document and compare tests with regard to their impact on prespecified clinical decisionmaking components (e.g., referral for additional testing, initiation or change in medication), particularly in outpatient settings, are needed. Such documentation should also include: post-test risk stratification and factors that influenced its determination, what decisions were made based on the test results (positive, negative or inconclusive results) and impact on hard clinical outcomes (death, MI) over time.
Outcome Measures | There is limited evidence on the impact of testing strategies (including consequences of downstream testing and treatment) on patient-related outcomes such as quality of life and symptom status. | Future studies should incorporate standardized, validated measures for patient reported outcomes and document the impact of testing, including downstream testing, on patient psychological status (particularly with false positive results), health status and resource use.
Outcome Measures | Adverse events and consequences of testing are poorly reported. | Future study protocols should delineate, a priori, possible adverse events and consequences (including those related to psychological aspects of testing, radiation exposure, resource use) and report their occurrence per the protocol.
Analysis | The lack of a standardized approach to determining and reporting pretest risk across studies and variable definitions of pretest risk used in included studies precluded ability to effectively stratify by pretest risk or pool data. | Individual patient data meta-analysis of RCTs may provide opportunities to use a standardized approach for pretest risk stratification and may facilitate evaluation of modification by patient characteristics and other factors.
Analysis | A number of studies did not provide details for pretest risk or report results stratified by pretest risk. | Studies should stratify by pretest risk of CAD using a standard method and report outcomes based on pretest risk strata.

CAD = coronary artery disease; ED = emergency department; MI = myocardial infarction; RCT = randomized controlled trial