# Conclusion

A review of current studies found no clear differences between testing strategies across settings with regard to clinical or management outcomes that would allow recommendation of one strategy over another for any given pretest risk group that included patients with intermediate pretest risk. No conclusions regarding low-risk patients or those without acute coronary syndrome at high risk were possible. Limited evidence from randomized controlled trials (RCTs) found no clear differences between coronary computed tomography angiography (CCTA) versus other strategies in clinical outcomes across risk groups, although anatomic testing may result in a higher frequency of referral for invasive coronary angiography (ICA) and revascularization. The frequency of all-cause mortality and myocardial infarction (MI) was low across studies in all settings. The absence of information on post-test risk stratification and subsequent decisionmaking precluded evaluation of the impact of testing on patient management or outcomes of management. Testing strategies vary in radiation exposure; there is inadequate comparative evidence to make judgments regarding exposure for the initial test or downstream testing. Assessment of harms was limited. Future research using more refined, evidence-based definitions of pretest risk, coupled with information on post-test risk stratification, its impact on clinical management (treatment and referral for additional testing) and longer-term followup to assess clinical outcomes, is needed to determine optimal testing strategies and roles of tests in different pretest risk groups.