# Appendix References

1 Chang SA, Choi SI, Choi EK, et al. Usefulness of 64-slice multidetector computed tomography as an initial diagnostic approach in patients with acute chest pain. Am Heart J. Aug. 2008;156(2):375-83. [pmid: 18657674].
2 Sabharwal NK, Stoykova B, Taneja AK, et al. A randomized trial of exercise treadmill ECG versus stress SPECT myocardial perfusion imaging as an initial diagnostic strategy in stable patients with chest pain and suspected CAD: cost analysis. [Erratum appears in J Nucl Cardiol. 2007 May-Jun;14(3):414]. J Nucl Cardiol. Apr. 2007;14(2):174-86. [pmid: 17386379].
3 Sanfilippo AJ, Abdollah H, Knott TC, et al. Stress echocardiography in the evaluation of women presenting with chest pain syndrome: a randomized, prospective comparison with electrocardiographic stress testing. Can J Cardiol. Apr. 2005;21(5):405-12. [pmid: 15861257].
4 McKavanagh P, Lusk L, Ball PA, et al. A comparison of cardiac computerized tomography and exercise stress electrocardiogram test for the investigation of stable chest pain: the clinical results of the CAPP randomized prospective trial. Eur Heart J Cardiovasc Imaging. 2014. Dec. 3. [pmid: 25473041].
5 Marwick TH, Shaw L, Case C, et al. Clinical and economic impact of exercise electrocardiography and exercise echocardiography in clinical practice. Eur Heart J. Jun. 2003;24(12):1153-63. [pmid: 12804930].
6 Shreibati JB, Baker LC, Hlatky MA. Association of coronary CT angiography or stress testing with subsequent utilization and spending among Medicare beneficiaries. JAMA. Nov. 16. 2011;306(19):2128-36. [pmid: 22089720].
7 Yamauchi T, Tamaki N, Kasanuki H, et al. Optimal initial diagnostic strategies for the evaluation of stable angina patients: a multicenter, prospective study on myocardial perfusion imaging, computed tomographic angiography, and coronary angiography. Circ J. 2012;76(12):2832-9. [pmid: 22975716].
8 Tandon V, Hall D, Yam Y, et al. Rates of downstream invasive coronary angiographyand revascularization: computed tomographic coronary angiography vs. Tc-99m single photon emission computed tomography. Eur Heart J. Mar. 2012;33(6):776-82. [pmid: 21893487].
9 Min JK, Shaw LJ, Berman DS, et al. Costs and clinical outcomes in individuals without known coronary artery disease undergoing coronary computed tomographic angiography from an analysis of Medicare category III transaction codes. Am J Cardiol. Sep. 15. 2008;102(6):672-8. [pmid: 18773986].
10 Min JK, Koduru S, Dunning AM, et al. Coronary CT angiography versus myocardial perfusion imaging for near-term quality of life, cost and radiation exposure: a prospective multicenter randomized pilot trial. J Cardiovasc Comput Tomogr. Jul-Aug. 2012;6(4):274-83. [pmid: 22732201].
11 Hachamovitch R, Nutter B, Hlatky MA, et al. Patient management after noninvasive cardiac imaging results from SPARC (Study of myocardial perfusion and coronary anatomy imaging roles in coronary artery disease). J Am Coll Cardiol. Jan. 31. 2012;59(5):462-74. [pmid: 22281249].
12 Hlatky MA, Shilane D, Hachamovitch R, et al. Economic outcomes in the Study of Myocardial Perfusion and Coronary Anatomy Imaging Roles in Coronary Artery Disease registry: the SPARC Study. J Am Coll Cardiol. Mar. 18. 2014;63(10):1002-8. [pmid: 24636556].
13 Hoffmann U, Truong QA, Schoenfeld DA, et al. Coronary CT angiography versus standard evaluation in acute chest pain. N Engl J Med. Jul. 26. 2012;367(4):299-308. [pmid: 22830462].
14 Shaw LJ, Mieres JH, Hendel RH, et al. Comparative effectiveness of exercise electrocardiography with or without myocardial perfusion single photon emission computed tomography in women with suspected coronary artery disease: results from the What Is the Optimal Method for Ischemia Evaluation in Women (WOMEN) trial. Circulation. Sep. 13. 2011;124(11):1239-49. [pmid: 21844080].
15 Douglas PS, Hoffmann U, Patel MR, et al. Outcomes of Anatomical versus Functional Testing for Coronary Artery Disease. N Engl J Med. Apr. 2. 2015;372(14):1291-300. [pmid: 25773919].
16 Levsky JM, Spevack DM, Travin MI, et al. Coronary Computed Tomography Angiography Versus Radionuclide Myocardial Perfusion Imaging in Patients With Chest Pain Admitted to Telemetry: A Randomized Trial. Ann Intern Med. Aug. 4. 2015;163(3):174-83. [pmid: 26052677].
17 Henzler T, Gruettner J, Meyer M, et al. Coronary computed tomography and triple rule out CT in patients with acute chest pain and an intermediate cardiac risk for acute coronary syndrome: part 2: economic aspects. Eur J Radiol. Jan. 2013;82(1):106-11. [pmid: 22835878].
18 Gruettner J, Fink C, Walter T, et al. Coronary computed tomography and triple rule out CT in patients with acute chest pain and an intermediate cardiac risk profile. Part 1: impact on patient management. Eur J Radiol. Jan. 2013;82(1):100-5. [pmid: 22749769].
19 Litt HI, Gatsonis C, Snyder B, et al. CT angiography for safe discharge of patients with possible acute coronary syndromes. N Engl J Med. Apr. 12. 2012;366(15):1393-403. [pmid: 22449295].
20 Miller AH, Pepe PE, Peshock R, et al. Is coronary computed tomography angiography a resource sparing strategy in the risk stratification and evaluation of acute chest pain? Results of a randomized controlled trial. Acad Emerg Med. May. 2011;18(5):458-67. [pmid: 21569165].
21 Goldstein JA, Chinnaiyan KM, Abidov A, et al. The CT-STAT (Coronary Computed Tomographic Angiography for Systematic Triage of Acute Chest Pain Patients to Treatment) trial. J Am Coll Cardiol. Sep. 27. 2011;58(14):1414-22. [pmid: 21939822].
22 Hamilton-Craig C, Fifoot A, Hansen M, et al. Diagnostic performance and cost of CT angiography versus stress ECG--a randomized prospective study of suspected acute coronary syndrome chest pain in the emergency department (CT-COMPARE). Int J Cardiol. Dec. 20. 2014;177(3):867-73. [pmid: 25466568].
23 Goldstein JA, Gallagher MJ, O'Neill WW, et al. A randomized controlled trial of multi-slice coronary computed tomography for evaluation of acute chest pain. J Am Coll Cardiol. Feb. 27. 2007;49(8):863-71. [pmid: 17320744].
24 Poon M, Cortegiano M, Abramowicz AJ, et al. Associations between routine coronary computed tomographic angiography and reduced unnecessary hospital admissions, length of stay, recidivism rates, and invasive coronary angiography in the emergency department triage of chest pain. J Am Coll Cardiol. Aug. 6. 2013;62(6):543-52. [pmid: 23684682].
25 Cheezum MK, Hulten EA, Taylor AJ, et al. Cardiac CT angiography compared with myocardial perfusion stress testing on downstream resource utilization. J Cardiovasc Comput Tomogr. Mar-Apr. 2011;5(2):101-9. [pmid: 21256102].
26 Nielsen LH, Markenvard J, Jensen JM, et al. Frontline diagnostic evaluation of patients suspected of angina by coronary computed tomography reduces downstream resource utilization when compared to conventional ischemia testing. Int J Cardiovasc Imaging. Jul. 2011;27(6):813-23. [pmid: 21042860].
27 Nielsen LH, Olsen J, Markenvard J, et al. Effects on costs of frontline diagnostic evaluation in patients suspected of angina: coronary computed tomography angiography vs. conventional ischaemia testing. Eur Heart J Cardiovasc Imaging. May. 2013;14(5):449-55. [pmid: 22922828].
28 Dodi C, Cortigiani L, Masini M, et al. The incremental prognostic value of pharmacological stress echo over exercise electrocardiography in women with chest pain of unknown origin. Eur Heart J. Jan. 2001;22(2):145-52. [pmid: 11161916].
29 Ferrara N, Leosco D, Abete P, et al. Dipyridamole echocardiography as a useful and safe test in the assessment of coronary artery disease in the elderly. J Am Geriatr Soc. Oct. 1991;39(10):993-9. [pmid: 1918787].
30 Severi S, Picano E, Michelassi C, et al. Diagnostic and prognostic value of dipyridamole echocardiography in patients with suspected coronary artery disease. Comparison with exercise electrocardiography. Circulation. Mar. 1994;89(3):1160-73. [pmid: 8124803].
31 Takeuchi M, Sonoda S, Miura Y, et al. Comparative diagnostic value of dobutamine stress echocardiography and stress thallium-201 single-photon-emission computed tomography for detecting coronary artery disease in women. Coron Artery Dis. Nov. 1996;7(11):831-5. [pmid: 8993941].
32 Guidelines for the management of acute coronary syndromes 2006. Med J Aust. Apr. 17. 2006;184(8 Suppl):S9-29. [pmid: 16618231].
33 Campeau L. Letter: Grading of angina pectoris. Circulation. Sep. 1976;54(3):522-3. [pmid: 947585].
34 Versteylen MO, Kietselaer BL, Dagnelie PC, et al. Additive value of semiautomated quantification of coronary artery disease using cardiac computed tomographic angiography to predict future acute coronary syndrome. J Am Coll Cardiol. Jun. 4. 2013;61(22):2296-305. [pmid: 23562925].
35 Goldman L, Cook EF, Johnson PA, et al. Prediction of the need for intensive care in patients who come to the emergency departments with acute chest pain. N Engl J Med. Jun. 6. 1996;334(23):1498-504. [pmid: 8618604].
36 Reilly BM, Evans AT, Schaider JJ, et al. Impact of a clinical decision rule on hospital triage of patients with suspected acute cardiac ischemia in the emergency department. JAMA. Jul. 17. 2002;288(3):342-50. [pmid: 12117399].
37 Antman EM, Cohen M, Bernink PJ, et al. The TIMI risk score for unstable angina/non-ST elevation MI: A method for prognostication and therapeutic decision making. JAMA. Aug. 16. 2000;284(7):835-42. [pmid: 10938172].
38 Pryor DB, Shaw L, McCants CB, et al. Value of the history and physical in identifying patients at increased risk for coronary artery disease. Ann Intern Med. Jan. 15. 1993;118(2):81-90. [pmid: 8416322].
39 Buchsbaum M, Marshall E, Levine B, et al. Emergency department evaluation of chest pain using exercise stress echocardiography. Acad Emerg Med. Feb. 2001;8(2):196-9. [pmid: 11157301].
40 Elhendy A, Shub C, McCully RB, et al. Exercise echocardiography for the prognostic stratification of patients with low pretest probability of coronary artery disease. Am J Med. Jul. 2001;111(1):18-23. [pmid: 11448656].
41 Innocenti F, Cerabona P, Donnini C, et al. Long-term prognostic value of stress echocardiography in patients presenting to the ED with spontaneous chest pain. Am J Emerg Med. Jul. 2014;32(7):731-6. [pmid: 24768667].
42 Petretta M, Daniele S, Acampa W, et al. Prognostic value of coronary artery calcium score and coronary CT angiography in patients with intermediate risk of coronary artery disease. Int J Cardiovasc Imaging. Aug. 2012;28(6):1547-56. [pmid: 21922205].
43 Villines TC, Hulten EA, Shaw LJ, et al. Prevalence and severity of coronary artery disease and adverse events among symptomatic patients with coronary artery calcification scores of zero undergoing coronary computed tomography angiography: results from the CONFIRM (Coronary CT Angiography Evaluation for Clinical Outcomes: An International Multicenter) registry. J Am Coll Cardiol. Dec. 6. 2011;58(24):2533-40. [pmid: 22079127].
44 Fine NM, Pellikka PA, Scott CG, et al. Characteristics and outcomes of patients who achieve high workload (>10 metabolic equivalents) during treadmill exercise echocardiography. Mayo Clin Proc. Dec. 2013;88(12):1408-19. [pmid: 24290114].
45 Colon PJ 3rd, Guarisco JS, Murgo J, et al. Utility of stress echocardiography in the triage of patients with atypical chest pain from the emergency department. Am J Cardiol. Nov. 15. 1998;82(10):1282-4. A10. [pmid: 9832109].
46 Cho I, Shim J, Chang HJ, et al. Prognostic value of multidetector coronary computed tomography angiography in relation to exercise electrocardiogram in patients with suspected coronary artery disease. J Am Coll Cardiol. Nov. 20. 2012;60(21):2205-15. [pmid: 23103039].
47 Dedic A, Genders TS, Ferket BS, et al. Stable angina pectoris: head-to-head comparison of prognostic value of cardiac CT and exercise testing. Radiology. Nov. 2011;261(2):428-36. [pmid: 21873254].
48 Hachamovitch R, Berman DS, Kiat H, et al. Exercise myocardial perfusion SPECT in patients without known coronary artery disease: incremental prognostic value and use in risk stratification. Circulation. Mar. 1. 1996;93(5):905-14. [pmid: 8598081].
49 Kim YJ, Hur J, Lee HJ, et al. Meaning of zero coronary calcium score in symptomatic patients referred for coronary computed tomographic angiography. Eur Heart J Cardiovasc Imaging. Sep. 2012;13(9):776-85. [pmid: 22461571].
50 Laudon DA, Behrenbeck TR, Wood CM, et al. Computed tomographic coronary artery calcium assessment for evaluating chest pain in the emergency department: long-term outcome of a prospective blind study. Mayo Clin Proc. Apr. 2010;85(4):314-22. [pmid: 20360291].
51 Krivokapich J, Child JS, Gerber RS, et al. Prognostic usefulness of positive or negative exercise stress echocardiography for predicting coronary events in ensuing twelve months. Am J Cardiol. Mar. 15. 1993;71(8):646-51. [pmid: 8447259].
52 Gentile R, Vitarelli A, Schillaci O, et al. Diagnostic accuracy and prognostic implications of stress testing for coronary artery disease in the elderly. Ital Heart J. Jul. 2001;2(7):539-45. [pmid: 11501963].
53 Heupler S, Mehta R, Lobo A, et al. Prognostic implications of exercise echocardiography in women with known or suspected coronary artery disease. J Am Coll Cardiol. Aug. 1997;30(2):414-20. [pmid: 9247513].
54 Schmermund A, Stang A, Mohlenkamp S, et al. Prognostic value of electron-beam computed tomography-derived coronary calcium scores compared with clinical parameters in patients evaluated for coronary artery disease. Prognostic value of EBCT in symptomatic patients. Zeitschrift fur Kardiologie. Sep. 2004;93(9):696-705. [pmid: 15365737].
55 Masini M, Picano E, Lattanzi F, et al. High dose dipyridamole-echocardiography test in women: correlation with exercise-electrocardiography test and coronary arteriography. J Am Coll Cardiol. Sep. 1988;12(3):682-5. [pmid: 3403825].
56 Nabi F, Chang SM, Pratt CM, et al. Coronary artery calcium scoring in the emergency department: identifying which patients with chest pain can be safely discharged home. Ann Emerg Med. Sep. 2010;56(3):220-9. [pmid: 20138399].
57 Nance JW Jr., Schlett CL, Schoepf UJ, et al. Incremental prognostic value of different components of coronary atherosclerotic plaque at cardiac CT angiography beyond coronary calcification in patients with acute chest pain. Radiology. Sep. 2012;264(3):679-90. [pmid: 22820732].
58 Dolor RJ, Patel MR, Melloni C, et al. Noninvasive Technologies for the Diagnosis of Coronary Artery Disease in Women. Comparative Effectiveness Review. 58. (Prepared by the Duke Evidence-based Practice Center under Contract No. 290-2007-10066-I.) AHRQ Publication No. 12-EHC034-EF. Rockville, MD. Agency for Healthcare Research and Quality. June. 2012. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
59 de Jong MC, Genders TS, van Geuns RJ, et al. Diagnostic performance of stress myocardial perfusion imaging for coronary artery disease: a systematic review and meta-analysis. Eur Radiol. Sep. 2012;22(9):1881-95. [pmid: 22527375].
60 Ladapo JA, Blecker S, Elashoff MR, et al. Clinical implications of referral bias in the diagnostic performance of exercise testing for coronary artery disease. J Am Heart Assoc. 2013;2(6):e000505. [pmid: 24334965].
61 Mc Ardle BA, Dowsley TF, deKemp RA, et al. Does rubidium-82 PET have superior accuracy to SPECT perfusion imaging for the diagnosis of obstructive coronary disease?: A systematic review and meta-analysis. J Am Coll Cardiol. Oct. 30. 2012;60(18):1828-37. [pmid: 23040573].
62 Jaarsma C, Leiner T, Bekkers SC, et al. Diagnostic performance of noninvasive myocardial perfusion imaging using single-photon emission computed tomography, cardiac magnetic resonance, and positron emission tomography imaging for the detection of obstructive coronary artery disease: a meta-analysis. J Am Coll Cardiol. May. 8. 2012;59(19):1719-28. [pmid: 22554604].
63 Nandalur KR, Dwamena BA, Choudhri AF, et al. Diagnostic performance of stress cardiac magnetic resonance imaging in the detection of coronary artery disease: a meta-analysis. Journal of the American College of CardiologyJ Am Coll Cardiol. Oct. 2. 2007;50(14):1343-53. [pmid: 17903634].
64 Skelly AC, Ecker ED, Henrikson NB, et al. Coronary Artery Calcium Scoring (CACS) as a Diagnostic Test for Detection of Coronary Artery Disease. Olympia, WA. Washington State Health Care Authority; Health Technology Assessment Program. September. 4. 2009. http://www.hta.hca.wa.gov/documents/calcium_scoring_report_final_090409.pdf.
65 Sarwar A, Shaw LJ, Shapiro MD, et al. Diagnostic and prognostic value of absence of coronary artery calcification. JACC Cardiovasc Imaging. Jun. 2009;2(6):675-88. [pmid: 19520336].
66 von Ballmoos MW, Haring B, Juillerat P, et al. Meta-analysis: diagnostic performance of low-radiation-dose coronary computed tomography angiography. [Erratum appears in Ann Intern Med. 2011 Jun 21;154(12):848]. Ann Intern Med. Mar. 15. 2011;154(6):413-20. [pmid: 21403076].
67 Paech DC, Weston AR. A systematic review of the clinical effectiveness of 64-slice or higher computed tomography angiography as an alternative to invasive coronary angiography in the investigation of suspected coronary artery disease. BMC Cardiovasc Disord. 2011;11:32. [pmid: 21679468].
68 Truong QA, Hayden D, Woodard PK, et al. Sex differences in the effectiveness of early coronary computed tomographic angiography compared with standard emergency department evaluation for acute chest pain: the rule-out myocardial infarction with Computer-Assisted Tomography (ROMICAT)-II Trial. Circulation. Jun. 25. 2013;127(25):2494-502. [pmid: 23685743].
69 Douglas PS, Hoffmann U, Lee KL, et al. PROspective Multicenter Imaging Study for Evaluation of chest pain: rationale and design of the PROMISE trial. Am Heart J. Jun. 2014;167(6):796-803 e1. [pmid: 24890527].