# Clinical Trials in Patients With Suspected Coronary Artery Disease

Table K1 Clinical trials in patients with suspected coronary artery disease listed on the Clinical Trials Web Site (ClinicalTrials.gov)

Trial Name (Number) | Intervention | Condition (Estimated N) | Outcomes | Status (Estimated Completion) Related Publications
Stress Testing Compared to Coronary Computed Tomographic Angiography in Patients With Suspected Coronary Artery Disease (NCT01368770) | Stress MPI, SPECT, CCTA | Patients with chest pain or suspected CAD N=303 | - Angiography; - Revascularization; - MACE | Completed, June 2014 Publications: not provided
Computed Tomography Versus Exercise Testing in Suspected Coronary Artery Disease (NCT01393028) | CCTA, CCS, Usual Care | Patients with chest pain N=350 | - Chest pain; - Revascularization; - Overall medical expenses; - Cost-effectiveness; - Radiation dose; - MACE; - QOL | Terminated, Estimated completion July 2011 Publications: not provided
Coronary CT Angiography as the Primary Initial Method of Evaluating Patients With Subacute Chest Pain (CT PRIME) (NCT00584337) | CCTA, Usual Care | Patients with chest pain N=300 | - Diagnostic accuracy | Withdrawn prior to enrollment, estimated completion June 2009 Publications: not provided
PROspective Multicenter Imaging Study for Evaluation of Chest Pain - The PROMISE Trial (NCT01174550) | Coronary angiography, stress echocardiography, nuclear stress test, exercise ECG | Patients with chest pain N=10,003 | - Death; - MI; - Unstable angina hospitalization; - Major complications from CV procedures; - Cumulative radiation exposure; - Medical costs; - QOL | Completed, October 2014 Publications: Douglas (2015)15; Douglas (2014)69 included in present report
Usefulness of Coronary CTA for the Diagnosis of Acute Coronary Syndrome in the Emergency Room. (NCT01682096) | CCTA, Exercise echocardiography | Patients with chest pain N=150 | - Diagnosis of acute coronary syndrome; - MACE; - Costs during admission | Completed, October 2013 Publications: not provided
Utility of 2D Strain Echocardiography in Triage of Patients With Chest Pain in the Emergency Department (NCT01163019) | Echocardiography, ECG, nuclear imaging | Patients with chest pain N=700 | - Diagnosis of acute coronary syndrome; - Significant CAD; - MACE | Completed, February 2014 Publications: not provided
Myocardial Perfusion Assessment With Multidetector Computed Tomography (NCT00846079) | Multi-detector CT | Patients with suspected CAD N=100 | - Diagnostic accuracy; - Radiation dosimetry | Unknown, Estimated completion September 2009 Publications: not provided
Association of Endothelial Function and Clinical Outcomes in Subjects Admitted to Chest Pain Unit (NCT01618123) | ECG, EndoPAT, stress nuclear imaging, stress echo | Patients with chest pain N=300 | - Long-term outcomes; - Short-term outcomes (no further details provided) | Recruiting, July 2015 Publications: not provided
A Study of Stress Heart Imaging in Patients With Diabetes at Risk for Coronary Disease. (NCT00162344) | MPI, Exercise ECG | Diabetic patients with atypical chest pain N=205 | - Diagnosis of ischemic heart disease; - Diagnostic accuracy; - Relative value for identifying risk | Completed, December 2005 Publications: not provided
Role of Cardiac CT in Rapid Access Chest Pain Clinics (RADICAL) (NCT01464203) | CCTA, Usual Care | Patients with chest pain N=600 | - Diagnostic accuracy; - QOL; - Number of invasive angiograms; - Revascularization; - Prognostic value | Unknown, Estimated completion December 2011 Publications: Yerramasu (2010)^*^; Yerramasu (2014)^†^
Combined Use of Coronary MDCTA, Coronary Doppler Ultrasonography and PET Perfusion in Diagnosing Coronary Artery Disease (PECTUS) (NCT00627172) | CCTA, PET, ICA, FFR | Patients with chest pain N=107 | - Diagnosis of coronary artery lesions; - QOL | Completed, January 2007 Publications: Kajander (2011)^*^; Bucci (2011)^*^; Kajander (2010)^*^
Stress Testing Versus Non-Stress Testing Based Strategy in Patients Hospitalized With Low-Risk Acute Coronary Syndromes: A Randomized, Single-Center Pilot Study (NCT01703156) | Stress test, no stress test | Patients with chest pain N=70 | - All-cause mortality; - Hospitalization for STEMI; - Revascularization; - Angiography; - Further testing; - Medication adjustments; - Medication side effects | Completed, July 2012 Publications: not provided

CAD = coronary artery disease; CACS = coronary artery calcium scan; CCTA = coronary computed tomography angiogram; ECG = electrocardiogram; FFR = fractional flow reserve; ICA = invasive coronary angiography; MACE = major adverse cardiovascular events; MPI = myocardial perfusion imaging; QOL = quality of life; SPECT = single photon-emission computed tomography

* Excluded from present report at title/abstract.

† Missed by literature search.