# Strength of Evidence Tables

[underlined: Strength of Evidence Grades:]

“High” grade indicates high confidence that the evidence reflects the true effect and that further research is very unlikely to change our confidence in the estimate of effect;

“Moderate” grade indicates moderate confidence that the evidence reflects the true effect and further research may change our confidence in the estimate of effect and may change the estimate;

“Low” grade indicates low confidence that the evidence reflects the true effect and further research is likely to change the confidence in the estimate of effect and is likely to change the estimate;

“Insufficient” grade indicates evidence either is unavailable or is too limited to permit any conclusion, due to the availability of only poor-quality studies, extreme inconsistency, or extreme imprecision.

[underlined: Final Strength of Evidence Note]: Outcomes for which data from randomized controlled trials (RCTs) and observational studies were available, if the strength of evidence for the observational studies was deemed insufficient, the final strength of evidence was based on RCT.

Table J1 Strength of evidence for included studies with patients considered to be at low risk for coronary artery disease

Table J2 Strength of evidence for included studies with patients considered to be at low to intermediate risk for coronary artery disease

Table J3 Strength of evidence for included studies with patients considered to be at intermediate risk for coronary artery disease

Table J4 Strength of evidence for included studies with patients considered to be at intermediate to high risk for coronary artery disease

Table J5 Strength of evidence for included studies with patients considered to be at high risk for coronary artery disease

Table J6 Strength of evidence for comparative studies with patients of mixed risk