# Quality Ratings for Included Studies

## Quality Ratings

Good-quality studies include clear descriptions of the population, setting, interventions, and comparison groups; a valid method for allocation of patients to treatment; low dropout rates and clear reporting of dropouts; appropriate means for preventing bias; and appropriate measurement of outcomes. Good quality studies are considered to have the least risk of bias and their results are considered valid.

Fair-quality studies may not meet all the criteria for a rating of good quality, but no flaw is likely to cause major bias. The study may be missing information, making it difficult to assess limitations and potential problems. The fair-quality category is broad, and studies with this rating will vary in their strengths and weaknesses. The results of some fair-quality studies are likely to be valid, while others may be only possibly valid. Fair-quality studies are susceptible to some bias, though not enough to invalidate the results.

Poor-quality studies have a serious or “fatal” flaw in design, analysis, or reporting; large amounts of missing information; discrepancies in reporting; or serious problems in the delivery of the intervention. The results of these studies are at least as likely to reflect flaws in the study design as the true difference between the compared interventions. Poor quality studies have significant flaws that imply biases of various types that may invalidate the results.

Table I1 Individual study quality ratings in patients with mixed pretest risk for CAD

Table I2 Individual study quality ratings in patients considered to have intermediate to high pretest risk for CAD

Table I3 Individual study quality ratings in patients considered to have low to intermediate pretest risk for CAD

Table I4 Individual study quality ratings in patients considered to have intermediate pretest risk for CAD