# Diagnostic Accuracy of Noninvasive Tests in Included Studies

Table H1 Diagnostic accuracy: Exercise ECG compared with coronary angiography as reference standard for diagnosis of CAD

Table H2 Diagnostic accuracy: Stress echocardiography compared with coronary angiography as reference standard for diagnosis of CAD

Table H3 Diagnostic accuracy: Single photon emission computed tomography compared with coronary angiography as reference standard for diagnosis of CAD

Table H4 Diagnostic accuracy: Positron emission tomography compared with coronary angiography as reference standard for diagnosis of CAD

Table H5 Diagnostic accuracy: Stress cardiac magnetic resonance imaging compared with coronary angiography as reference standard for diagnosis of CAD

Table H6 Diagnostic accuracy: Coronary artery calcification (CAC score >0) compared with coronary angiography as reference standard for diagnosis of CAD

Table H7 Diagnostic accuracy: Coronary computed tomography angiography compared with coronary angiography as reference standard for diagnosis of CAD