# Safety Information in Included Comparative Studies and Studies Included for Safety Information Only

## Safety Results for Studies Included for Safety Information Only

Table G1 Demographics for observational studies where patients received both stress echo and a second test and are included for safety information only**

Table G2 Demographics for observational studies where patients received both computed tomography and CACS tests and are included for safety information only

## Safety Results for Included Comparative Studies

Table G3 Safety outcomes reported in included comparative studies

Table G4 Radiation exposure in included comparative studies