# Evidence Tables for Noncomparative Studies

Table F1 Demographics and study characteristics for noncomparative stress echocardiography studies with patients at low risk

Table F2 Summary clinical outcomes from single arm studies of stress echocardiography in patients at low risk

Table F3 Demographics and study characteristics for single arm coronary artery calcium scoring studies with patients at intermediate risk

Table F4 Summary outcomes for single arm coronary artery calcium scoring studies with patients at intermediate risk

Table F5 Demographics and study characteristics for single arm stress echocardiography studies with patients at low to intermediate risk

Table F6 Summary outcomes for single arm stress echocardiography studies with patients at low to intermediate risk

Table F7 Demographics and study characteristics for single arm stress electrocardiogram (ECG) studies with patients at low to intermediate risk

Table F8 Summary outcomes for single arm stress echocardiography studies with patients at low to intermediate risk

Table F9 Demographics and study characteristics for single arm coronary artery calcium scoring studies with patients at low to intermediate risk

Table F10 Summary outcomes for single arm coronary artery calcium scoring studies with patients at low to intermediate risk

Table F11 Demographics and study characteristics for single arm stress echocardiography studies with patients at intermediate to high risk

Table F12 Summary outcomes for single arm stress echocardiography studies with patients at intermediate to high risk

Table F13 Demographics and study characteristics for single arm stress echocardiography studies with patients not stratified by risk

Table F14 Summary results for single arm stress echocardiography studies with patients not stratified by risk

Table F15 Demographics and study characteristics for single arm stress electrocardiography (ECG) studies with patients not stratified by risk

Table F16 Summary results for single arm stress electrocardiography (ECG) studies with patients not stratified by risk

Table F17 Demographics and study characteristics for single arm coronary artery calcium scoring studies with patients not stratified by risk

Table F18 Summary results for single arm coronary artery calcium scoring studies with patients not stratified by risk