# Evidence Tables for Comparative Studies

Table E1 Demographics for included RCTs in populations with mixed risk for coronary artery disease

Table E2 Clinical outcomes from randomized controlled trials including populations with mixed risk for coronary artery disease

Table E3 Clinical management and hospitalization outcomes from randomized controlled trials including populations with mixed risk for coronary artery disease

Table E4 Demographics for observational studies in patients with mixed pretest risk for coronary artery disease comparing functional test versus functional test

Table E5 Clinical outcomes from observational studies including populations with mixed risk for coronary artery disease and comparing functional testing with functional testing

Table E6 Clinical management and hospitalization outcomes from observational studies including populations with mixed risk for coronary artery disease and comparing functional testing with functional testing

Table E7 Demographics for observational studies in patients with mixed pretest risk for coronary artery disease comparing anatomic test versus functional tests

Table E8 Clinical outcomes from observational studies including populations with mixed risk for coronary artery disease and comparing anatomical testing with functional testing

Table E9 Clinical management and hospitalization outcomes from observational studies including populations with mixed risk for coronary artery disease and comparing anatomical testing with functional testing

Table E10 Demographics for included RCTs in populations considered to be at high risk for coronary artery disease

Table E11 Clinical outcomes from randomized controlled trials including patients considered to be at high risk for coronary artery disease

Table E12 Clinical management outcomes from randomized controlled trials including patients considered to be at high risk for coronary artery disease

Table E13 Hospital and emergency department outcomes from randomized controlled trials including patients considered to be at high risk for coronary artery disease

Table E14 Demographics for the included RCT in a population considered to be at intermediate to high risk for coronary artery disease

Table E15 Clinical outcomes, clinical management outcomes, and hospitalization outcomes from randomized controlled trials including patients considered to be at intermediate to high risk for coronary artery disease

Table E16 Demographics for the included observational study in populations considered to be at intermediate to high risk for coronary artery disease

Table E17 Clinical outcomes, clinical management outcomes, and hospitalization outcomes from prospective observational studies including patients considered to be at low to intermediate risk for coronary artery disease

Table E18 Demographics for included RCTs in populations considered to be at intermediate risk for coronary artery disease

Table E19 Clinical outcomes from randomized controlled trials including patients considered to be at intermediate risk for coronary artery disease

Table E20 Clinical management outcomes from randomized controlled trials including patients considered to be at intermediate risk for coronary artery disease

Table E21 Hospital and emergency department outcomes from randomized controlled trials including patients considered to be at intermediate risk for coronary artery disease

Table E22 Demographics for the included RCT in a population considered to be at intermediate risk for coronary artery disease comparing CCTA to various functional tests

Table E23 Clinical outcomes for the included RCT in a population considered to be at intermediate risk for coronary artery disease comparing CCTA to various functional tests

Table E24 Clinical management outcomes from randomized controlled trials including patients considered to be at intermediate risk for coronary artery disease

Table E25 Hospital and emergency department outcomes for the included RCT in a population considered to be at intermediate risk for coronary artery disease comparing CCTA to various functional tests

Table E26 Demographics for the included RCT in a population considered to be at intermediate risk for coronary artery disease comparing CCTA to SPECT

Table E27 Clinical outcomes for the included RCT in a population considered to be at intermediate risk for coronary artery disease comparing CCTA to SPECT

Table E28 Clinical management outcomes for the included RCT in a population considered to be at intermediate risk for coronary artery disease comparing CCTA to SPECT

Table E29 Hospital and emergency department outcomes for the included RCT in a population considered to be at intermediate risk for coronary artery disease comparing CCTA to SPECT

Table E30 Demographics for the included observational study in populations considered to be at intermediate risk for coronary artery disease

Table E31 Clinical outcomes, clinical management outcomes, and hospital outcomes from observational studies including patients considered to be at intermediate risk for coronary artery disease

Table E32 Demographics for included RCTs in populations considered to be at low to intermediate risk for coronary artery disease

Table E33 Clinical outcomes from randomized controlled trials including patients considered to be at low to intermediate risk for coronary artery disease

Table E34 Clinical management outcomes from randomized controlled trials including patients considered to be at low to intermediate risk for coronary artery disease

Table E35 Hospital and emergency department outcomes from randomized controlled trials including patients considered to be at low to intermediate risk for coronary artery disease

Table E36 Demographics for included observational studies in populations considered to be at low to intermediate risk for coronary artery disease

Table E37 Clinical outcomes from retrospective observational studies including patients considered to be at low to intermediate risk for coronary artery disease

Table E38 Clinical management outcomes from retrospective observational studies including patients considered to be at low to intermediate risk for coronary artery disease

Table E39 Hospital or emergency department outcomes from retrospective observational studies including patients considered to be at low to intermediate risk for coronary artery disease*

Table E40 Demographics for included RCTs in populations considered to be at low risk for coronary artery disease

Table E41 Clinical outcomes from randomized controlled trials including patients considered to be at low risk for coronary artery disease

Table E42 Clinical management outcomes from randomized controlled trials including patients considered to be at low risk for coronary artery disease

Table E43 Hospital and emergency department outcomes from randomized controlled trials including patients considered to be at low risk for coronary artery disease*

Table E44 Pretest risk assessment in included studies

Table E45 Definition of risk assessment in included studies

Table E46 Definitions for usual care in included studies