# Sample Data Extraction Elements

- Author, year
- Study design
  ○ RCT
  ○ Prospective cohort
  ○ Retrospective cohort
  ○ Administrative database
- Country, number of centers (multicenter / single center), setting (inpatient, outpatient, emergency department, etc.), funding source
- Inclusion criteria
- Exclusion criteria
- Number enrolled, randomized, analyzed, complete followup (%, months)
- Followup time points
  ○ Note if followup was assessed in-person
  ○ Note any separate followup studies
- Tests evaluated (number of patients evaluated by each test)
- Test details
  ○ Type of stressor (specific modality- drug, type of exercise, etc.)
  ○ Contrast
  ○ Other pertinent details
- Definition of a positive test (as reported in text)
- Demographics
  ○ Age (mean)
  ○ % female
  ○ Race
  ○ Note any pertinent subgroups
- Baseline risk for CAD (e.g. very low, low, intermediate to high, high)
  ○ ACC pre-test likelihood (%)
  ○ Framingham
  ○ TIMI score
- Cardiovascular characteristics (%)
  ○ Chest pain
    ▪ Typical angina
    ▪ Atypical angina
    ▪ Nonspecific chest pain
  ○ Dyspnea
  ○ Prior myocardial infarction
  ○ Prior revascularization
  ○ Known CAD
  ○ Chest pain frequency
  ○ Hypertension
  ○ Hyperlipidemia
  ○ Diabetes
- Test results (i.e., normal vs. abnormal) (%)
- Clinical Health Outcomes, % (n/N) for each timepoint (include data if results were stratified by test result)
  ○ Quality of life
  ○ Change in angina
  ○ Myocardial infarction
  ○ Heart failure
  ○ Stroke
  ○ Death
  ○ Cardiovascular hospitalization for acute coronary syndrome, heart failure or arrhythmias
  ○ Dysrhythmia
  ○ Composite outcome (define)
- Adverse events, % (n/N) for each timepoint (include data if results were stratified by test result)
  ○ Harms of testing (renal failure, allergy, neprogenic systemic fibrosis, contrast-related harms, adverse reaction to medications used for stress testing)
  ○ Vascular complications
  ○ Risks and consequences of testing (radiation exposure, psychological consequences of diagnosis, need for additional testing)
- Clinical management outcomes, % (n/N) for each timepoint (include data if results were stratified by test result)
  ○ Additional testing (including referral for additional testing)
  ○ Clinical decisionmaking and management based on revised risk stratification (e.g., use of guideline-directed medical therapy including management of lipids, blood pressure and diabetes, counseling related to diet, physical activity, smoking cessation, alcohol use and management of psychological factors; use of additional therapies to reduce risk of MI and death (e.g., antiplatelet therapy)
  ○ Need for subsequent revascularization (PCI or CABG)
- Harms associated with additional testing
- Differential effectiveness for subgroups: Clinical outcomes
- Differential harms for subgroups
- Differential effectiveness for subgroups: clinical management