# List of Excluded Studies With Rationale

1 Abdelmoneim SS, Bernier M, Hagen ME, et al. A multicenter, prospective study to evaluate the use of contrast stress echocardiography in early menopausal women at risk for coronary artery disease: trial design and baseline findings. J Womens Health (Larchmt). Feb. 2013;22(2):173-83. Wrong population. [pmid: 23398128].
2 Abdelmoneim SS, Dhoble A, Bernier M, et al. Quantitative myocardial contrast echocardiography during pharmacological stress for diagnosis of coronary artery disease: a systematic review and meta-analysis of diagnostic accuracy studies. Eur J Echocardiogr. Oct. 2009;10(7):813-25. Wrong population, wrong intervention. [pmid: 19549700].
3 Abdulla J, Asferg C, Kofoed KF. Prognostic value of absence or presence of coronary artery disease determined by 64-slice computed tomography coronary angiography a systematic review and meta-analysis. Int J Cardiovasc Imaging. Mar. 2011;27(3):413-20. Wrong population. [pmid: 20549366].
4 Aggarwal NR, Knickelbine T, Tande A, et al. Noncalcified plaque: relationship between results of multislice computed tomography, risk factors, and late clinical outcome. Catheter Cardiovasc Interv. Dec. 1. 2011;78(7):1116-24. Wrong population. [pmid: 21542104].
5 Amemiya S, Takao H. Computed tomographic coronary angiography for diagnosing stable coronary artery disease: a cost-utility and cost-effectiveness analysis. Circ J. Jul. 2009;73(7):1263-70. Wrong outcomes. [pmid: 19436120].
6 Arruda AM, Das MK, Roger VL, et al. Prognostic value of exercise echocardiography in 2,632 patients > or = 65 years of age. J Am Coll Cardiol. Mar. 15. 2001;37(4):1036-41. Wrong population. [pmid: 11263605].
7 Arruda-Olson AM, Juracan EM, Mahoney DW, et al. Prognostic value of exercise echocardiography in 5,798 patients: is there a gender difference?. J Am Coll Cardiol. Feb. 20. 2002;39(4):625-31. Wrong population. [pmid: 11849861].
8 Ayaram D, Bellolio MF, Murad MH, et al. Triple rule-out computed tomographic angiography for chest pain: a diagnostic systematic review and meta-analysis. Acad Emerg Med. Sep. 2013;20(9):861-71. Wrong population, wrong intervention. [pmid: 24050793].
9 Bamberg F, Sommer WH, Hoffman V, et al. Meta-analysis and systematic review of the long-term predictive value of assessment of coronary atherosclerosis by contrast-enhanced coronary computed tomography angiography. J Am Coll Cardiol. Jun. 14. 2011;57(24):2426-36. Wrong outcomes. [pmid: 21658564].
10 Banerjee AN, Newman DR, Van den Bruel A, et al. Diagnostic accuracy of exercise stress testing for coronary artery disease: a systematic review and meta-analysis of prospective studies. Int J Clin Pract. May. 2012;66(5):477-92. Wrong intervention. [pmid: 22512607].
11 Biagini E, Shaw LJ, Poldermans D, et al. Accuracy of non-invasive techniques for diagnosis of coronary artery disease and prediction of cardiac events in patients with left bundle branch block: a meta-analysis. Eur J Nucl Med Mol Imaging. Dec. 2006;33(12):1442-51. Wrong population, systematic review or meta-analysis, original data used instead. [pmid: 16847655].
12 Bigi R, Desideri A, Cortigiani L, et al. Stress echocardiography for risk stratification of diabetic patients with known or suspected coronary artery disease. Diabetes Care. Sep. 2001;24(9):1596-601. Wrong population. [pmid: 11522705].
13 Bikiri E, Mereles D, Voss A, et al. Dobutamine stress cardiac magnetic resonance versus echocardiography for the assessment of outcome in patients with suspected or known coronary artery disease. Are the two imaging modalities comparable?. Int J Cardiol. Feb. 1. 2014;171(2):153-60. Wrong population. [pmid: 24342416].
14 Bingham SE, Hachamovitch R. Incremental prognostic significance of combined cardiac magnetic resonance imaging, adenosine stress perfusion, delayed enhancement, and left ventricular function over preimaging information for the prediction of adverse events. Circulation. Apr. 12. 2011;123(14):1509-18. Wrong population. [pmid: 21444886].
15 Bobbio M, Pollock BH, Cohen I, et al. Comparative accuracy of clinical tests for diagnosis and prognosis of coronary artery disease. Am J Cardiol. Nov. 1. 1988;62(13):896-900. Wrong intervention. [pmid: 3177237].
16 Bodi V, Sanchis J, Lopez-Lereu MP, et al. Prognostic and therapeutic implications of dipyridamole stress cardiovascular magnetic resonance on the basis of the ischaemic cascade. Heart. Jan. 2009;95(1):49-55. Wrong population. [pmid: 18381373].
17 Bodi V, Sanchis J, Lopez-Lereu MP, et al. Prognostic value of dipyridamole stress cardiovascular magnetic resonance imaging in patients with known or suspected coronary artery disease. J Am Coll Cardiol. Sep. 18. 2007;50(12):1174-9. Wrong population. [pmid: 17868810].
18 Bouzas-Mosquera A, Peteiro J, Alvarez-Garcia N, et al. Prognostic value of exercise echocardiography in patients with left bundle branch block. JACC Cardiovasc Imaging. Mar. 2009;2(3):251-9. Wrong population. [pmid: 19356568].
19 Bouzas-Mosquera A, Peteiro J, Broullon FJ, et al. Effect of atrial fibrillation on outcome in patients with known or suspected coronary artery disease referred for exercise stress testing. Am J Cardiol. May. 1. 2010;105(9):1207-11. Wrong population. [pmid: 20403467].
20 Bouzas-Mosquera A, Peteiro J, Broullon FJ, et al. Prognostic value of exercise echocardiography in patients with atrial fibrillation. Eur J Echocardiogr. May. 2010;11(4):346-51. Wrong population. [pmid: 20164089].
21 Bouzas-Mosquera A, Peteiro J, Broullon FJ, et al. Value of exercise echocardiography for predicting mortality in elderly patients. Eur J Clin Invest. Dec. 2010;40(12):1122-30. Wrong population. [pmid: 20718848].
22 Brown KA, Boucher CA, Okada RD, et al. Prognostic value of exercise thallium-201 imaging in patients presenting for evaluation of chest pain. J Am Coll Cardiol. Apr. 1983;1(4):994-1001. Wrong intervention, wrong comparison. [pmid: 6833659].
23 Buckert D, Dewes P, Walcher T, et al. Intermediate-term prognostic value of reversible perfusion deficit diagnosed by adenosine CMR: a prospective follow-up study in a consecutive patient population. JACC Cardiovasc Imaging. Jan. 2013;6(1):56-63. Wrong population. [pmid: 23328562].
24 Budoff MJ, Liu S, Chow D, et al. Coronary CT angiography versus standard of care strategies to evaluate patients with potential coronary artery disease; effect on long term clinical outcomes. Atherosclerosis. Dec. 2014;237(2):494-8. Wrong population. [pmid: 25463080].
25 Budoff MJ, Young R, Lopez VA, et al. Progression of coronary calcium and incident coronary heart disease events: MESA (Multi-Ethnic Study of Atherosclerosis). J Am Coll Cardiol. Mar. 26. 2013;61(12):1231-9. Wrong population. [pmid: 23500326].
26 Bunch AM. A systematic review of the predictive value of a coronary computed tomography angiography as compared with coronary calcium scoring in alternative noninvasive technique in detecting coronary artery disease and evaluating acute coronary syndrome in an acute care setting. Dccn. Mar-Apr. 2012;31(2):73-83. Systematic review or meta-analysis, using original studies instead. [pmid: 22333713].
27 Cardiac Magnetic Resonance Imaging (MRI) for Patients with Coronary Artery Disease: A Review of Diagnostic Accuracy. Ottawa, ON Canada. Canadian Agency for Drugs and Technologies in Health. Health Technology Inquiry Service (HTIS). February. 2009. Wrong outcomes.
28 Chang SM, Nabi F, Xu J, et al. Value of CACS Compared With ETT and Myocardial Perfusion Imaging for Predicting Long-Term Cardiac Outcome in Asymptomatic and Symptomatic Patients at Low Risk for Coronary Disease: Clinical Implications in a Multimodality Imaging World. JACC Cardiovasc Imaging. Feb. 2015;8(2):134-44. Wrong population. [pmid: 25677886].
29 Chatziioannou SN, Moore WH, Ford PV, et al. Prognostic value of myocardial perfusion imaging in patients with high exercise tolerance. Circulation. Feb. 23. 1999;99(7):867-72. Wrong population. [pmid: 10027807].
30 Chen L, Wang X, Bao J, et al. Direct comparison of cardiovascular magnetic resonance and single-photon emission computed tomography for detection of coronary artery disease: a meta-analysis. PLoS One. 2014;9(2):e88402. Wrong population. [pmid: 24520382].
31 Chow BJ, Al Shammeri OM, Beanlands RS, et al. Prognostic value of treadmill exercise and dobutamine stress positron emission tomography. Can J Cardiol. Jul. 2009;25(7):e220-4. Wrong population. [pmid: 19584976].
32 Christian TF, Miller TD, Bailey KR, et al. Exercise tomographic thallium-201 imaging in patients with severe coronary artery disease and normal electrocardiograms. Ann Intern Med. Dec. 1. 1994;121(11):825-32. Wrong outcomes. [pmid: 7794314].
33 Clark EE. Coronary Computed Tomographic Angiography. Portland. Center for Evidence-based Policy. 2011. Available at: http://www.ohsu.edu/xd/research/centers-institutes/evidence-based-policy-center/med/index.cfm. Wrong outcomes.
34 Coletta C, Galati A, Greco G, et al. Prognostic value of high dose dipyridamole echocardiography in patients with chronic coronary artery disease and preserved left ventricular function. J Am Coll Cardiol. Oct. 1995;26(4):887-94. Wrong population. [pmid: 7560613].
35 Computed Tomography for Suspected Coronary Artery Disease. Alert Report No 2011-03. Stockholm. The Swedish Council on Health Technology Assessment (SBU). April. 2011. Wrong outcomes.
36 Computed Tomography Radiation Safety Issues in Ontario. Toronto, ON Canada. Healthcare Human Factors Group, Centre for Global eHealth Innovation. University Health Network. June. 2006. Wrong outcomes.
37 Conti A, Luzzi M, Nanna C, et al. Effectiveness of nuclear scan strategy in low-risk chest pain patients: novel insights from the real world. Nucl Med Commun. Dec. 2011;32(12):1223-30. Wrong outcomes. [pmid: 22167851].
38 Cury RC, Budoff M, Taylor AJ. Coronary CT angiography versus standard of care for assessment of chest pain in the emergency department. J Cardiovasc Comput Tomogr. Mar-Apr. 2013;7(2):79-82. Systematic review or meta-analysis, using original studies instead. [pmid: 23538167].
39 D'Andrea A, Severino S, Caso P, et al. Prognostic value of supine bicycle exercise stress echocardiography in patients with known or suspected coronary artery disease. Eur J Echocardiogr. Aug. 2005;6(4):271-9. Wrong population. [pmid: 15992710].
40 Danias PG, Roussakis A, Ioannidis JP. Diagnostic performance of coronary magnetic resonance angiography as compared against conventional X-ray angiography: a meta-analysis. J Am Coll Cardiol. Nov. 2. 2004;44(9):1867-76. Wrong population. [pmid: 15519021].
41 Daniele S, Nappi C, Acampa W, et al. Incremental prognostic value of coronary flow reserve assessed with single-photon emission computed tomography. J Nucl Cardiol. Aug. 2011;18(4):612-9. Wrong intervention. [pmid: 21626091].
42 D'Ascenzo F, Cerrato E, Biondi-Zoccai G, et al. Coronary computed tomographic angiography for detection of coronary artery disease in patients presenting to the emergency department with chest pain: a meta-analysis of randomized clinical trials. Eur Heart J Cardiovasc Imaging. Aug. 2013;14(8):782-9. Systematic review or meta-analysis, using original studies instead. [pmid: 23221314].
43 de Albuquerque Fonseca L, Picano E. Comparison of dipyridamole and exercise stress echocardiography for detection of coronary artery disease (a meta-analysis). Am J Cardiol. May. 15. 2001;87(10):1193-6. A4. Wrong population. [pmid: 11356397].
44 De Lorenzo A, Hachamovitch R, Kang X, et al. Prognostic value of myocardial perfusion SPECT versus exercise electrocardiography in patients with ST-segment depression on resting electrocardiography. J Nucl Cardiol. Nov-Dec. 2005;12(6):655-61. Wrong population. [pmid: 16344227].
45 Dedic A, Rossi A, Ten Kate GJ, et al. First-line evaluation of coronary artery disease with coronary calcium scanning or exercise electrocardiography. Int J Cardiol. Feb. 20. 2013;163(2):190-5. Wrong outcomes, do not report test positive and test negative. [pmid: 21689855].
46 Dedic A, Ten Kate GJ, Neefjes LA, et al. Coronary CT angiography outperforms calcium imaging in the triage of acute coronary syndrome. Int J Cardiol. Aug. 20. 2013;167(4):1597-602. Wrong outcomes. [pmid: 22572630].
47 Dendukuri N, Chiu K, Brophy JM. Validity of electron beam computed tomography for coronary artery disease: asystematic review and meta-analysis. BMC Med. 2007;5:35. Wrong population. [pmid: 18036252].
48 Detrano R, Hsiai T, Wang S, et al. Prognostic value of coronary calcification and angiographic stenoses in patients undergoing coronary angiography. J Am Coll Cardiol. Feb. 1996;27(2):285-90. Wrong population. [pmid: 8557895].
49 Detrano R, Gianrossi R, Froelicher V. The diagnostic accuracy of the exercise electrocardiogram: a meta-analysis of 22 years of research. Prog Cardiovasc Dis. Nov-Dec. 1989;32(3):173-206. Wrong intervention. [pmid: 2530605].
50 Detrano R, Gianrossi R, Mulvihill D, et al. Exercise-induced ST segment depression in the diagnosis of multivessel coronary disease: a meta analysis. J Am Coll Cardiol. Nov. 15. 1989;14(6):1501-8. Wrong intervention. [pmid: 2809010].
51 Di Tanna GL, Berti E, Stivanello E, et al. Informative value of clinical research on multislice computed tomography in the diagnosis of coronary artery disease: A systematic review. Int J Cardiol. Nov. 28. 2008;130(3):386-404. Wrong population. [pmid: 18760849].
52 Dorbala S, Di Carli MF, Beanlands RS, et al. Prognostic value of stress myocardial perfusion positron emission tomography: results from a multicenter observational registry. J Am Coll Cardiol. Jan. 15. 2013;61(2):176-84. Wrong population. [pmid: 23219297].
53 Dorbala S, Hachamovitch R, Curillova Z, et al. Incremental prognostic value of gated Rb-82 positron emission tomography myocardial perfusion imaging over clinical variables and rest LVEF. JACC Cardiovasc Imaging. Jul. 2009;2(7):846-54. Wrong population. [pmid: 19608135].
54 El Aidi H, Adams A, Moons KG, et al. Cardiac magnetic resonance imaging findings and the risk of cardiovascular events in patients with recent myocardial infarction or suspected or known coronary artery disease: a systematic review of prognostic studies. J Am Coll Cardiol. Mar. 25. 2014;63(11):1031-45. Wrong population, wrong outcomes. [pmid: 24486280].
55 Elhendy A, Chandrasekaran K, Gersh BJ, et al. Functional and prognostic significance of exercise-induced ventricular arrhythmias in patients with suspected coronary artery disease. Am J Cardiol. Jul. 15. 2002;90(2):95-100. Wrong outcomes. [pmid: 12106835].
56 Elhendy A, Mahoney DW, McCully RB, et al. Use of a scoring model combining clinical, exercise test, and echocardiographic data to predict mortality in patients with known or suspected coronary artery disease. Am J Cardiol. May. 15. 2004;93(10):1223-8. Wrong outcomes. [pmid: 15135693].
57 Ellestad MH, Wan MK. Predictive implications of stress testing. Follow-up of 2700 subjects after maximum treadmill stress testing. Circulation. Feb. 1975;51(2):363-9. Wrong population. [pmid: 1112017].
58 Ely S, Chandra A, Mani G, et al. Utility of observation units for young emergency department chest pain patients. J Emerg Med. Feb. 2013;44(2):306-12. Wrong intervention. [pmid: 22975283].
59 Farhad H, Dunet V, Bachelard K, et al. Added prognostic value of myocardial blood flow quantitation in rubidium-82 positron emission tomography imaging. Eur Heart J Cardiovasc Imaging. Dec. 2013;14(12):1203-10. Wrong population. [pmid: 23660750].
60 Fennich N, Ellouali F, Abdelali S, et al. Stress echocardiography: safety and tolerability. Cardiovasc Ultrasound. 2013;11:30. Wrong population. [pmid: 23961806].
61 Feola M, Biggi A, Vado A, et al. The usefulness of adenosine 99mTc tetrofosmin SPECT for the diagnosis of left anterior descending coronary artery disease in patients with chest pain and left bundle branch block. Nucl Med Commun. Mar. 2004;25(3):265-9. Wrong intervention. [pmid: 15094445].
62 Ferencik M, Schlett CL, Bamberg F, et al. Comparison of traditional cardiovascular risk models and coronary atherosclerotic plaque as detected by computed tomography for prediction of acute coronary syndrome in patients with acute chest pain. Acad Emerg Med. Aug. 2012;19(8):934-42. Wrong outcomes. [pmid: 22849339].
63 Fesmire FM, Hughes AD, Stout PK, et al. Selective dual nuclear scanning in low-risk patients with chest pain to reliably identify and exclude acute coronary syndromes. Ann Emerg Med. Sep. 2001;38(3):207-15. Wrong population. [pmid: 11524638].
64 Fleischmann KE, Hunink MG, Kuntz, et al. Exercise echocardiography or exercise SPECT imaging? A meta-analysis of diagnostic test performance. JAMA. Sep. 9. 1998;280(10):913-20. Wrong population. [pmid: 9739977].
65 Freed BH, Narang A, Bhave NM, et al. Prognostic value of normal regadenoson stress perfusion cardiovascular magnetic resonance. J Cardiovasc Magn Reson. 2013;15:108. Wrong population. [pmid: 24359617].
66 From AM, Kane G, Bruce C, et al. Characteristics and outcomes of patients with abnormal stress echocardiograms and angiographically mild coronary artery disease (<50% stenoses) or normal coronary arteries. Gaemperli O, Husmann L, Schepis T, et al. Coronary CT angiography and myocardial perfusion imaging to detect flow-limiting stenoses: a potential gatekeeper for coronary revascularization?. Eur Heart J. Dec. 2009;30(23):2921-9. Wrong population. [pmid: 19684023].
67 Foy A, Rier J, Kozak M. High numbers of false-positive stress tests are the result of inappropriate testing. Am J of Med Qual. 2014;29(2):153-159. Wrong population, wrong outcome. [pmid: 23847082].
68 Fujita T, Ajisaka R, Matsumoto R, et al. Isoproterenol infusion stress two-dimensional echocardiography in diagnosis of coronary artery disease in elderly patients. Comparison with the other stress testing methods. Jpn Heart J. May. 1986;27(3):287-97. Wrong intervention. [pmid: 3761564].
69 Gaibazzi N, Reverberi C, Lorenzoni V, et al. Prognostic value of high-dose dipyridamole stress myocardial contrast perfusion echocardiography. [Erratum appears in Circulation. 2014 Apr 1;129(13):e429]. Circulation. Sep. 4. 2012;126(10):1217-24. Wrong intervention, wrong comparison. [pmid: 22872314].
70 Gallagher MJ, Ross MA, Raff GL, et al. The diagnostic accuracy of 64-slice computed tomography coronary angiography compared with stress nuclear imaging in emergency department low-risk chest pain patients. Ann Emerg Med. Feb. 2007;49(2):125-36. Wrong outcomes. [pmid: 16978738].
71 Galper BZ, Moran A, Coxson PG, et al. Using stress testing to guide primary prevention of coronary heart disease among intermediate-risk patients: a cost-effectiveness analysis. Circulation. Jan. 17. 2012;125(2):260-70. Wrong outcomes. [pmid: 22144567].
72 Garber AM, Solomon NA. Cost-effectiveness of alternative test strategies for the diagnosis of coronary artery disease. Ann Intern Med. May. 4. 1999;130(9):719-28. Wrong population, systematic review or meta-analysis, original data used instead. [pmid: 10357690].
73 Gargiulo P, Petretta M, Bruzzese D, et al. Myocardial perfusion scintigraphy and echocardiography for detecting coronary artery disease in hypertensive patients: a meta-analysis. Eur J Nucl Med Mol Imaging. Nov. 2011;38(11):2040-9. Wrong population. [pmid: 21814850].
74 Gargiulo P, Dellegrottaglie S, Bruzzese D, et al. The prognostic value of normal stress cardiac magnetic resonance in patients with known or suspected coronary artery disease: a meta-analysis. Circ Cardiovasc Imaging. Jul. 2013;6(4):574-82. Wrong population. [pmid: 23771988].
75 Gaudio C, Pelliccia F, Evangelista A, et al. 320-row computed tomography coronary angiography vs. conventional coronary angiography in patients with suspected coronary artery disease: a systematic review and meta-analysis. Int J Cardiol. Sep. 30. 2013;168(2):1562-4. Wrong outcomes. [pmid: 23347611].
76 Gebker R, Jahnke C, Manka R, et al. The role of dobutamine stress cardiovascular magnetic resonance in the clinical management of patients with suspected and known coronary artery disease. J Cardiovasc Magn Reson. 2011;13:46. Wrong population. [pmid: 21910881].
77 Ghadri JR, Fiechter M, Fuchs TA, et al. Registry for the Evaluation of the PROgnostic value of a novel integrated imaging approach combining Single Photon Emission Computed Tomography with coronary calcification imaging (REPROSPECT. Eur Heart J Cardiovasc Imaging). Apr. 2013;14(4):374-80. Wrong population. [pmid: 23111694].
78 Gimelli A, Rossi G, Landi P, et al. Stress/Rest Myocardial Perfusion Abnormalities by Gated SPECT: Still the Best Predictor of Cardiac Events in Stable Ischemic Heart Disease. J Nucl Med. Apr. 2009;50(4):546-53. Wrong population. [pmid: 19289433].
79 Glover DR, Robinson CS, Murray RG. Diagnostic exercise testing in 104 patients over 65 years of age. Eur Heart J. Nov. Suppl E. 1984;5:59-61. Wrong population. [pmid: 6526041].
80 Gopal A, Nasir K, Ahmadi N, et al. Cardiac computed tomographic angiography in an outpatient setting: an analysis of clinical outcomes over a 40-month period. J Cardiovasc Comput Tomogr. Mar-Apr. 2009;3(2):90-5. Wrong population. [pmid: 19269915].
81 Gorenoi V, Schonermark MP, Hagen A. CT coronary angiography vs invasive coronary angiography in CHD. GMS Health Technology Assessment. Hannover, Germany. 2012;8(Doc02). Wrong outcomes. [pmid: 22536300].
82 Grunig E, Mereles D, Benz A, et al. Contribution of stress echocardiography to clinical decision making in unselected ambulatory patients with known or suspected coronary artery disease. Int J Cardiol. Aug. 2002;84(2-3):179-85. Wrong population. [pmid: 12127370].
83 Habib PJ, Green J, Butterfield RC, et al. Association of cardiac events with coronary artery disease detected by 64-slice or greater coronary CT angiography: a systematic review and meta-analysis. Int J Cardiol. Oct. 30. 2013;169(2):112-20. Wrong population. [pmid: 24090745].
84 Hachamovitch R, Johnson JR, Hlatky MA, et al. The study of myocardial perfusion and coronary anatomy imaging roles in CAD (SPARC): design, rationale, and baseline patient characteristics of a prospective, multicenter observational registry comparing PET, SPECT, and CTA for resource utilization and clinical outcomes. J Nucl Cardiol. Nov-Dec. 2009;16(6):935-48. Not a study, a study protocol. [pmid: 19760338].
85 Hacioglu Y, Gupta M, Budoff MJ. Noninvasive anatomical coronary artery imaging versus myocardial perfusion imaging: which confers superior diagnostic and prognostic information?. J Comput Assist Tomogr. Sep-Oct. 2010;34(5):637-44. Wrong population. [pmid: 20861763].
86 Hadamitzky M, Distler R, Meyer T, et al. Prognostic value of coronary computed tomographic angiography in comparison with calcium scoring and clinical risk scores. Circ Cardiovasc Imaging. Jan. 2011;4(1):16-23. Wrong population, wrong comparison. [pmid: 20884832].
87 Halpern EJ, Deutsch JP, Hannaway MM, et al. Cardiac risk factors and risk scores vs cardiac computed tomography angiography: a prospective cohort study for triage of ED patients with acute chest pain. Am J Emerg Med. Oct. 2013;31(10):1479-85. Wrong intervention. [pmid: 24035047].
88 Hamdan A, Asbach P, Wellnhofer E, et al. A prospective study for comparison of MR and CT imaging for detection of coronary artery stenosis. JACC Cardiovasc Imaging. Jan. 2011;4(1):50-61. Wrong population. [pmid: 21232704].
89 Hamon M, Biondi-Zoccai GG, Malagutti P, et al. Diagnostic performance of multislice spiral computed tomography of coronary arteries as compared with conventional invasive coronary angiography: a meta-analysis. J Am Coll Cardiol. Nov. 7. 2006;48(9):1896-910. Wrong population. [pmid: 17084268].
90 Hamon M, Fau G, Née G, et al. Meta-analysis of the diagnostic performance of stress perfusion cardiovascular magnetic resonance for detection of coronary artery disease. J Cardiovasc Magn Reson. 2010;12(1):29. Wrong population. [pmid: 20482819].
91 Han PP, Tian YQ, Fang W, et al. Impact of myocardial perfusion imaging on in-hospital coronary angiography and revascularization of patients with suspected coronary artery disease. Chin Med J. Jun. 2011;124(11):1603-9. Wrong outcomes. [pmid: 21740763].
92 Haramati LB, Levsky JM, Jain VR, et al. CT angiography for evaluation of coronary artery disease in inner-city outpatients: an initial prospective comparison with stress myocardial perfusion imaging. Int J Cardiovasc Imaging. Mar. 2009;25(3):303-13. Wrong population. [pmid: 18979224].
93 Hartlage G, Janik M, Anadiotis A, et al. Prognostic value of adenosine stress cardiovascular magnetic resonance and dobutamine stress echocardiography in patients with low-risk chest pain. Int J Cardiovasc Imaging. Apr. 2012;28(4):803-12. Wrong intervention. [pmid: 21562726].
94 Heitner JF, Klem I, Rasheed D, et al. Stress cardiac MR imaging compared with stress echocardiography in the early evaluation of patients who present to the emergency department with intermediate-risk chest pain. Radiology. Apr. 2014;271(1):56-64. Wrong intervention. [pmid: 24475814].
95 Hennessy TG, Codd MB, Kane G, et al. Safety of dobutamine stress echocardiography in 474 consecutive studies. Coron Artery Dis. Mar-Apr. 1997;8(3-4):175-8. Wrong population. [pmid: 9237028].
96 Herzog BA, Husmann L, Valenta I, et al. Long-term prognostic value of 13N-ammonia myocardial perfusion positron emission tomography added value of coronary flow reserve. J Am Coll Cardiol. Jul. 7. 2009;54(2):150-6. Wrong population. [pmid: 19573732].
97 Ho FM, Huang PJ, Liau CS, et al. Dobutamine stress echocardiography compared with dipyridamole thallium-201 single-photon emission computed tomography in detecting coronary artery disease. Eur Heart J. Apr. 1995;16(4):570-5. Wrong population. [pmid: 7671905].
98 Hoque A, Maaieh M, Longaker RA, et al. Exercise echocardiography and thallium-201 single-photon emission computed tomography stress test for 5- and 10-year prognosis of mortality and specific cardiac events. J Am Soc Echocardiogr. Nov. 2002;15(11):1326-34. Wrong population. [pmid: 12415225].
99 Hou ZH, Lu B, Gao Y, et al. Prognostic value of coronary CT angiography and calcium score for major adverse cardiac events in outpatients. JACC Cardiovasc Imaging. Oct. 2012;5(10):990-9. Wrong population. [pmid: 23058065].
100 Hulten E, Pickett C, Bittencourt MS, et al. Outcomes after coronary computed tomography angiography in the emergency department: a systematic review and meta-analysis of randomized, controlled trials. J Am Coll Cardiol. Feb. 26. 2013;61(8):880-92. Systematic review or meta-analysis, using original studies instead. [pmid: 23395069].
101 Hulten EA, Carbonaro S, Petrillo SP, et al. Prognostic value of cardiac computed tomography angiography: a systematic review and meta-analysis. J Am Coll Cardiol. Mar. 8. 2011;57(10):1237-47. Wrong intervention, systematic review or meta-analysis, original data used instead. [pmid: 21145688].
102 Hussain ST, Paul M, Plein S, et al. Design and rationale of the MR-INFORM study: stress perfusion cardiovascular magnetic resonance imaging to guide the management of patients with stable coronary artery disease. J Cardiovasc Magn Reson. 2012;14:65. Not a study, a study protocol. [pmid: 22992411].
103 Imran MB, Khan MA, Aslam MN, et al. Diagnosis of coronary artery disease by stress echocardiography and perfusion scintigraphy. J Coll Physicians Surg Pak. Aug. 2003;13(8):465-70. Wrong population. [pmid: 12921688].
104 Innocenti F, Agresti C, Baroncini C, et al. Prognostic value of dobutamine stress echocardiography in diabetic patients. Int J Cardiovasc Imaging. Jun. 2010;26(5):499-507. Wrong population. [pmid: 20155443].
105 Innocenti F, Totti A, Baroncini C, et al. Prognostic value of dobutamine stress echocardiography in octogenarians. Int J Cardiovasc Imaging. Jan. 2011;27(1):65-74. Wrong population. [pmid: 20589431].
106 Iskandar A, Limone B, Parker MW, et al. Gender differences in the diagnostic accuracy of SPECT myocardial perfusion imaging: a bivariate meta-analysis. J Nucl Cardiol. Feb. 2013;20(1):53-63. Wrong population. [pmid: 23149886].
107 Iskandrian AS, Johnson J, Le TT, et al. Comparison of the treadmill exercise score and single-photon emission computed tomographic thallium imaging in risk assessment. J Nucl Cardiol. Mar-Apr. 1994;1(2 Pt 1):144-9. Wrong population. [pmid: 9420681].
108 Iwata K, Ogasawara K. Comparison of the cost-effectiveness of stress myocardial perfusion MRI and SPECT in patients with suspected coronary artery disease. Radiol Phys Technol. Jan. 2013;6(1):28-34. Wrong intervention. [pmid: 22806543].
109 Iwata K, Nakagawa S, Ogasawara K. The prognostic value of normal stress cardiovascular magnetic resonance imaging. J Comput Assist Tomogr. Jan-Feb. 2014;38(1):36-43. Wrong population. [pmid: 24424555].
110 Jahnke C, Nagel E, Gebker R, et al. Prognostic value of cardiac magnetic resonance stress tests: adenosine stress perfusion and dobutamine stress wall motion imaging. Circulation. Apr. 3. 2007;115(13):1769-76. Wrong population. [pmid: 17353441].
111 Janne d'Othee B, Siebert U, Cury R, et al. A systematic review on diagnostic accuracy of CT-based detection of significant coronary artery disease. Eur J Radiol. Mar. 2008;65(3):449-61. Wrong population. [pmid: 17590554].
112 Jeetley P, Burden L, Senior R. Stress echocardiography is superior to exercise ECG in the risk stratification of patients presenting with acute chest pain with negative Troponin. Eur J Echocardiogr. Mar. 2006;7(2):155-64. Wrong population. [pmid: 15967730].
113 Jeetley P, Burden L, Stoykova B, et al. Clinical and economic impact of stress echocardiography compared with exercise electrocardiography in patients with suspected acute coronary syndrome but negative troponin: a prospective randomized controlled study. Eur Heart J. Jan. 2007;28(2):204-11. Wrong population. [pmid: 17227784].
114 Jogiya R, Morton G, De Silva K, et al. Ischemic burden by 3-dimensional myocardial perfusion cardiovascular magnetic resonance: comparison with myocardial perfusion scintigraphy. Circ Cardiovasc Imaging. Jul. 2014;7(4):647-54. Wrong population. [pmid: 24867884].
115 Jones RL, Thomas DM, Barnwell ML, et al. Safe and rapid disposition of low-to-intermediate risk patients presenting to the emergency department with chest pain: a 1-year high-volume single-center experience. J Cardiovasc Comput Tomogr. Sep-Oct. 2014;8(5):375-83. Poor quality observational study, enough RCTs already included. [pmid: 25301043].
116 Kabasakal L, Collier BD, Shaker R, et al. Enterogastric bile reflux during technetium-99m-sestamibi cardiac imaging. J Nucl Med. Aug. 1996;37(8):1285-8. Wrong population. [pmid: 8708757].
117 Kapetanopoulos A, Heller GV, Selker HP, et al. Acute resting myocardial perfusion imaging in patients with diabetes mellitus: results from the Emergency Room Assessment of Sestamibi for Evaluation of Chest Pain (ERASE Chest Pain) trial. J Nucl Cardiol. 2004;11(5):570-577. Wrong intervention (no definition of usual care provided). [pmid: 15472642].
118 Kaul S, Senior R, Firschke C, et al. Incremental value of cardiac imaging in patients presenting to the emergency department with chest pain and without ST-segment elevation: a multicenter study. Am Heart J. Jul. 2004;148(1):129-36. Wrong population. [pmid: 15215802].
119 Kay J, Dorbala S, Goyal A, et al. Influence of sex on risk stratification with stress myocardial perfusion Rb-82 positron emission tomography: Results from the PET (Positron Emission Tomography) Prognosis Multicenter Registry. J Am Coll Cardiol. Nov. 12. 2013;62(20):1866-76. Wrong population. [pmid: 23850903].
120 Kelle S, Chiribiri A, Vierecke J, et al. Long-term prognostic value of dobutamine stress CMR. JACC Cardiovasc Imaging. Feb. 2011;4(2):161-72. Wrong population. [pmid: 21329901].
121 Kelle S, Egnell C, Vierecke J, et al. Prognostic value of negative dobutamine-stress cardiac magnetic resonance imaging. Med Sci Monit. Oct. 2009;15(10):MT131-6. Wrong population. [pmid: 19789518].
122 Khan R, Rawal S, Eisenberg MJ. Transitioning from 16-slice to 64-slice multidetector computed tomography for the assessment of coronary artery disease: are we really making progress?. Can J Cardiol. Sep. 2009;25(9):533-42. Wrong outcomes. [pmid: 19746244].
123 Kim C, Kwok YS, Heagerty P, et al. Pharmacologic stress testing for coronary disease diagnosis: A meta-analysis. Am Heart J. Dec. 2001;142(6):934-44. Wrong population. [pmid: 11717594].
124 Klem I, Shah DJ, White RD, et al. Prognostic value of routine cardiac magnetic resonance assessment of left ventricular ejection fraction and myocardial damage: an international, multicenter study. Circ Cardiovasc Imaging. Nov. 2011;4(6):610-9. Wrong population. [pmid: 21911738].
125 Korosoglou G, Elhmidi Y, Steen H, et al. Prognostic value of high-dose dobutamine stress magnetic resonance imaging in 1,493 consecutive patients: assessment of myocardial wall motion and perfusion. J Am Coll Cardiol. Oct. 5. 2010;56(15):1225-34. Wrong population. [pmid: 20883929].
126 Korosoglou G, Gitsioudis G, Voss A, et al. Strain-encoded cardiac magnetic resonance during high-dose dobutamine stress testing for the estimation of cardiac outcomes: comparison to clinical parameters and conventional wall motion readings. J Am Coll Cardiol. Sep. 6. 2011;58(11):1140-9. Wrong population. [pmid: 21884952].
127 Krivokapich J, Child JS, Walter DO, et al. Prognostic value of dobutamine stress echocardiography in predicting cardiac events in patients with known or suspected coronary artery disease. J Am Coll Cardiol. Mar. 1999;33(3):708-16. Wrong population. [pmid: 10080472].
128 Kronander H, Hammar N, Fischer-Colbrie W, et al. Analysis of ST/HR hysteresis improves long-term prognostic value of exercise ECG test. Int J Cardiol. Apr. 1. 2011;148(1):64-9. Wrong population. [pmid: 19903576].
129 Kwok Y, Kim C, Grady D, et al. Meta-analysis of exercise testing to detect coronary artery disease in women. Am J Cardiol. Mar. 1. 1999;83(5):660-6. Wrong population. [pmid: 10080415].
130 Kwon SW, Kim YJ, Shim J, et al. Coronary artery calcium scoring does not add prognostic value to standard 64-section CT angiography protocol in low-risk patients suspected of having coronary artery disease. Radiology. Apr. 2011;259(1):92-9. Wrong intervention. [pmid: 21324842].
131 Lacalzada J, de la Rosa A, Jimenez JJ, et al. Prognostic value of echocardiographic-derived calcium index in coronary artery disease diagnosed by 64-multidetector computed tomography. Echocardiography. Oct. 2012;29(9):1120-7. Wrong population, wrong comparison. [pmid: 22672409].
132 Lai S, Kaykha A, Yamazaki T, et al. Treadmill scores in elderly men. J Am Coll Cardiol. Feb. 18. 2004;43(4):606-15. Wrong population, wrong outcomes. [pmid: 14975471].
133 Lee DS, Jang MJ, Cheon GJ, et al. Comparison of the cost-effectiveness of stress myocardial SPECT and stress echocardiography in suspected coronary artery disease considering the prognostic value of false-negative results. J Nucl Cardiol. Sep-Oct. 2002;9(5):515-22. Wrong population, wrong outcomes. [pmid: 12360132].
134 Lerakis S, McLean DS, Anadiotis AV, et al. Prognostic value of adenosine stress cardiovascular magnetic resonance in patients with low-risk chest pain. J Cardiovasc Magn Reson. 2009;11:37. Wrong population. [pmid: 19772587].
135 Li S, Ni Q, Wu H, et al. Diagnostic accuracy of 320-slice computed tomography angiography for detection of coronary artery stenosis: meta-analysis. Int J Cardiol. Oct. 3. 2013;168(3):2699-705. Wrong outcomes. [pmid: 23566493].
136 Linde JJ, Kofoed KF, Sorgaard M, et al. Cardiac computed tomography guided treatment strategy in patients with recent acute-onset chest pain: results from the randomised, controlled trial: CArdiac cT in the treatment of acute CHest pain (CATCH). Int J Cardiol. 2013;168(6):5257-5262. Wrong intervention. [pmid: 23998546].
137 Lipinski MJ, McVey CM, Berger JS, et al. Prognostic value of stress cardiac magnetic resonance imaging in patients with known or suspected coronary artery disease: a systematic review and meta-analysis. J Am Coll Cardiol. Aug. 27. 2013;62(9):826-38. Wrong population. [pmid: 23727209].
138 MacIntyre WJ, Go RT, King JL, et al. Clinical outcome of cardiac patients with negative thallium-201 SPECT and positive rubidium-82 PET myocardial perfusion imaging. J Nucl Med. Mar. 1993;34(3):400-4. Wrong population. [pmid: 8441029].
139 Madsen JK, Hommel E, Hansen JF. Prognostic value of an electrocardiogram at rest and exercise test in patients admitted with suspected acute myocardial infarction, in whom the diagnosis is not confirmed. Eur Heart J. Jul. 1987;8(7):717-24. Wrong population. [pmid: 3653123].
140 Madsen T, Mallin M, Bledsoe J, et al. Utility of the emergency department observation unit in ensuring stress testing in low-risk chest pain patients. Crit Pathw Cardiol. Sep. 2009;8(3):122-4. Wrong comparison: technical or feasibility studies. [pmid: 19726932].
141 Maffei E, Seitun S, Palumbo A, et al. Prognostic value of Morise clinical score, calcium score and computed tomography coronary angiography in patients with suspected or known coronary artery disease. Radiol Med (Torino). Dec. 2011;116(8):1188-202. Wrong population. [pmid: 21892713].
142 Magnetic Resonance Imaging Environment Safety in Ontario. Toronto, ON Canada. Healthcare Human Factors Group. University Health Network. April. 2006. Wrong outcomes.
143 Mahenthiran J, Bangalore S, Yao SS, et al. Comparison of prognostic value of stress echocardiography versus stress electrocardiography in patients with suspected coronary artery disease. Am J Cardiol. Sep. 1. 2005;96(5):628-34. Wrong outcomes. [pmid: 16125483].
144 Manca C, Dei Cas L, Albertini D, et al. Different prognostic value of exercise electrocardiogram in men and women. Cardiology. 1978;63(5):312-9. Wrong population. [pmid: 679224].
145 Marie PY, Danchin N, Durand JF, et al. Long-term prediction of major ischemic events by exercise thallium-201 single-photon emission computed tomography. Incremental prognostic value compared with clinical, exercise testing, catheterization and radionuclide angiographic data. J Am Coll Cardiol. Oct. 1995;26(4):879-86. Wrong population. [pmid: 7560612].
146 Mark DB, Hlatky MA, Califf RM, et al. Painless exercise ST deviation on the treadmill: long-term prognosis. J Am Coll Cardiol. Oct. 1989;14(4):885-92. Wrong population. [pmid: 2794272].
147 Markiewicz W, Moscovitz M, Reisner S, et al. Diagnostic and prognostic value of oral dipyridamole test using echocardiography. Isr J Med Sci. Nov. 1990;26(11):601-5. Wrong population. [pmid: 2254074].
148 Marwick TH, Case C, Sawada S, et al. Prediction of outcomes in hypertensive patients with suspected coronary disease. Hypertension. Jun. 2002;39(6):1113-8. Wrong population. [pmid: 12052851].
149 Marwick TH, Case C, Sawada S, et al. Use of stress echocardiography to predict mortality in patients with diabetes and known or suspected coronary artery disease. Diabetes Care. Jun. 2002;25(6):1042-8. Wrong population. [pmid: 12032112].
150 Marwick TH, D'Hondt AM, Mairesse GH, et al. Comparative ability of dobutamine and exercise stress in inducing myocardial ischaemia in active patients. [Erratum appears in Br Heart J 1994 Dec;72(6):590]. Br Heart J. Jul. 1994;72(1):31-8. Wrong outcomes, wrong comparison. [pmid: 8068466].
151 Marwick TH, Mehta R, Arheart K, et al. Use of exercise echocardiography for prognostic evaluation of patients with known or suspected coronary artery disease. J Am Coll Cardiol. Jul. 1997;30(1):83-90. Wrong population. [pmid: 9207625].
152 Masini M, Picano E, Lattanzi F, et al. High dose dipyridamole-echocardiography test in women: correlation with exercise-electrocardiography test and coronary arteriography. J Am Coll Cardiol. Sep. 1988;12(3):682-5. Wrong outcomes. [pmid: 3403825].
153 Matchar DB, Mark DB, Patel MR, et al. Noninvasive Imaging for Coronary Artery Disease. Technology Assessment. (Prepared by the Duke Evidence-based Practice Center under Contract No. 290-02-0025). Rockville, MD. Agency for Healtcare Research and Quality. October. 2006. www.effectivehealthcare.ahrq.gov/reports/final.cfm. Wrong intervention, wrong outcomes.
154 Mattera JA, Arain SA, Sinusas AJ, et al. Exercise testing with myocardial perfusion imaging in patients with normal baseline electrocardiograms: cost savings with a stepwise diagnostic strategy. J Nucl Cardiol. Sep-Oct. 1998;5(5):498-506. Wrong outcomes. [pmid: 9796897].
155 Mazeika P, Nihoyannopoulos P, Joshi J, et al. Uses and limitations of high dose dipyridamole stress echocardiography for evaluation of coronary artery disease. Br Heart J. Feb. 1992;67(2):144-9. Wrong population. [pmid: 1540434].
156 Mazeika PK, Nadazdin A, Oakley CM. Dobutamine stress echocardiography for detection and assessment of coronary artery disease. J Am Coll Cardiol. May. 1992;19(6):1203-11. Wrong population. [pmid: 1564221].
157 Mazzotta G, Pace L, Bonow RO. Risk stratification of patients with coronary artery disease and left ventricular dysfunction by exercise radionuclide angiography and exercise electrocardiography. J Nucl Cardiol. Nov-Dec. 1994;1(6):529-36. Wrong population. [pmid: 9420747].
158 Medical Advisory Secretariat. 64-Slice computed tomographic angiography for the diagnosis of intermediate risk coronary artery disease: an evidence-based analysis. Ontario Health Technology Assessment Series. June. 2010;10(11):1-44. Available from: http://www.health.gov.on.ca/english/providers/program/mas/tech/reviews/pdf/cardiac_CT_20100528.pdf. Wrong outcomes.
159 Medical Advisory Secretariat. Magnetic resonance imaging (MRI) for the assessment of myocardial viability: an evidence-based analysis. Ontario Health Technology Assessment Series. July. 2010;10(15):1-45. Available from: http://www.health.gov.on.ca/english/providers/program/mas/tech/reviews/pdf/cardiac_viability_MRI_20100716.pdf. Wrong outcomes.
160 Menon M, Lesser JR, Hara H, et al. Multidetector CT coronary angiography for patient triage to invasive coronary angiography: Performance and cost in ambulatory patients with equivocal or suspected inaccurate noninvasive stress tests. Catheter Cardiovasc Interv. Mar. 1. 2009;73(4):497-502. Wrong population. [pmid: 19229981].
161 Merhige ME, Breen WJ, Shelton V, et al. Impact of myocardial perfusion imaging with PET and (82)Rb on downstream invasive procedure utilization, costs, and outcomes in coronary disease management. J Nucl Med. Jul. 2007;48(7):1069-76. Wrong population. [pmid: 17607038].
162 Metz LD, Beattie M, Hom R, et al. The prognostic value of normal exercise myocardial perfusion imaging and exercise echocardiography: a meta-analysis. J Am Coll Cardiol. Jan. 16. 2007;49(2):227-37. Systematic review or meta-analysis, using original studies instead. [pmid: 17222734].
163 Metz LD, Beattie M, Hom R, et al. The prognostic value of normal exercise myocardial perfusion imaging and exercise echocardiography: a meta-analysis. J Am Coll Cardiol. Jan. 16. 2007;49(2):227-37. Wrong intervention. [pmid: 17222734].
164 Meyer M, Nance JW Jr., Schoepf UJ, et al. Cost-effectiveness of substituting dual-energy CT for SPECT in the assessment of myocardial perfusion for the workup of coronary artery disease. Eur J Radiol. Dec. 2012;81(12):3719-25. Wrong population. [pmid: 21277132].
165 Miller CD, Case LD, Litle WC, et al. Stress CMR reduces revascularization, hospital readmission, and recurrent cardiac testing in intermediate-risk patients with acute chest pain. JACC Cardiovasc Imaging. Jul. 2013;6(7):785-94. Wrong intervention. [pmid: 23664718].
166 Miller CD, Hoekstra JW, Lefebvre C, et al. Provider-directed imaging stress testing reduces health care expenditures in lower-risk chest pain patients present to the emergency department. Circ Cardiovasc Imaging. Jan. 2012;5(1):111-18. Wrong intervention. [pmid: 22128195].
167 Miller CD, Hwang W, Case D, et al. Stress CMR imaging observation unit in the emergency department reduces 1-year medical care costs in patients with acute chest pain: a randomized study for comparison with inpatient care. JACC Cardiovasc Imaging. Aug. 2011;4(8):862-70. Wrong intervention. [pmid: 21835378].
168 Miller CD, Hwang W, Hoekstra JW, et al. Stress cardiac magnetic resonance imaging with observation unit care reduces cost for patients with emergent chest pain: a randomized trial. Ann Emerg Med. Sep. 2010;56(3):209-219. Wrong intervention. [pmid: 20554078].
169 Miranda CP, Lehmann KG, Froelicher VF. Correlation between resting ST segment depression, exercise testing, coronary angiography, and long-term prognosis. Am Heart J. Dec. 1991;122(6):1617-28. Wrong outcomes. [pmid: 1957757].
170 Mouden M, Timmer JR, Ottervanger JP, et al. Impact of a new ultrafast CZT SPECT camera for myocardial perfusion imaging: fewer equivocal results and lower radiation dose. Eur J Nucl Med Mol Imaging. Jun. 2012;39(6):1048-55. Wrong comparison: technical or feasibility studies. [pmid: 22426827].
171 Mouden M, Timmer JR, Reiffers S, et al. Coronary artery calcium scoring to exclude flow-limiting coronary artery disease in symptomatic stable patients at low or intermediate risk. Radiology. Oct. 2013;269(1):77-83. Wrong comparison: technical or feasibility studies. [pmid: 23788718].
172 Mowatt G, Cummins E, Waugh N, et al. Systematic review of the clinical effectiveness and cost-effectiveness of 64-slice or higher computed tomography angiography as an alternative to invasive coronary angiography in the investigation of coronary artery disease. United Kingdom. National Institute for Health Research; Health Technology Assessment. 2008;12(17). Wrong outcomes.
173 Mowatt G, Brazzelli M, Gemmell H, et al. Systematic review of the prognostic effectiveness of SPECT myocardial perfusion scintigraphy in patients with suspected or known coronary artery disease and following myocardial infarction. Nucl Med Commun. Mar. 2005;26(3):217-29. Wrong population. [pmid: 15722902].
174 Mowatt G, Vale L, Brazzelli M, et al. Systematic review of the effectiveness and cost-effectiveness, and economic evaluation, of myocardial perfusion scintigraphy for the diagnosis and management of angina and myocardial infarction. Health Technol Assess. Jul. 2004;8(30):iii-iv. 1. 207. Wrong population. [pmid: 15248938].
175 Multiple-detector computed tomography for the diagnosis of coronary artery disease. Brazilian Health Technology Assessment Bulletin. Brasilia. National Health Surveillance Agency (ANVISA). July. 2008;3(4). Available at: www.anvisa.gov.br. Wrong outcomes.
176 Multi-Slice Computed Tomography Coronary Angiography for Coronary Artery Disease: A Review of the Clinical Effectiveness and Guidelines. Ottawa, ON Canada. Canadian Agency for Drugs and Technologies in Health. Health Technology Inquiry Service. February. 2009. Wrong outcomes.
177 Murphy JC, Scott PJ, Shannon HJ, et al. ST elevation on the exercise ECG in patients presenting with chest pain and no prior history of myocardial infarction. Heart. Nov. 2009;95(21):1792-7. Wrong population, wrong outcomes. [pmid: 19570758].
178 Murthy VL, Naya M, Foster CR, et al. Improved cardiac risk assessment with noninvasive measures of coronary flow reserve. Circulation. Nov. 15. 2011;124(20):2215-24. Wrong population. [pmid: 22007073].
179 Muzzarelli S, Pfisterer ME, Muller-Brand J, et al. Gate-keeper to coronary angiography: comparison of exercise testing, myocardial perfusion SPECT and individually tailored approach for risk stratification. Int J Cardiovasc Imaging. Dec. 2010;26(8):871-9. Wrong population. [pmid: 20411429].
180 Nair CK, Aronow WS, Sketch MH, et al. Diagnostic and prognostic significance of exercise-induced premature ventricular complexes in men and women: a four year follow-up. J Am Coll Cardiol. May. 1983;1(5):1201-6. Wrong population. [pmid: 6601121].
181 Namdar M, Hany TF, Koepfli P, et al. Integrated PET/CT for the assessment of coronary artery disease: a feasibility study. J Nucl Med. Jun. 2005;46(6):930-5. Wrong population. [pmid: 15937302].
182 Nasir K, Shaw LJ, Liu ST, et al. Ethnic differences in the prognostic value of coronary artery calcification for all-cause mortality. J Am Coll Cardiol. Sep. 4. 2007;50(10):953-60. Wrong population. [pmid: 17765122].
183 Navare SM, Katten D, Johnson LL, et al. Risk stratification with electrocardiographic-gated dobutamine stress technetium-99m sestamibi single-photon emission tomographic imaging: value of heart rate response and assessment of left ventricular function. J Am Coll Cardiol. Feb. 21. 2006;47(4):781-8. Wrong population. [pmid: 16487845].
184 Nucifora G, Badano LP, Sarraf-Zadegan N, et al. Comparison of early dobutamine stress echocardiography and exercise electrocardiographic testing for management of patients presenting to the emergency department with chest pain. Am J Cardiol. 2007;100(7):1068-1073. Wrong population. [pmid: 17884363].
185 Olatidoye AG, Baltazar RF. Dipyridamole-thallium stress testing: a local community hospital experience. Md Med J. Jul. 1993;42(7):663-7. Wrong population. [pmid: 8412526].
186 Ollendorf DA, Colby JA, Cameron C, et al. Cardiac Nuclear Imaging. Olympia, WA. Washington State Health Care Authority; Health Technology Assessment Program. August. 2013. 2013. Wrong population, systematic review or meta-analysis, original data used instead.
187 Ollendorf DA, Gohler A, Pearson SD. Coronary Computed Tomographic Angiography for Detection of Coronary Artery Disease. Olympia, WA. Washington State Health Care Authority; Health Technology Assessment Program. October. 2008. Wrong population, systematic review or meta-analysis, original data used instead.
188 Ollendorf DA, Kuba M, Pearson SD. The diagnostic performance of multi-slice coronary computed tomographic angiography: a systematic review. J Gen Intern Med. Mar. 2011;26(3):307-16. Wrong population. [pmid: 21063800].
189 Olmos LI, Dakik H, Gordon R, et al. Long-term prognostic value of exercise echocardiography compared with exercise 201Tl, ECG, and clinical variables in patients evaluated for coronary artery disease. Circulation. Dec. 15. 1998;98(24):2679-86. Wrong population. [pmid: 9851953].
190 Parker MW, Iskandar A, Limone B, et al. Diagnostic accuracy of cardiac positron emission tomography versus single photon emission computed tomography for coronary artery disease: a bivariate meta-analysis. Circ Cardiovasc Imaging. Nov. 2012;5(6):700-7. Wrong population. [pmid: 23051888].
191 Peteiro J, Bouzas-Mosquera A, Broullon FJ, et al. Prognostic value of peak and post-exercise treadmill exercise echocardiography in patients with known or suspected coronary artery disease. Eur Heart J. Jan. 2010;31(2):187-95. Wrong population. [pmid: 19825812].
192 Picano E, Severi S, Michelassi C, et al. Prognostic importance of dipyridamole-echocardiography test in coronary artery disease. Circulation. Sep. 1989;80(3):450-7. Wrong population. [pmid: 2766502].
193 Picano E, Bedetti G, Varga A, et al. The comparable diagnostic accuracies of dobutamine-stress and dipyridamole-stress echocardiographies: a meta-analysis. Coron Artery Dis. Mar. 2000;11(2):151-9. Wrong population. [pmid: 10758817].
194 Pilz G, Jeske A, Klos M, et al. Prognostic value of normal adenosine-stress cardiac magnetic resonance imaging. Am J Cardiol. May. 15. 2008;101(10):1408-12. Wrong population. [pmid: 18471450].
195 Pontone G, Andreini D, Bartorelli AL, et al. A long-term prognostic value of CT angiography and exercise ECG in patients with suspected CAD. JACC Cardiovasc Imaging. Jun. 2013;6(6):641-50. Wrong outcomes. [pmid: 23764093].
196 Pontone G, Andreini D, Bartoreli AL, et al. Radiation dose and diagnostic accuracy of multidetector computed tomography for the detection of significant coronary artery stenoses: a meta-analysis. Int J Cardiol. Oct. 18. 2012;160(3):155-64. Wrong outcomes. [pmid: 21978473].
197 Powell ES, Patterson BW, Venkatesh AK, et al. Cost-effectiveness of a novel indication of computed tomography of the coronary arteries. Crit Pathw Cardiol. Mar. 2012;11(1):20-5. Wrong outcomes. [pmid: 22337217].
198 Prazeres CE, Cury RC, Carneiro AC. Coronary computed tomography angiography in the assessment of acute chest pain in the emergency room. Arq Bras Cardiol. Dec. 2013;101(6):562-9. Systematic review or meta-analysis, using original studies instead. [pmid: 24145392].
199 Rai M, Baker WL, Parker MW, et al. Meta-analysis of optimal risk stratification in patients >65 years of age. Am J Cardiol. Oct. 15. 2012;110(8):1092-9. Wrong population, systematic review or meta-analysis, original data used instead. [pmid: 22795509].
200 Ramakrishna G, Breen JF, Mulvagh SL, et al. Relationship between coronary artery calcification detected by electron-beam computed tomography and abnormal stress echocardiography: association and prognostic implications. J Am Coll Cardiol. Nov. 21. 2006;48(10):2125-31. Wrong population. [pmid: 17113002].
201 Ramakrishna G, Miller TD, Breen JF, et al. Relationship and prognostic value of coronary artery calcification by electron beam computed tomography to stress-induced ischemia by single photon emission computed tomography. Am Heart J. May. 2007;153(5):807-14. Wrong population. [pmid: 17452158].
202 Raman V, Mc Williams ET, Holmbert SR, et al. Economic analysis of the use of coronary calcium scoring as an alternative to stress ECG in the non-invasive diagnosis of coronary artery disease. Eur Radiol. Mar. 2012;22(3):579-87. Wrong population. [pmid: 21993982].
203 Russo V, Zavalloni A, Bacchi Reggiani ML, et al. Incremental prognostic value of coronary CT angiography in patients with suspected coronary artery disease. Circ Cardiovasc Imaging. Jul. 2010;3(4):351-9. Wrong population. [pmid: 20460497].
204 Ryan TJ, Weiner DA, McCabe CH, et al. Exercise testing in the Coronary Artery Surgery Study randomized population. Circulation. Dec. 1985;72(6 Pt 2):V31-8. Wrong population. [pmid: 3905057].
205 Sabarudin A, Sun Z, Ng KH. A systematic review of radiation dose associated with different generations of multidetector CT coronary angiography. J Med Imaging Radiat Oncol. Feb. 2012;56(1):5-17. Wrong population. [pmid: 22339741].
206 Sabarudin A, Sun Z, Ng KH. Coronary computed tomography angiography with prospective electrocardiography triggering: a systematic review of image quality and radiation dose. Singapore Med J. Jan. 2013;54(1):15-23. Wrong population. [pmid: 23338911].
207 Sanfilippo AJ, Abdollah H, Knott C, et al. Defining low risk for coronary heart disease among women with chest pain syndrome: a prospective evaluation. J Womens Health (Larchmt). Apr. 2005;14(3):240-7. Wrong outcomes. [pmid: 15857270].
208 Sawada SG, Ryan T, Conley MJ, et al. Prognostic value of a normal exercise echocardiogram. Am Heart J. Jul. 1990;120(1):49-55. Wrong population. [pmid: 2360517].
209 Sawada SG, Sayyed S, Raiesdana A, et al. Clinical assessment and rest and stress echocardiography for prediction of long-term prognosis in African Americans with known or suspected coronary artery disease. Echocardiography. May. 2009;26(5):558-66. Wrong population. [pmid: 19452609].
210 Schindler TH, Nitzsche EU, Schelbert HR, et al. Positron emission tomography-measured abnormal responses of myocardial blood flow to sympathetic stimulation are associated with the risk of developing cardiovascular events. J Am Coll Cardiol. May. 3. 2005;45(9):1505-12. Wrong population. [pmid: 15862426].
211 Schinkel AF, Elhendy A, Biagini E, et al. Prognostic stratification using dobutamine stress 99mTc-tetrofosmin myocardial perfusion SPECT in elderly patients unable to perform exercise testing. J Nucl Med. Jan. 2005;46(1):12-8. Wrong population. [pmid: 15632027].
212 Schinkel AF, Elhendy A, van Domburg RT, et al. Incremental value of exercise technetium-99m tetrofosmin myocardial perfusion single-photon emission computed tomography for the prediction of cardiac events. Am J Cardiol. Feb. 15. 2003;91(4):408-11. Wrong population. [pmid: 12586253].
213 Schinkel AF, Elhendy A, Van Domburg RT, et al. Long-term prognostic value of dobutamine stress 99mTc-sestamibi SPECT: single-center experience with 8-year follow-up. Radiology. Dec. 2002;225(3):701-6. Wrong population. [pmid: 12461248].
214 Schmermund A, Elsasser A, Behl M, et al. Comparison of prognostic usefulness (three years) of computed tomographic angiography versus 64-slice computed tomographic calcium scanner in subjects without significant coronary artery disease. Am J Cardiol. Dec. 1. 2010;106(11):1574-9. Wrong population. [pmid: 21094357].
215 Schuetz GM, Zacharopoulou NM, Schlattmann P, et al. Meta-analysis: noninvasive coronary angiography using computed tomography versus magnetic resonance imaging. Ann Intern Med. Feb. 2. 2010;152(3):167-77. Wrong population. [pmid: 20124233].
216 Schuijf JD, Bax JJ, Shaw LJ, et al. Meta-analysis of comparative diagnostic performance of magnetic resonance imaging and multislice computed tomography for noninvasive coronary angiography. Am Heart J. Feb. 2006;151(2):404-11. Wrong population. [pmid: 16442907].
217 SCOT-HEART investigators. CT coronary angiography in patients with suspected angina due to coronary heart disease (SCOT-HEART): an open-label, parallel-group, multicentre trial. Lancet. Jun. 13. 2015;385(9985):2283-91. Wrong population, wrong intervention. [pmid: 25788230].
218 Secci A, Wong N, Tang W, et al. Electron beam computed tomographic coronary calcium as a predictor of coronary events: comparison of two protocols. Circulation. Aug. 19. 1997;96(4):1122-9. Wrong population. [pmid: 9286939].
219 Sekhri N, Feder GS, Junghans C, et al. Incremental prognostic value of the exercise electrocardiogram in the initial assessment of patients with suspected angina: cohort study. BMJ. 2008;337:a2240. Wrong outcomes, do not report test positive and test negative. [pmid: 19008264].
220 Senior R, Soman P, Khattar RS, et al. Prognostic value of dobutamine stress echocardiography in patients undergoing diagnostic coronary arteriography. Am J Cardiol. Jun. 15. 1997;79(12):1610-4. Wrong population. [pmid: 9202350].
221 Shah R, Heydari B, Coelho-Filho O, et al. Stress cardiac magnetic resonance imaging provides effective cardiac risk reclassification in patients with known or suspected stable coronary artery disease. Circulation. Aug. 6. 2013;128(6):605-14. Wrong population. [pmid: 23804252].
222 Shareghi S, Ahmadi N, Young E, et al. Prognostic significance of zero coronary calcium scores on cardiac computed tomography. J Cardiovasc Comput Tomogr. Dec. 2007;1(3):155-9. Wrong population. [pmid: 19083900].
223 Sharples L, Hughes V, Crean A, et al. Cost-effectiveness of functional cardiac testing in the diagnosis and management of coronary artery disease: a randomised controlled trial. The CECaT trial. Health Technol Assess. Dec. 2007;11(49):iii-iv. ix. 115. Wrong population. [pmid: 18021576].
224 Shaw LJ, Berman DS, Hendel RC, et al. Prognosis by coronary computed tomographic angiography: matched comparison with myocardial perfusion single-photon emission computed tomography. J Cardiovasc Comput Tomogr. Mar-Apr. 2008;2(2):93-101. Wrong intervention. [pmid: 19083928].
225 Shaw LJ, Miller DD, Romeis JC, et al. Gender differences in the noninvasive evaluation and management of patients with suspected coronary artery disease. Ann Intern Med. Apr. 1. 1994;120(7):559-66. Wrong population. [pmid: 8116993].
226 Shaw LJ, Hendel R, Borges-Neto S, et al. Prognostic value of normal exercise and adenosine (99m)Tc-tetrofosmin SPECT imaging: results from the multicenter registry of 4,728 patients. [Erratum appears in J Nucl Med. 2003 Apr;44(4):648]. J Nucl Med. Feb. 2003;44(2):134-9. Wrong outcomes. [pmid: 12571200].
227 Shimoni S, Goland S, Livshitz S, et al. Accuracy and long-term prognostic value of pacing stress echocardiography compared with dipyridamole tl201 emission computed tomography in patients with a permanent pacemaker and known or suspected coronary artery disease. Cardiology. 2010;116(3):229-36. Wrong population. [pmid: 20693801].
228 Shoyeb A, Bokhari S, Sullivan J, et al. Value of definitive diagnostic testing in the evaluation of patients presenting to the emergency department with chest pain. Am J Cardiol. Jun. 15. 2003;91(12):1410-4. Wrong population. [pmid: 12804725].
229 Siebelink HM, Blanksma PK, Crijns HJ, et al. No difference in cardiac event-free survival between positron emission tomography-guided and single-photon emission computed tomography-guided patient management: a prospective, randomized comparison of patients with suspicion of jeopardized myocardium. J Am Coll Cardiol. Jan. 2001;37(1):81-8. Wrong intervention. [pmid: 11153777].
230 Slim J, Castillo-Rojas L, Hann M, et al. Computed tomography coronary angiography versus stress myocardial perfusion imaging for risk stratification in patients with high occupational risk. J Thorac Imaging. Jan. 2012;27(1):40-3. Wrong intervention. [pmid: 21263354].
231 Southard J, Baker L, Schaefer S. In search of the false-negative exercise treadmill testing evidence-based use of exercise echocardiography. Clin Cardiol. Jan. 2008;31(1):35-40. Wrong population. [pmid: 18203117].
232 Sozzi FB, Elhendy A, Roelandt JR, et al. Prognostic value of dobutamine stress echocardiography in patients with diabetes. Diabetes Care. Apr. 2003;26(4):1074-8. Wrong population. [pmid: 12663576].
233 Steel K, Broderick R, Gandla V, et al. Complementary prognostic values of stress myocardial perfusion and late gadolinium enhancement imaging by cardiac magnetic resonance in patients with known or suspected coronary artery disease. Circulation. Oct. 6. 2009;120(14):1390-400. Wrong population. [pmid: 19770399].
234 Stowers SA, Eisenstein EL, Th Wackers FJ, et al. An economic analysis of an aggressive diagnostic strategy with single photon emission computed tomography myocardial perfusion imaging and early exercise stress testing in emergency department patients who present with chest pain but nondiagnostic electrocardiograms: results from a randomized trial. Ann Emerg Med. 2000;35(1):17-25. Wrong population. [pmid: 10613936].
235 Sullivan AK, Holdright DR, Wright CA, et al. Chest pain in women: clinical, investigative, and prognostic features. BMJ. Apr. 2. 1994;308(6933):883-6. Wrong population. [pmid: 8173366].
236 Syed MA, Al-Malki Q, Kazmouz G, et al. Usefulness of exercise echocardiography in predicting cardiac events in an outpatient population. Am J Cardiol. Sep. 1. 1998;82(5):569-73. Wrong population. [pmid: 9732881].
237 Takakuwa KM, Keith SW, Estepa AT, et al. A meta-analysis of 64-section coronary CT angiography findings for predicting 30-day major adverse cardiac events in patients presenting with symptoms suggestive of acute coronary syndrome. Acad Radiol. Dec. 2011;18(12):1522-8. Wrong population. [pmid: 22055795].
238 Tardif JC, Dore A, Chan KL, et al. Economic impact of contrast stress echocardiography on the diagnosis and initial treatment of patients with suspected coronary artery disease. J Am Soc Echocardiogr. Nov. 2002;15(11):1335-45. Wrong population. [pmid: 12415226].
239 ten Kate GJ, Caliskan K, Dedic A, et al. Computed tomography coronary imaging as a gatekeeper for invasive coronary angiography in patients with newly diagnosed heart failure of unknown aetiology. Eur J Heart Fail. Sep. 2013;15(9):1028-34. Wrong population. [pmid: 23759285].
240 Thom H, West NE, Hughes V, et al. Cost-effectiveness of initial stress cardiovascular MR, stress SPECT or stress echocardiography as a gate-keeper test, compared with upfront invasive coronary angiography in the investigation and management of patients with stable chest pain: mid-term outcomes from the CECaT randomised controlled trial. BMJ Open. Feb. 7. 2014;4(2):e003419. Wrong population. [pmid: 24508847].
241 Udelson JE, Beshansky JR, Ballin DS, et al. Myocardial perfusion imaging for evaluation and triage of patients with suspected acute cardiac ischemia: a randomized controlled trial. JAMA. 2002;288(21):2693-2700. Wrong intevention (no definition of usual care provided). [pmid: 12460092].
242 Underwood SR, Godman B, Salyani S, et al. Economics of myocardial perfusion imaging in Europe--the EMPIRE Study. Eur Heart J. Jan. 1999;20(2):157-66. Wrong intervention, wrong comparison. [pmid: 10099913].
243 Valeti US, Miller TD, Hodge DO, et al. Exercise single-photon emission computed tomography provides effective risk stratification of elderly men and elderly women. Circulation. Apr. 12. 2005;111(14):1771-6. Wrong population. [pmid: 15809375].
244 Van Brabandt H, Camberlin C, Cleemput I. 64-Slice computed tomography imaging of coronary arteries in patients suspected for coronary artery disease; 82 C. Brussels. Belgian Health Care Knowledge Centre. 2008. Available at: http://www.kce.fgov.be. Wrong population, systematic review or meta-analysis, original data used instead.
245 Van Tosh A, Supino PG, Nichols KJ, et al. Prognosis of a normal positron emission tomography 82Rb myocardial perfusion imaging study in women with no history of coronary disease. Cardiology. 2010;117(4):301-6. Wrong population. [pmid: 21372570].
246 van Werkhoven JM, Schuijf JD, Gaemperli O, et al. Incremental prognostic value of multi-slice computed tomography coronary angiography over coronary artery calcium scoring in patients with suspected coronary artery disease. Eur Heart J. Nov. 2009;30(21):2622-9. Wrong population. [pmid: 19567382].
247 van Werkhoven JM, Schuijf JD, Gaemperli O, et al. Prognostic value of multislice computed tomography and gated single-photon emission computed tomography in patients with suspected coronary artery disease. J Am Coll Cardiol. Feb. 17. 2009;53(7):623-32. Wrong population. [pmid: 19215839].
248 Vanzetto G, Ormezzano O, Fagret D, et al. Long-term additive prognostic value of thallium-201 myocardial perfusion imaging over clinical and exercise stress test in low to intermediate risk patients : study in 1137 patients with 6-year follow-up. Circulation. Oct. 5. 1999;100(14):1521-7. Wrong population. [pmid: 10510055].
249 Walker S, Girardin F, McKenna C, et al. Cost-effectiveness of cardiovascular magnetic resonance in the diagnosis of coronary heart disease: an economic evaluation using data from the CE-MARC study. Heart. Jun. 2013;99(12):873-81. Wrong population. [pmid: 23591668].
250 Watanabe R, Lemos MM, Manfredi SR, et al. Impact of cardiovascular calcification in nondialyzed patients after 24 months of follow-up. Clin J Am Soc Nephrol. Feb. 2010;5(2):189-94. Wrong population. [pmid: 19965535].
251 Wennike N, Shah BN, Boger E, et al. Stress echocardiography in the district hospital setting: a cost-saving analysis. Eur J Echocardiogr. Jun. 2010;11(5):401-5. Wrong population. [pmid: 20067915].
252 Westwood M, Al M, Burgers L, et al. A systematic review and economic evaluation of new-generation computed tomography scanners for imaging in coronary artery disease and congenital heart disease: Somatom Definition Flash, Aquilion ONE, Brilliance iCT and Discovery CT750 HD. Southamptom, UK. National Institute for Health Research, Health Technology Assessment. March. 2013;17(9). Wrong outcomes.
253 Westwood M, Al M, Burgers L, et al. A systematic review and economic evaluation of new-generation computed tomography scanners for imaging in coronary artery disease and congenital heart disease: Somatom Definition Flash, Aquilion ONE, Brilliance iCT and Discovery CT750 HD. Health Technol Assess. 2013;17(9):1-243. Wrong population. [pmid: 23463937].
254 Williams BA, Dorn JM, LaMonte MJ, et al. Evaluating the prognostic value of positron-emission tomography myocardial perfusion imaging using automated software to calculate perfusion defect size. Clin Cardiol. Nov. 2012;35(11):E14-21. Wrong population. [pmid: 22961671].
255 Winchester DE, Jeffrey R, Schwarz J, et al. Comparing two strategies for emergency department chest pain patients: immediate computed tomography coronary angiography versus delayed outpatient treadmill testing. Crit Pathw Cardiol. Dec. 2013;12(4):197-200. Wrong intervention. [pmid: 24240549].
256 Winchester DE, Jois P, Kraft SM, et al. Immediate computed tomography coronary angiography versus delayed outpatient stress testing for detecting coronary artery disease in emergency department patients with chest pain. Int J Cardiovasc Imaging. Mar. 2012;28(3):667-74. Wrong intervention. [pmid: 21503704].
257 Wyns W, Musschaert-Beauthier E, van Domburg R, et al. Prognostic value of symptom limited exercise testing in men with a high prevalence of coronary artery disease. Eur Heart J. Nov. 1985;6(11):939-45. Wrong population. [pmid: 4076203].
258 Yamamoto H, Ohashi N, Ishibashi K, et al. Coronary calcium score as a predictor for coronary artery disease and cardiac events in Japanese high-risk patients. Circ J. 2011;75(10):2424-31. Wrong population. Wrong population. [pmid: 21778594].
259 Yoshinaga K, Chow BJ, Williams K, et al. What is the prognostic value of myocardial perfusion imaging using rubidium-82 positron emission tomography?. J Am Coll Cardiol. Sep. 5. 2006;48(5):1029-39. Wrong population. [pmid: 16949498].