# List of Included Studies

1 Buchsbaum M, Marshall E, Levine B, et al. Emergency department evaluation of chest pain using exercise stress echocardiography. Acad Emerg Med. Feb. 2001;8(2):196-9. [pmid: 11157301].
2 Chang SA, Choi SI, Choi EK, et al. Usefulness of 64-slice multidetector computed tomography as an initial diagnostic approach in patients with acute chest pain. Am Heart J. Aug. 2008;156(2):375-83. [pmid: 18657674].
3 Cheezum MK, Hulten EA, Taylor AJ, et al. Cardiac CT angiography compared with myocardial perfusion stress testing on downstream resource utilization. J Cardiovasc Comput Tomogr. Mar-Apr. 2011;5(2):101-9. [pmid: 21256102].
4 Cho I, Shim J, Chang HJ, et al. Prognostic value of multidetector coronary computed tomography angiography in relation to exercise electrocardiogram in patients with suspected coronary artery disease. J Am Coll Cardiol. Nov. 20. 2012;60(21):2205-15. [pmid: 23103039].
5 Colon PJ 3rd, Guarisco JS, Murgo J, et al. Utility of stress echocardiography in the triage of patients with atypical chest pain from the emergency department. Am J Cardiol. Nov. 15. 1998;82(10):1282-4. A10. [pmid: 9832109].
6 Dedic A, Genders TS, Ferket BS, et al. Stable angina pectoris: head-to-head comparison of prognostic value of cardiac CT and exercise testing. Radiology. Nov. 2011;261(2):428-36. [pmid: 21873254].
7 Dodi C, Cortigiani L, Masini M, et al. The incremental prognostic value of pharmacological stress echo over exercise electrocardiography in women with chest pain of unknown origin. Eur Heart J. Jan. 2001;22(2):145-52. [pmid: 11161916].
8 Douglas PS, Hoffmann U, Patel MR, et al. Outcomes of anatomical versus functional testing for coronary artery disease. New Engl J Med. 2015. Mar. 14. [pmid: 25773919].
9 Elhendy A, Shub C, McCully RB, et al. Exercise echocardiography for the prognostic stratification of patients with low pretest probability of coronary artery disease. Am J Med. Jul. 2001;111(1):18-23. [pmid: 11448656].
10 Ferrara N, Leosco D, Abete P, et al. Dipyridamole echocardiography as a useful and safe test in the assessment of coronary artery disease in the elderly. J Am Geriatr Soc. Oct. 1991;39(10):993-9. [pmid: 1918787].
11 Fine NM, Pellikka PA, Scott CG, et al. Characteristics and outcomes of patients who achieve high workload (>10 metabolic equivalents) during treadmill exercise echocardiography. Mayo Clin Proc. Dec. 2013;88(12):1408-19. [pmid: 24290114].
12 Gentile R, Vitarelli A, Schillaci O, et al. Diagnostic accuracy and prognostic implications of stress testing for coronary artery disease in the elderly. Ital Heart J. Jul. 2001;2(7):539-45. [pmid: 11501963].
13 Goldstein JA, Chinnaiyan KM, Abidov A, et al. The CT-STAT (Coronary Computed Tomographic Angiography for Systematic Triage of Acute Chest Pain Patients to Treatment) trial. J Am Coll Cardiol. Sep. 27. 2011;58(14):1414-22. [pmid: 21939822].
14 Goldstein JA, Gallagher MJ, O'Neill WW, et al. A randomized controlled trial of multi-slice coronary computed tomography for evaluation of acute chest pain. J Am Coll Cardiol. Feb. 27. 2007;49(8):863-71. [pmid: 17320744].
15 Gruettner J, Fink C, Walter T, et al. Coronary computed tomography and triple rule out CT in patients with acute chest pain and an intermediate cardiac risk profile. Part 1: impact on patient management. Eur J Radiol. Jan. 2013;82(1):100-5. [pmid: 22749769].
16 Hachamovitch R, Berman DS, Kiat H, et al. Exercise myocardial perfusion SPECT in patients without known coronary artery disease: incremental prognostic value and use in risk stratification. Circulation. Mar. 1. 1996;93(5):905-14. [pmid: 8598081].
17 Hachamovitch R, Nutter B, Hlatky MA, et al. Patient management after noninvasive cardiac imaging results from SPARC (Study of myocardial perfusion and coronary anatomy imaging roles in coronary artery disease). J Am Coll Cardiol. Jan. 31. 2012;59(5):462-74. [pmid: 22281249].
18 Hamilton-Craig C, Fifoot A, Hansen M, et al. Diagnostic performance and cost of CT angiography versus stress ECG--a randomized prospective study of suspected acute coronary syndrome chest pain in the emergency department (CT-COMPARE). Int J Cardiol. Dec. 20. 2014;177(3):867-73. [pmid: 25466568].
19 Henzler T, Gruettner J, Meyer M, et al. Coronary computed tomography and triple rule out CT in patients with acute chest pain and an intermediate cardiac risk for acute coronary syndrome: part 2: economic aspects. Eur J Radiol. Jan. 2013;82(1):106-11. [pmid: 22835878].
20 Heupler S, Mehta R, Lobo A, et al. Prognostic implications of exercise echocardiography in women with known or suspected coronary artery disease. J Am Coll Cardiol. Aug. 1997;30(2):414-20. [pmid: 9247513].
21 Hlatky MA, Shilane D, Hachamovitch R, et al. Economic outcomes in the Study of Myocardial Perfusion and Coronary Anatomy Imaging Roles in Coronary Artery Disease registry: the SPARC Study. J Am Coll Cardiol. Mar. 18. 2014;63(10):1002-8. [pmid: 24636556].
22 Hoffmann U, Truong QA, Schoenfeld DA, et al. Coronary CT angiography versus standard evaluation in acute chest pain. New Engl J Med. Jul. 26. 2012;367(4):299-308. [pmid: 22830462].
23 Innocenti F, Cerabona P, Donnini C, et al. Long-term prognostic value of stress echocardiography in patients presenting to the ED with spontaneous chest pain. Am J Emerg Med. Jul. 2014;32(7):731-6. [pmid: 24768667].
24 Innocenti F, Lazzeretti D, Conti A, et al. Stress echocardiography in the ED: diagnostic performance in high-risk subgroups. Am J Emerg Med. Sep. 2013;31(9):1309-14. [pmid: 23827088].
25 Kim YJ, Hur J, Lee HJ, et al. Meaning of zero coronary calcium score in symptomatic patients referred for coronary computed tomographic angiography. Eur Heart J Cardiovasc Imaging. Sep. 2012;13(9):776-85. [pmid: 22461571].
26 Krivokapich J, Child JS, Gerber RS, et al. Prognostic usefulness of positive or negative exercise stress echocardiography for predicting coronary events in ensuing twelve months. Am J Cardiol. Mar. 15. 1993;71(8):646-51. [pmid: 8447259].
27 Laudon DA, Behrenbeck TR, Wood CM, et al. Computed tomographic coronary artery calcium assessment for evaluating chest pain in the emergency department: long-term outcome of a prospective blind study. Mayo Clin Proc. Apr. 2010;85(4):314-22. [pmid: 20360291].
28 Levsky JM, Spevack DM, Travin MI, et al. Coronary computed tomography angiography versus radionuclide myocardial perfusion imaging in patients with chest pain admitted to telemetry: a randomized trial. Ann Intern Med. Aug. 163(3):174-83. [pmid: 26052677].
29 Litt HI, Gatsonis C, Snyder B, et al. CT angiography for safe discharge of patients with possible acute coronary syndromes. New Engl J Med. Apr. 12. 2012;366(15):1393-403. [pmid: 22449295].
30 Marwick TH, Shaw L, Case C, et al. Clinical and economic impact of exercise electrocardiography and exercise echocardiography in clinical practice. Eur Heart J. Jun. 2003;24(12):1153-63. [pmid: 12804930].
31 McKavanagh P, Lusk L, Ball PA, et al. A comparison of cardiac computerized tomography and exercise stress electrocardiogram test for the investigation of stable chest pain: the clinical results of the CAPP randomized prospective trial. Eur Heart J Cardiovasc Imaging. 2014. Dec. 3. [pmid: 25473041].
32 Miller AH, Pepe PE, Peshock R, et al. Is coronary computed tomography angiography a resource sparing strategy in the risk stratification and evaluation of acute chest pain? Results of a randomized controlled trial. Acad Emerg Med. May. 2011;18(5):458-67. [pmid: 21569165].
33 Min JK, Koduru S, Dunning AM, et al. Coronary CT angiography versus myocardial perfusion imaging for near-term quality of life, cost and radiation exposure: a prospective multicenter randomized pilot trial. J Cardiovasc Comput Tomogr. Jul-Aug. 2012;6(4):274-83. [pmid: 22732201].
34 Min JK, Shaw LJ, Berman DS, et al. Costs and clinical outcomes in individuals without known coronary artery disease undergoing coronary computed tomographic angiography from an analysis of Medicare category III transaction codes. Am J Cardiol. Sep. 15. 2008;102(6):672-8. [pmid: 18773986].
35 Nabi F, Chang SM, Pratt CM, et al. Coronary artery calcium scoring in the emergency department: identifying which patients with chest pain can be safely discharged home. Ann Emerg Med. Sep. 2010;56(3):220-9. [pmid: 20138399].
36 Nance JW Jr., Schlett CL, Schoepf UJ, et al. Incremental prognostic value of different components of coronary atherosclerotic plaque at cardiac CT angiography beyond coronary calcification in patients with acute chest pain. Radiology. Sep. 2012;264(3):679-90. [pmid: 22820732].
37 Nielsen LH, Markenvard J, Jensen JM, et al. Frontline diagnostic evaluation of patients suspected of angina by coronary computed tomography reduces downstream resource utilization when compared to conventional ischemia testing. Int J Cardiovasc Imaging. Jul. 2011;27(6):813-23. [pmid: 21042860].
38 Nielsen LH, Olsen J, Markenvard J, et al. Effects on costs of frontline diagnostic evaluation in patients suspected of angina: coronary computed tomography angiography vs. conventional ischaemia testing. Eur Heart J Cardiovasc Imaging. May. 2013;14(5):449-55. 449. 455. [pmid: 22922828].
39 Petretta M, Daniele S, Acampa W543, et al. Prognostic value of coronary artery calcium score and coronary CT angiography in patients with intermediate risk of coronary artery disease. Int J Cardiovasc Imaging. Aug. 2012;28(6):1547-56. [pmid: 21922205].
40 Poon M, Cortegiano M, Abramowicz AJ, et al. Associations between routine coronary computed tomographic angiography and reduced unnecessary hospital admissions, length of stay, recidivism rates, and invasive coronary angiography in the emergency department triage of chest pain. J Am Coll Cardiol. Aug. 6. 2013;62(6):543-52. [pmid: 23684682].
41 Sabharwal NK, Stoykova B, Taneja AK, et al. A randomized trial of exercise treadmill ECG versus stress SPECT myocardial perfusion imaging as an initial diagnostic strategy in stable patients with chest pain and suspected CAD: cost analysis. [Erratum appears in J Nucl Cardiol. 2007 May-Jun;14(3):414]. J Nucl Cardiol. Apr. 2007;14(2):174-86. [pmid: 17386379].
42 Sanfilippo AJ, Abdollah H, Knott TC, et al. Stress echocardiography in the evaluation of women presenting with chest pain syndrome: a randomized, prospective comparison with electrocardiographic stress testing. Can J Cardiol. Apr. 2005;21(5):405-12. [pmid: 15861257].
43 Schmermund A, Stang A, Mohlenkamp S, et al. Prognostic value of electron-beam computed tomography-derived coronary calcium scores compared with clinical parameters in patients evaluated for coronary artery disease. Prognostic value of EBCT in symptomatic patients. Z Kardiol. Sep. 2004;93(9):696-705. [pmid: 15365737].
44 Severi S, Picano E, Michelassi C, et al. Diagnostic and prognostic value of dipyridamole echocardiography in patients with suspected coronary artery disease. Comparison with exercise electrocardiography. Circulation. Mar. 1994;89(3):1160-73. [pmid: 8124803].
45 Shaw LJ, Mieres JH, Hendel RH, et al. Comparative effectiveness of exercise electrocardiography with or without myocardial perfusion single photon emission computed tomography in women with suspected coronary artery disease: results from the What Is the Optimal Method for Ischemia Evaluation in Women (WOMEN) trial. Circulation. Sep. 13. 2011;124(11):1239-49. [pmid: 21844080].
46 Shreibati JB, Baker LC, Hlatky MA. Association of coronary CT angiography or stress testing with subsequent utilization and spending among Medicare beneficiaries. JAMA. Nov. 16. 2011;306(19):2128-36. [pmid: 22089720].
47 Takeuchi M, Sonoda S, Miura Y, et al. Comparative diagnostic value of dobutamine stress echocardiography and stress thallium-201 single-photon-emission computed tomography for detecting coronary artery disease in women. Coron Artery Dis. Nov. 1996;7(11):831-5. [pmid: 8993941].
48 Tandon V, Hall D, Yam Y, et al. Rates of downstream invasive coronary angiography and revascularization: computed tomographic coronary angiography vs. Tc-99m single photon emission computed tomography. Eur Heart J. Mar. 2012;33(6):776-82. [pmid: 21893487].
49 Truong QA, Hayden D, Woodard PK, et al. Sex differences in the effectiveness of early coronary computed tomographic angiography compared with standard emergency department evaluation for acute chest pain: the rule-out myocardial infarction with Computer-Assisted Tomography (ROMICAT)-II Trial. Circulation. Jun. 25. 2013;127(25):2494-502. [pmid: 23685743].
50 Villines TC, Hulten EA, Shaw LJ, et al. Prevalence and severity of coronary artery disease and adverse events among symptomatic patients with coronary artery calcification scores of zero undergoing coronary computed tomography angiography: results from the CONFIRM (Coronary CT Angiography Evaluation for Clinical Outcomes: An International Multicenter) registry. J Am Coll Cardiol. Dec. 6. 2011;58(24):2533-40. [pmid: 22079127].
51 Yamauchi T, Tamaki N, Kasanuki H, et al. Optimal initial diagnostic strategies for the evaluation of stable angina patients: a multicenter, prospective study on myocardial perfusion imaging, computed tomographic angiography, and coronary angiography. Circ J. 2012;76(12):2832-9. [pmid: 22975716].