# Search Strategy

Database: Ovid MEDLINE(R) and Ovid OLDMEDLINE(R) <1946 to July Week 3 2015>

Search Strategy:

--------------------------------------------------------------------------------

1 | exp Coronary Disease/di, pa, ra, ri, us [Diagnosis, Pathology, Radiography, Radionuclide Imaging, Ultrasonography]
2 | exp Coronary Circulation/
3 | 1 or 2
4 | exp Exercise Test/
5 | exp Electrocardiography/
6 | exp Echocardiography/
7 | 5 or 6
8 | 4 and 7
9 | 3 and 8
10 | exp Tomography, Emission-Computed, Single-Photon/
11 | exp Positron-Emission Tomography/
12 | 3 and 10
13 | 3 and 11
14 | (radionuclid$ adj5 scintigra$).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier]
15 | 3 and 14
16 | exp Vasodilator Agents/
17 | exp Dobutamine/
18 | 16 or 17
19 | exp Magnetic Resonance Imaging/
20 | 3 and 18 and 19
21 | exp Tomography, X-Ray Computed/
22 | 22 3 and 21
23 | exp Image Interpretation, Computer-Assisted/
24 | exp Calcium/
25 | exp Calcium Compounds/
26 | exp Calcium Metabolism Disorders/
27 | 24 or 25 or 26
28 | 23 and 27
29 | exp Heart Diseases/
30 | exp Heart/
31 | exp Cardiovascular Physiological Phenomena/
32 | 29 or 30 or 31
33 | 28 and 32
34 | exp Cardiac Imaging Techniques/
35 | 21 and 34
36 | 3 and 35
37 | exp Magnetic Resonance Imaging/
38 | 3 and 37
39 | 9 or 12 or 13 or 15 or 20 or 22 or 33 or 36 or 38
40 | limit 39 to english language
41 | limit 39 to abstracts
42 | 40 or 41

Database: EBM Reviews - Cochrane Database of Systematic Reviews <2005 to July 2015>

Search Strategy:

--------------------------------------------------------------------------------

1 | (coronary adj5 (diseas$ or occlus$ or occlud$ or block$ or stenos$ or stenotic$ or arterioscler$ or atheroscler$ or vasospas$ or aneurysm$)).mp. [mp=title, abstract, full text, keywords, caption text]
2 | (coronary adj5 (circulat$ or ((blood adj3 flow$) or supply$ or supplie$))).mp.
3 | ((stable adj2 angina$) or (chest adj2 pain$)).mp. [mp=title, abstract, full text, keywords, caption text]
4 | 1 or 2 or 3
5 | ((Exercis$ or treadmill$ or bicycl$ or step or steps or stress$) adj3 (echocardiogra$ or electrocardiogra$ or ekg or ecg)).mp.
6 | 6 ((Exercis$ or treadmill$ or bicycl$ or step or steps or stress$) adj3 Test$).mp.
7 | (Electrocardiogra$ or ekg or ecg).mp.
8 | Echocardiogra$.mp.
9 | 7 or 8
10 | 6 and 9
11 | 5 or 10
12 | 4 and 11
13 | (spect or (single adj3 photon$ adj5 (emit$ or emission$) adj7 tomogra$)).mp.
14 | 4 and 13
15 | 15 ((pet adj2 scan$) or (Positron$ adj3 (emit$ or emission$) adj7 tomogra$)).mp.
16 | 4 and 15
17 | (radionuclid$ adj5 scintigra$).mp.
18 | 4 and 17
19 | vasodilator$.mp.
20 | dobutamine.mp.
21 | 19 or 20
22 | (mri or (magnet$ adj3 resonan$ adj3 imag$)).mp.
23 | 4 and 21 and 22
24 | cine ct.mp.
25 | 25 ((x-ray$ or spiral$ or multidetector$ or cone beam$ or electron beam$) adj5 (comput$ adj3 tomogra$)).mp.
26 | ((x-ray$ or spiral$ or multidetector$ or cone beam$ or electron beam$) adj5 ((cat or ct) adj scan$)).mp.
27 | 24 or 25 or 26
28 | 4 and 27
29 | 29 (comput$ adj5 assist$ adj7 (imag$ adj5 process$)).mp. [mp=title, abstract, full text, keywords, caption text]
30 | (calcium or ca++ or ca ion$ ca2+ or ca+2).mp. [mp=title, abstract, full text, keywords, caption text]
31 | 29 and 30
32 | 4 and 31
33 | (heart$ or cardia$ or cardio$ or myocard$ or coronar$).mp. [mp=title, abstract, full text, keywords, caption text]
34 | 32 and 33
35 | (non-invasiv$ adj5 (imag$ or procedur$ or interven$ or scan$ or test$ or diagno$ or radiogra$ or x-ray$)).mp. [mp=title, abstract, full text, keywords, caption text]
36 | (“not ” adj invasiv$ adj5 (imag$ or procedur$ or interven$ or scan$ or test$ or diagno$ or radiogra$ or x-ray$)).mp.
37 | 37 35 or 36
38 | 4 and 37
39 | 12 or 14 or 16 or 18 or 23 or 28 or 34 or 38

Database: EBM Reviews - Cochrane Central Register of Controlled Trials <July 2015>

Search Strategy:

--------------------------------------------------------------------------------

1 | (coronary adj5 (diseas$ or occlus$ or occlud$ or block$ or stenos$ or stenotic$ or arterioscler$ or atheroscler$ or vasospas$ or aneurysm$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
2 | (coronary adj5 (circulat$ or ((blood adj3 flow$) or supply$ or supplie$))).mp.
3 | ((stable adj2 angina$) or (chest adj2 pain$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
4 | 1 or 2 or 3
5 | ((Exercis$ or treadmill$ or bicycl$ or step or steps or stress$) adj3 (echocardiogra$ or electrocardiogra$ or ekg or ecg)).mp.
6 | ((Exercis$ or treadmill$ or bicycl$ or step or steps or stress$) adj3 Test$).mp.
7 | (Electrocardiogra$ or ekg or ecg).mp.
8 | Echocardiogra$.mp.
9 | 7 or 8
10 | 6 and 9
11 | 11 5 or 10
12 | 4 and 11
13 | (spect or (single adj3 photon$ adj5 (emit$ or emission$) adj7 tomogra$)).mp.
14 | 4 and 13
15 | ((pet adj2 scan$) or (Positron$ adj3 (emit$ or emission$) adj7 tomogra$)).mp.
16 | 4 and 15
17 | (radionuclid$ adj5 scintigra$).mp.
18 | 4 and 17
19 | vasodilator$.mp.
20 | dobutamine.mp.
21 | 19 or 20
22 | 22 (mri or (magnet$ adj3 resonan$ adj3 imag$)).mp.
23 | 4 and 21 and 22
24 | cine ct.mp.
25 | ((x-ray$ or spiral$ or multidetector$ or cone beam$ or electron beam$) adj5 (comput$ adj3 tomogra$)).mp.
26 | ((x-ray$ or spiral$ or multidetector$ or cone beam$ or electron beam$) adj5 ((cat or ct) adj scan$)).mp.
27 | 24 or 25 or 26
28 | 4 and 27
29 | (comput$ adj5 assist$ adj7 (imag$ adj5 process$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
30 | (calcium or ca++ or ca ion$ ca2+ or ca+2).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
31 | 29 and 30
32 | 4 and 31
33 | (heart$ or cardia$ or cardio$ or myocard$ or coronar$).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
34 | 32 and 33
35 | (non-invasiv$ adj5 (imag$ or procedur$ or interven$ or scan$ or test$ or diagno$ or radiogra$ or x-ray$)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword]
36 | (“not ” adj invasiv$ adj5 (imag$ or procedur$ or interven$ or scan$ or test$ or diagno$ or radiogra$ or x-ray$)).mp.
37 | 37 35 or 36
38 | 4 and 37
39 | 12 or 14 or 16 or 18 or 23 or 28 or 34 or 38

Database: EBM Reviews - Health Technology Assessment <2nd Quarter 2015>

Search Strategy:

--------------------------------------------------------------------------------

1 | (coronary adj5 (diseas$ or occlus$ or occlud$ or block$ or stenos$ or stenotic$ or arterioscler$ or atheroscler$ or vasospas$ or aneurysm$)).mp. [mp=title, text, subject heading word]
2 | (coronary adj5 (circulat$ or ((blood adj3 flow$) or supply$ or supplie$))).mp.
3 | ((stable adj2 angina$) or (chest adj2 pain$)).mp. [mp=title, text, subject heading word]
4 | 1 or 2 or 3
5 | ((Exercis$ or treadmill$ or bicycl$ or step or steps or stress$) adj3 (echocardiogra$ or electrocardiogra$ or ekg or ecg)).mp.
6 | ((Exercis$ or treadmill$ or bicycl$ or step or steps or stress$) adj3 Test$).mp.
7 | (Electrocardiogra$ or ekg or ecg).mp.
8 | Echocardiogra$.mp.
9 | 7 or 8
10 | 6 and 9
11 | 5 or 10
12 | 4 and 11
13 | (spect or (single adj3 photon$ adj5 (emit$ or emission$) adj7 tomogra$)).mp.
14 | 4 and 13
15 | ((pet adj2 scan$) or (Positron$ adj3 (emit$ or emission$) adj7 tomogra$)).mp.
16 | 4 and 15
17 | (radionuclid$ adj5 scintigra$).mp.
18 | 4 and 17
19 | vasodilator$.mp.
20 | dobutamine.mp.
21 | 19 or 20
22 | (mri or (magnet$ adj3 resonan$ adj3 imag$)).mp.
23 | 4 and 21 and 22
24 | cine ct.mp.
25 | ((x-ray$ or spiral$ or multidetector$ or cone beam$ or electron beam$) adj5 (comput$ adj3 tomogra$)).mp.
26 | ((x-ray$ or spiral$ or multidetector$ or cone beam$ or electron beam$) adj5 ((cat or ct) adj scan$)).mp.
27 | 24 or 25 or 26
28 | 4 and 27
29 | (comput$ adj5 assist$ adj7 (imag$ adj5 process$)).mp. [mp=title, text, subject heading word]
30 | (calcium or ca++ or ca ion$ ca2+ or ca+2).mp. [mp=title, text, subject heading word]
31 | 29 and 30
32 | 4 and 31
33 | (heart$ or cardia$ or cardio$ or myocard$ or coronar$).mp. [mp=title, text, subject heading word] (1374)
34 | 32 and 33
35 | (non-invasiv$ adj5 (imag$ or procedur$ or interven$ or scan$ or test$ or diagno$ or radiogra$ or x-ray$)).mp. [mp=title, text, subject heading word]
36 | (“not ” adj invasiv$ adj5 (imag$ or procedur$ or interven$ or scan$ or test$ or diagno$ or radiogra$ or x-ray$)).mp.
37 | 35 or 36
38 | 4 and 37
39 | 12 or 14 or 16 or 18 or 23 or 28 or 34 or 38