# Abbreviations and Acronyms

ACCF: American College of Cardiology Foundation
AHA: American Heart Association
AHRQ: Agency for Healthcare Research and Quality
BMIPP: Beta-methyl iodophenyl pentadecanoic acid
CABG: Coronary artery bypass grafting
CAD: Coronary artery disease
CCTA: Coronary computed tomography angiography
CER: Comparative Effectiveness Review
CMR: Cardiac magnetic resonance
CT: Computed tomography
EBCT: Electron beam computed tomography
ECG: Electrocardiography
FDG-PET: Fludeoxyglucose (18F) positron emission tomography
FDA: Food and Drug Administration
FFR: Fractional flow reserve
F/U: Followup
HIV: Human immunodeficiency virus
ICA: Invasive coronary angiography
IQR: Interquartile range
KQ: Key Question
LBBB: Left bundle branch block
LVEF: Left ventricular ejection fraction
MDCT: Multidetector computed tomography
MI: Myocardial infarction
MPI: Myocardial perfusion imaging
MRA: Magnetic resonance angiography
MRI: Magnetic resonance imaging
MUGA: Multigated acquisition scan
N/A: Not applicable
NR: Not reported
NS: Not statistically significant
NSTE-ACS: Non-ST elevation acute coronary syndromes
NSTEMI: Non-ST-segment elevation myocardial infarction
PCI: Percutaneous coronary intervention
PET: Positron emission tomography
PTCA: Percutaneous transluminal coronary angioplasty
RCT: Randomized controlled trial
RD: Risk difference
RR: Relative risk
SD: Standard deviation
SPECT: Single photon emission computed tomography
STEMI: ST-segment elevation myocardial infarction
TEE: Transesophageal echocardiography
TEP: Technical Expert Panel
TIMI: Thrombolysis in Myocardial Infarction Risk Score