# References

1 Agency for Healthcare Research and Quality. CAHPS Cultural Competence Item Set. Available at: https://cahps.ahrq.gov/surveys-guidance/item-sets/cultural/index.html. Nov 15, 2013.
2 Office of Minority Health-Department of Health and Human Services. The National CLAS Standards. Available at: http://minorityhealth.hhs.gov/templates/browse.aspx?lvl=2&lvlID=15. May 29, 2013.
3 Gregg J, Saha S. Losing culture on the way to competence: the use and misuse of culture in medical education. Acad Med. Jun. 2006;81(6):542-7. [pmid: 16728802].
4 World Health Organization. International Classification of Functioning, Disability and Health, ICF. World Health Organization. 2001.
5 Iezzoni LI. Eliminating health and health care disparities among the growing population of people with disabilities. Health Aff (Millwood). Oct. 2011;30(10):1947-54. [pmid: 21976339].
6 Thomas SB, Quinn SC, Butler J, et al. Toward a fourth generation of disparities research to achieve health equity. Annual review of public health. 2011;32:399-416. [pmid: 21219164].
7 Goode TD, Carter-Pokras OD, Horner-Johnson W, et al. Parallel Tracks: Reflections on the Need for Collaborative Health Disparities Research on Race/Ethnicity and Disability. Medical Care. 2014;52:S3-S8. [doi: 10.1097/MLR.0000000000000201]. [pmid: 25215917].
8 Peterson-Besse JJ, O'Brien MS, Walsh ES, et al. Clinical preventive service use disparities among subgroups of people with disabilities: A scoping review. Disability and Health Journal. 10. 2014;7(4):373-93. [pmid: 25224979].
9 Gill C. A psychological view of disability culture. Disability: The Social, Political and Ethical Debate. 1995:163.
10 Eddey GE, Robey KL. Considering the culture of disability in cultural competence education. Acad Med. Jul. 2005;80(7):706-12. [pmid: 15980092].
11 Lipson JG, Rogers JG. Cultural aspects of disability. J Transcult Nurs. 2000;11(3):212-9. [pmid: 11982110].
12 Moher D, Liberati A, Tetzlaff J, et al. Preferred reporting items for systematic reviews and meta-analyses: the PRISMA statement. BMJ (Clinical research ed). 2009;339:b2535. [pmid: 19622551].
13 Collie K, Kreshka MA, Ferrier S, et al. Videoconferencing for delivery of breast cancer support groups to women living in rural communities: A pilot study. Psychooncology. 2007;16(8):778-82. [pmid: 17253594].
14 Hawke LD, Michalak EE, Maxwell V, et al. Reducing stigma toward people with bipolar disorder: Impact of a filmed theatrical intervention based on a personal narrative. International Journal of Social Psychiatry. 2014;60(8):741-50. [pmid: 24351967].
15 Commons Treloar AJ. Effectiveness of education programs in changing clinician's attitudes towards treating borderline personality disorder. Psychiatr Serv. 2009;60(8):1128-31. [pmid: 19648203].
16 Pernice R, Lys K. Interventions for attitude change towards people with disabilities: how successful are they?. Int J Rehabil Res. Jun. 1996;19(2):171-4. [pmid: 8842831].
17 Pittman JOE, Noh S, Coleman D. Evaluating the effectiveness of a consumer delivered anti-stigma program: replication with graduate-level helping professionals. Psychiatr Rehabil J. 2010;33(3):236-8. [pmid: 20061261].
18 Jones RG, Kerr MP. A randomized control trial of an opportunistic health screening tool in primary care for people with intellectual disability. J Intellect Disabil Res. 1997;41(5):409-15. [pmid: 9373821].
19 Bell JS, Johns R, Chen TF. Pharmacy students' and graduates' attitudes towards people with schizophrenia and severe depression. Am J Pharm Educ. Aug. 15. 2006;70(4):77. [pmid: 17136196].
20 Kerby J, Calton T, DiMambro B, et al. Anti-stigma films and medical students' attitudes towards mental illness and psychiatry: Randomised controlled trial. Psychiatric Bulletin. 2008;32(9):345-9.
21 Kassam A, Glozier N, Leese M, et al. A controlled trial of mental illness related stigma training for medical students. BMC Med Educ. 2011;11:51. [pmid: 21801355].
22 Goddard L, Jordan L. Changing attitudes about persons with disabilities: effects of a simulation. J Neurosci Nurs. Oct. 1998;30(5):307-13. [pmid: 9816562].
23 Symons AB, Morley CP, McGuigan D, et al. A curriculum on care for people with disabilities: effects on medical student self-reported attitudes and comfort level. Disabil Health J. Jan. 2014;7(1):88-95. [pmid: 24411512].
24 Melville CA, Cooper SA, Morrison J, et al. The outcomes of an intervention study to reduce the barriers experienced by people with intellectual disabilities accessing primary health care services. J Intellect Disabil Res. Jan. 2006;50(Pt 1):11-7. [pmid: 16316426].
25 Nguyen E, Chen TF, O'Reilly CL. Evaluating the impact of direct and indirect contact on the mental health stigma of pharmacy students. Soc Psychiatry Psychiatr Epidemiol. Jul. 2012;47(7):1087-98. [pmid: 21755345].
26 Clement S, van Nieuwenhuizen A, Kassam A, et al. Filmed v. live social contact interventions to reduce stigma: randomised controlled trial. Br J Psychiatry. Jul. 2012;201(1):57-64. [pmid: 22157800].
27 Bannatyne A, Stapleton P. Educating medical students about anorexia nervosa: A potential method for reducing the volitional stigma associated with the disorder. Eating Disorders: The Journal of Treatment & Prevention. 2015;23(2):115-33. [pmid: 10640266].
28 Cutler JL, Harding KJ, Hutner LA, et al. Reducing medical students' stigmatization of people with chronic mental illness: A field intervention at the “living museum” state hospital art studio. Acad Psychiatry. 2012;36(3):191-6. [pmid: 22751820].
29 Friedrich B, Evans-Lacko S, London J, et al. Anti-stigma training for medical students: the Education Not Discrimination project. Br J Psychiatry Suppl. Apr. 2013;55:s89-94. [pmid: 23553700].
30 Papish A, Kassam A, Modgill G, et al. Reducing the stigma of mental illness in undergraduate medical education: a randomized controlled trial. BMC Med Educ. 2013;13:141. [pmid: 24156397].
31 O'Reilly CL, Bell JS, Kelly PJ, et al. Impact of mental health first aid training on pharmacy students' knowledge, attitudes and self-reported behaviour: a controlled trial. Aust N Z J Psychiatry. Jul. 2011;45(7):549-57. [pmid: 21718124].
32 Patten SB, Remillard A, Phillips L, et al. Effectiveness of contact-based education for reducing mental illness-related stigma in pharmacy students. BMC Med Educ. 2012;12:120. [pmid: 23216787].
33 Munro A, Watson HE, McFadyen A. Assessing the impact of training on mental health nurses' therapeutic attitudes and knowledge about co-morbidity: a randomised controlled trial. Int J Nurs Stud. Nov. 2007;44(8):1430-8. [pmid: 16996517].
34 Michaels PJ, Corrigan PW, Buchholz B, et al. Changing stigma through a consumer-based stigma reduction program. Community Ment Health J. May. 2014;50(4):395-401. [pmid: 23760975].
35 Kirby RL, Crawford KA, Smith C, et al. A wheelchair workshop for medical students improves knowledge and skills: a randomized controlled trial. Am J Phys Med Rehabil. Mar. 2011;90(3):197-206. [pmid: 21273901].
36 Domenech J, Sanchez-Zuriaga D, Segura-Orti E, et al. Impact of biomedical and biopsychosocial training sessions on the attitudes, beliefs, and recommendations of health care providers about low back pain: a randomised clinical trial. Pain. Nov. 2011;152(11):2557-63. [pmid: 21917377].
37 Peterson JJ, Suzuki R, Walsh ES, et al. Improving cancer screening among women with mobility impairments: randomized controlled trial of a participatory workshop intervention. Am J Health Promot. Mar-Apr. 2012;26(4):212-6. [pmid: 22375570].
38 Lennox N, Bain C, Rey-Conde T, et al. Effects of a comprehensive health assessment programme for Australian adults with intellectual disability: a cluster randomized trial. Int J Epidemiol. Feb. 2007;36(1):139-46. [pmid: 17218326].
39 Turk V, Burchell S, Burrha S, et al. An Evaluation of the Implementation of Hand Held Health Records with Adults with Learning Disabilities: A Cluster Randomized Controlled Trial. J Appl Res Intellect Disabil. 2010;23(2):100-11.
40 Meurs D, Rutten M, de Jongh A. Does information about patients who are intellectually disabled translate into better cooperation during dental visits?. Spec Care Dentist. Sep-Oct. 2010;30(5):200-5. [pmid: 20831738].
41 Wolraich ML, Bickman L, Lambert EW, et al. Intervening to improve communication between parents, teachers, and primary care providers of children with ADHD or at high risk for ADHD. J Atten Disord. Aug. 2005;9(1):354-68. [pmid: 16371681].
42 Knaevelsrud C, Maercker A. Long-term effects of an internet-based treatment for posttraumatic stress. Cognitive Behav Ther. 2010;39(1):72-7. [pmid: 19675958].
43 Finlayson M, Preissner K, Cho C, et al. Randomized trial of a teleconference-delivered fatigue management program for people with multiple sclerosis. Mult Scler. Sep. 2011;17(9):1130-40. [pmid: 21561960].
44 Shigaki CL, Smarr KL, Siva C, et al. RAHelp: an online intervention for individuals with rheumatoid arthritis. Arthritis Care Res (Hoboken). Oct. 2013;65(10):1573-81. [pmid: 23666599].
45 Cutler JL, Harding KJ, Hutner LA, et al. Reducing medical students' stigmatization of people with chronic mental illness: a field intervention at the “living museum” state hospital art studio. Acad Psychiatry. May. 1. 2012;36(3):191-6. [pmid: 22751820].
46 French S. Simulation Exercises in Disability Awareness Training: A Critique. Disability, Handicap & Society. 1992. 01. 01. 1992;7(3):257-66.
47 Morland LA, Greene CJ, Rosen CS, et al. Telemedicine for anger management therapy in a rural population of combat veterans with posttraumatic stress disorder: A randomized non inferiority trial. J Clin Psychiatry. 2010;71(7):855-63. [pmid: 20122374].
48 Morland LA, Mackintosh M-A, Greene CJ, et al. Cognitive processing therapy for posttraumatic stress disorder delivered to rural veterans via telemental health: A randomized noninferiority clinical trial. J Clin Psychiatry. 2014;75(5):470-6. [pmid: 24922484].
49 Bombardier CH, Ehde DM, Gibbons LE, et al. Telephone-based physical activity counseling for major depression in people with multiple sclerosis. Journal of Consulting and Clinical Psychology. 2013;81(1):89-99. [pmid: 23379265].
50 Knaevelsrud C, Maercker A. Internet-based treatment for PTSD reduces distress and facilitates the development of a strong therapeutic alliance: a randomized controlled clinical trial. BMC Psychiatry. 2007;7(1):13. PMID:. [doi: 10.1186/1471-244X-7-13]. [pmid: 17442125].
51 Horvat L, Horey D, Romios P, et al. Cultural competence education for health professionals. Cochrane Database Syst Rev. 2014;5. CD009405. [pmid: 24793445].
52 Horner-Johnson W, Dobbertin K. Usual source of care and unmet health care needs: interaction of disability with race and ethnicity. Med Care. Oct. 2014;52(10 Suppl 3):S40-50. [pmid: 25215919].
53 Horner-Johnson W, Fujiura GT, Goode TD. Promoting a new research agenda: health disparities research at the intersection of disability, race, and ethnicity. Med Care. Oct. 2014;52(10 Suppl 3):S1-2. [pmid: 25215914].
54 Bershadsky J, Hiersteiner D, Fay ML, et al. Race/ethnicity and the use of preventive health care among adults with intellectual and developmental disabilities. Med Care. Oct. 2014;52(10 Suppl 3):S25-31. [pmid: 25215916].
55 Peterson-Besse JJ, Walsh ES, Horner-Johnson W, et al. Barriers to health care among people with disabilities who are members of underserved racial/ethnic groups: a scoping review of the literature. Med Care. Oct. 2014;52(10 Suppl 3):S51-63. [pmid: 25215920].
56 Ozturk OD, McDermott S, Mann JR, et al. Disparities in Health Care Utilization by Race Among Teenagers and Young Adults With Muscular Dystrophy. Medical Care. 2014;52(10 Suppl 3):S32-S9. [pmid: 25215918].
57 Jones CP. Systems of Power, Axes of Inequity: Parallels, Intersections, Braiding the Strands. Medical Care. 2014;52(10 Suppl 3):S71-S5. [pmid: 25215922].
58 Almomani F, Brown C, Williams KB. The effect of an oral health promotion program for people with psychiatric disabilities. Psychiatr Rehabil J. Spring. 2006;29(4):274-81. [pmid: 16689038].
59 Berman BA, Jo A, Cumberland WG, et al. Breast cancer knowledge and practices among D/deaf women. Disabil Health J. Oct. 2013;6(4):303-16. [pmid: 24060253].
60 Bombardier CH, Bell KR, Temkin NR, et al. The efficacy of a scheduled telephone intervention for ameliorating depressive symptoms during the first year after traumatic brain injury. J Head Trauma Rehabil. Jul-Aug. 2009;24(4):230-8. [pmid: 19625862].
61 Carraro A, Gobbi E. Effects of an exercise programme on anxiety in adults with intellectual disabilities. Res Dev Disabil. Jul-Aug. 2012;33(4):1221-6. [pmid: 22502848].
62 Gephart EF, Loman DG. Use of prevention and prevention plus weight management guidelines for youth with developmental disabilities living in group homes. J Pediatr Health Care. Mar-Apr. 2013;27(2):98-108. [pmid: 23414975].
63 Harry KM, Malcarne VL, Branz P, et al. Evaluating a skin cancer education program for the Deaf community. J Cancer Educ. Jun. 2012;27(3):501-6. [pmid: 22544511].
64 Horner-Johnson W, Drum CE, Abdullah N. A randomized trial of a health promotion intervention for adults with disabilities. Disabil Health J. Oct. 2011;4(4):254-61. [pmid: 22014673].
65 Jansen M, de Groot IJ, van Alfen N, et al. Physical training in boys with Duchenne Muscular Dystrophy: the protocol of the No Use is Disuse study. BMC Pediatr. 2010;10:55. [pmid: 20691042].
66 Jinks A, Cotton A, Rylance R. Obesity interventions for people with a learning disability: an integrative literature review. J Adv Nurs. Mar. 2011;67(3):460-71. [pmid: 21077935].
67 Perez-Cruzado D, Cuesta-Vargas AI. Improving Adherence Physical Activity with a Smartphone Application Based on Adults with Intellectual Disabilities (APPCOID). BMC Public Health. 2013;13:1173. [pmid: 24330604].
68 Steffen T, Petersen C, Dvorak L. Community-based exercise and wellness program for people diagnosed with Parkinson disease: experiences from a 10-month trial. Journal of geriatric physical therapy. (2001). Oct-Dec. 2012;35(4):173-80. [pmid: 22460178].
69 Froehlich-Grobe K, White GW. Promoting physical activity among women with mobility impairments: a randomized controlled trial to assess a home- and community-based intervention. Arch Phys Med Rehabil. Apr. 2004;85(4):640-8. [pmid: 15083442].
70 Ravesloot C, Seekins T, White G. Living Well With a Disability health promotion intervention: improved health status for consumers and lower costs for health care policymakers. Rehabil Psychol. 2005;50(3):239.
71 Ravesloot C, Seekins T, Young Q-R. Health promotion for people with chronic illness and physical disabilities: the connection between health psychology and disability prevention. Clinical Psychology & Psychotherapy. 1998;5(2):76-85.
72 Rimmer JH. Health Promotion for People With Disabilities: The Emerging Paradigm Shift From Disability Prevention to Prevention of Secondary Conditions. Physical Therapy. May. 1. 1999;79(5):495-502. [pmid: 10331753].
73 Rimmer JH, Rauworth A, Wang E, et al. A randomized controlled trial to increase physical activity and reduce obesity in a predominantly African American group of women with mobility disabilities and severe obesity. Preventive medicine. May. 2009;48(5):473-9. [pmid: 19459233].
74 Rimmer JH, Rowland JL, Yamaki K. Obesity and secondary conditions in adolescents with disabilities: addressing the needs of an underserved population. The Journal of adolescent health : official publication of the Society for Adolescent Medicine. Sep. 2007;41(3):224-9. [pmid: 17707291].
75 Saha S, Beach MC, Cooper LA. Patient centeredness, cultural competence and healthcare quality. J Natl Med Assoc. Nov. 2008;100(11):1275-85. [pmid: 19024223].
76 Baker K, Beagan B. Making assumptions, making space: an anthropological critique of cultural competency and its relevance to queer patients. Med Anthropol Q. Dec. 2014;28(4):578-98. [pmid: 25196115].
77 Institute of Medicine. The Health of Lesbian, Gay, Bisexual, and Transgender People: Building a Foundation for Better Understanding. 2011/10/21 ed. 2011.
78 Bradford J, Mustanski B. Health Disparities Among Sexual Minority Youth: The Value of Population Data. Am J Public Health. 2013;104(2):197. [pmid: 24328630].
79 Bauer GR, Jairam JA. Are Lesbians Really Women Who Have Sex with Women (WSW)? Methodological Concerns in Measuring Sexual Orientation in Health Research. Women Health. 2008. 12. 26. 2008;48(4):383-408. [pmid: 19301530].
80 Pathela P, Blank S, Sell RL, et al. The importance of both sexual behavior and identity. Am J Public Health. 2006. 05. 01. 2006;96(5):765. [pmid: 16571688].
81 Gates GJ. How many people are lesbian, gay, bisexual and transgender?. 2011.
82 Midanik LT, Drabble L, Trocki K, et al. Sexual orientation and alcohol use: identity versus behavior measures. J LGBT Health Res. 2007;3(1):25-35. [pmid: 18029313].
83 Everett BG. Sexual orientation disparities in sexually transmitted infections: examining the intersection between sexual identity and sexual behavior. Arch Sex Behav. Feb. 2013;42(2):225-36. [pmid: 22350122].
84 Przedworski JM, McAlpine DD, Karaca-Mandic P, et al. Health and health risks among sexual minority women: an examination of 3 subgroups. Am J Public Health. Jun. 2014;104(6):1045-7. [pmid: 24825204].
85 Conron KJ, Scott G, Stowell GS, et al. Transgender health in Massachusetts: results from a household probability sample of adults. Am J Public Health. Jan. 2012;102(1):118-22. [pmid: 22095354].
86 Young RM, Meyer IH. The Trouble With “MSM” and “WSW”: Erasure of the Sexual-Minority Person in Public Health Discourse. Am J Public Health. 2005;95(7):1144-9. [pmid: 15961753].
87 Hollenbach A, Eckstrand K, Dreger A. Implementing curricular and institutional climate changes to improve health care for individuals who are LGBT, gender nonconforming, or born with DSD: A resource for medical educators. Washington. AAMC. 2014.
88 Cochran SD, Mays VM. Sexual Orientation and Mortality Among US Men Aged 17 to 59 Years: Results From the National Health and Nutrition Examination Survey III. Am J Public Health. 2011;101(6):1133-8. [pmid: 21493941].
89 Kapadia F, Landers S. The Health of Sexual Minorities: A New Frontier. Am J Public Health. 2013. 10. 01. 2013;103(10):1735. [pmid: 23947323].
90 Coulter RW, Kenst KS, Bowen DJ, et al. Research funded by the National Institutes of Health on the health of lesbian, gay, bisexual, and transgender populations. Am J Public Health. Feb. 2014;104(2):e105-12. [pmid: 24328665].
91 Wolitski RJ, Fenton KA. Sexual health, HIV, and sexually transmitted infections among gay, bisexual, and other men who have sex with men in the United States. Aids Behav. Apr. Suppl 1. 2011;15:S9-17. [pmid: 21331797].
92 Cochran SD, Bandiera FC, Mays VM. Sexual orientation-related differences in tobacco use and secondhand smoke exposure among US adults aged 20 to 59 years: 2003-2010 National Health and Nutrition Examination Surveys. Am J Public Health. Oct. 2013;103(10):1837-44. [pmid: 23948019].
93 Boehmer U, Bowen DJ, Bauer GR. Overweight and obesity in sexual-minority women: evidence from population-based data. Am J Public Health. Jun. 2007;97(6):1134-40. [pmid: 17463369].
94 Rosario M, Corliss HL, Everett BG, et al. Sexual orientation disparities in cancer-related risk behaviors of tobacco, alcohol, sexual behaviors, and diet and physical activity: pooled Youth Risk Behavior Surveys. Am J Public Health. Feb. 2014;104(2):245-54. [pmid: 24328632].
95 Talley AE, Hughes TL, Aranda F, et al. Exploring alcohol-use behaviors among heterosexual and sexual minority adolescents: intersections with sex, age, and race/ethnicity. Am J Public Health. Feb. 2014;104(2):295-303. [pmid: 24328614].
96 Laska MN, VanKim NA, Erickson DJ, et al. Disparities in Weight and Weight Behaviors by Sexual Orientation in College Students. Am J Public Health. Jan. 2015;105(1):111-21. [pmid: 25393177].
97 Bostwick WB, Boyd CJ, Hughes TL, et al. Dimensions of sexual orientation and the prevalence of mood and anxiety disorders in the United States. Am J Public Health. Mar. 2010;100(3):468-75. [pmid: 19696380].
98 Russell ST, Joyner K. Adolescent Sexual Orientation and Suicide Risk: Evidence From a National Study. Am J Public Health. 2001;91(8):1276-81. [pmid: 11499118].
99 Reisner SL, Vetters R, Leclerc M, et al. Mental Health of Transgender Youth in Care at an Adolescent Urban Community Health Center: A Matched Retrospective Cohort Study. The Journal of adolescent health : official publication of the Society for Adolescent Medicine. 2015. Jan. 7. [pmid: 25577670].
100 Almazan EP, Roettger ME, Acosta PS. Measures of Sexual Minority Status and Suicide Risk among Young Adults in the United States. Arch Suicide Res. 2014;18(3):274-81. [pmid: 24611686].
101 Mereish EH, Bradford JB. Intersecting identities and substance use problems: sexual orientation, gender, race, and lifetime substance use problems. J Stud Alcohol Drugs. Jan. 2014;75(1):179-88. [pmid: 24411810].
102 Bowleg L. “Once You've Blended the Cake, You Can't Take the Parts Back to the Main Ingredients”: Black Gay and Bisexual Men's Descriptions and Experiences of Intersectionality. Sex Roles. 2013. 06. 01. 2013;68(11-12):754-67.
103 Bowleg L, Huang J, Brooks K, et al. Triple jeopardy and beyond: multiple minority stress and resilience among black lesbians. J Lesbian Stud. 2003;7(4):87-108. [pmid: 24831386].
104 Boehmer U, Cooley TP, Clark MA. Cancer and men who have sex with men: a systematic review. Lancet Oncol. Dec. 2012;13(12):e545-53. [pmid: 23182195].
105 Austin SB, Pazaris MJ, Nichols LP, et al. An examination of sexual orientation group patterns in mammographic and colorectal screening in a cohort of U.S. women. Cancer Causes Control. Mar. 2013;24(3):539-47. [pmid: 22729931].
106 Diamant AL, Wold C, Spritzer K, et al. Health behaviors, health status, and access to and use of health care: a population-based study of lesbian, bisexual, and heterosexual women. Arch Fam Med. Nov-Dec. 2000;9(10):1043-51. [pmid: 11115206].
107 Blosnich JR, Farmer GW, Lee JG, et al. Health inequalities among sexual minority adults: evidence from ten U.S. states, 2010. Am J Prev Med. Apr. 2014;46(4):337-49. [pmid: 24650836].
108 Farmer GW, Jabson JM, Bucholz KK, et al. A population-based study of cardiovascular disease risk in sexual-minority women. Am J Public Health. Oct. 2013;103(10):1845-50. [pmid: 23948018].
109 Hart D. Toward better care for lesbian, gay, bisexual and transgender patients. Minn Med. Aug. 2013;96(8):42-5. [pmid: 24490430].
110 McGarry KA, Clarke JG, Cyr MG, et al. Evaluating a lesbian and gay health care curriculum. Teach Learn Med. 2002;14(4):244-8. [pmid: 12395487].
111 Higa D, Crepaz N, Marshall K, et al. A Systematic Review to Identify Challenges of Demonstrating Efficacy of HIV Behavioral Interventions for Gay, Bisexual, and Other Men Who Have Sex with Men (MSM). AIDS and Behavior. 2013. 05. 01. 2013;17(4):1231-44. [pmid: 23397183].
112 Kegeles SM, Hays RB, Coates TJ. The Mpowerment Project: a community-level HIV prevention intervention for young gay men. Am J Public Health. 1996;86(8):1129-36. [pmid: 8712273].
113 Kelly JA, St Lawrence JS, Stevenson LY, et al. Community AIDS/HIV risk reduction: the effects of endorsements by popular people in three cities. Am J Public Health. 1992;82(11):1483-9. [pmid: 1443297].
114 Dilley JW, Woods WJ, Sabatino J, et al. Changing sexual behavior among gay male repeat testers for HIV: a randomized, controlled trial of a single-session intervention. J Acquir Immune Defic Syndr. Jun. 1. 2002;30(2):177-86. [pmid: 12045680].
115 Koblin B, Chesney M, Coates T, et al. Effects of a behavioural intervention to reduce acquisition of HIV infection among men who have sex with men: the EXPLORE randomised controlled study. Lancet. Jul. 3-9. 2004;364(9428):41-50. [pmid: 15234855].
116 Wolitski RJ, Gomez CA, Parsons JT. Effects of a peer-led behavioral intervention to reduce HIV transmission and promote serostatus disclosure among HIV-seropositive gay and bisexual men. Aids. Apr. Suppl 1. 2005;19:S99-109. [pmid: 15838199].
117 Choi KH, Lew S, Vittinghoff E, et al. The efficacy of brief group counseling in HIV risk reduction among homosexual Asian and Pacific Islander men. Aids. Jan. 1996;10(1):81-7. [pmid: 8924256].
118 McKirnan DJ, Tolou-Shams M, Courtenay-Quirk C. The Treatment Advocacy Program: a randomized controlled trial of a peer-led safer sex intervention for HIV-infected men who have sex with men. J Consult Clin Psychol. Dec. 2010;78(6):952-63. [pmid: 20919760].
119 Wilton L, Herbst JH, Coury-Doniger P, et al. Efficacy of an HIV/STI prevention intervention for black men who have sex with men: findings from the Many Men, Many Voices (3MV) project. Aids Behav. Jun. 2009;13(3):532-44. [pmid: 19267264].
120 Bachmann LH, Grimley DM, Gao H, et al. Impact of a computer-assisted, provider-delivered intervention on sexual risk behaviors in HIV-positive men who have sex with men (MSM) in a primary care setting. AIDS Educ Prev. Apr. 2013;25(2):87-101. [pmid: 23514077].
121 Patel P, Bush T, Mayer K, et al. Routine brief risk-reduction counseling with biannual STD testing reduces STD incidence among HIV-infected men who have sex with men in care. Sex Transm Dis. Jun. 2012;39(6):470-4. [pmid: 22592834].
122 Blas MM, Alva IE, Carcamo CP, et al. Effect of an online video-based intervention to increase HIV testing in men who have sex with men in Peru. PLoS ONE. 2010;5(5):e10448. [pmid: 20454667].
123 Peck JA, Reback CJ, Yang X, et al. Sustained reductions in drug use and depression symptoms from treatment for drug abuse in methamphetamine-dependent gay and bisexual men. J Urban Health. Mar. 2005;82(1 Suppl 1):i100-8. [pmid: 15738315].
124 Shoptaw S, Reback CJ, Peck JA, et al. Behavioral treatment approaches for methamphetamine dependence and HIV-related sexual risk behaviors among urban gay and bisexual men. Drug Alcohol Depend. May. 9. 2005;78(2):125-34. [pmid: 15845315].
125 Fobair P, Koopman C, DiMiceli S, et al. Psychosocial intervention for lesbians with primary breast cancer. Psychooncology. Sep-Oct. 2002;11(5):427-38. [pmid: 12228876].
126 Bowen DJ, Powers D, Greenlee H. Effects of breast cancer risk counseling for sexual minority women. Health Care Women Int. Jan. 2006;27(1):59-74. [pmid: 16338740].
127 Marrazzo JM, Thomas KK, Ringwood K. A behavioural intervention to reduce persistence of bacterial vaginosis among women who report sex with women: results of a randomised trial. Sex Transm Infect. Aug. 2011;87(5):399-405. [pmid: 21653935].
128 Beagan BL. Teaching social and cultural awareness to medical students: “it's all very nice to talk about it in theory, but ultimately it makes no difference”. Acad Med. Jun. 2003;78(6):605-14. [pmid: 12805041].
129 Kelley L, Chou CL, Dibble SL, et al. A critical intervention in lesbian, gay, bisexual, and transgender health: knowledge and attitude outcomes among second-year medical students. Teach Learn Med. Jul-Sep. 2008;20(3):248-53. [pmid: 18615300].
130 Marshal MP, Sucato G, Stepp SD, et al. Substance use and mental health disparities among sexual minority girls: results from the Pittsburgh girls study. J Pediatr Adolesc Gynecol. Feb. 2012;25(1):15-8. [pmid: 22051788].
131 Jessup MA, Dibble SL. Unmet mental health and substance abuse treatment needs of sexual minority elders. Journal of Homosexuality. 2012;59(5):656-74. [pmid: 22587357].
132 Lehavot K, Simoni JM. The impact of minority stress on mental health and substance use among sexual minority women. J Consult Clin Psychol. Apr. 2011;79(2):159-70. [pmid: 21341888].
133 Beyrer C, Baral SD, van Griensven F, et al. Global epidemiology of HIV infection in men who have sex with men. Lancet. Jul. 28. 2012;380(9839):367-77. [pmid: 22819660].
134 Rounds KE, McGrath BB, Walsh E. Perspectives on provider behaviors: a qualitative study of sexual and gender minorities regarding quality of care. Contemp Nurse. Apr. 2013;44(1):99-110. [pmid: 23721392].
135 Grant JM, Mottet L, Tanis JE, et al. Injustice at every turn: A report of the National Transgender Discrimination Survey. National Center for Transgender Equality. 2011.
136 Marrazzo JM, Koutsky LA, Kiviat NB, et al. Papanicolaou test screening and prevalence of genital human papillomavirus among women who have sex with women. Am J Public Health. Jun. 2001;91(6):947-52. [pmid: 11392939].
137 Seaver MR, Freund KM, Wright LM, et al. Healthcare preferences among lesbians: a focus group analysis. J Womens Health (Larchmt). Mar. 2008;17(2):215-25. [pmid: 18321173].
138 Saulnier CF. Deciding who to see: lesbians discuss their preferences in health and mental health care providers. Soc Work. Oct. 2002;47(4):355-65. [pmid: 12450007].
139 Petroll AE, Mosack KE. Physician awareness of sexual orientation and preventive health recommendations to men who have sex with men. Sex Transm Dis. Jan. 2011;38(1):63-7. [pmid: 20706178].
140 Steele LS, Tinmouth JM, Lu A. Regular health care use by lesbians: a path analysis of predictive factors. Fam Pract. Dec. 2006;23(6):631-6. [pmid: 16799166].
141 Tracy JK, Lydecker AD, Ireland L. Barriers to cervical cancer screening among lesbians. J Womens Health (Larchmt). Feb. 2010;19(2):229-37. [pmid: 20095905].
142 Tesar CM, Rovi SL. Survey of curriculum on homosexuality/bisexuality in departments of family medicine. Fam Med. Apr. 1998;30(4):283-7. [pmid: 9568499].
143 Obedin-Maliver J, Goldsmith ES, Stewart L, et al. Lesbian, gay, bisexual, and transgender-related content in undergraduate medical education. Jama. Sep. 7. 2011;306(9):971-7. [pmid: 21900137].
144 Committee on Adolescence. Office-Based Care for Lesbian, Gay, Bisexual, Transgender, and Questioning Youth. Pediatrics. July. 1. 2013;132(1):198-203. [pmid: 23796746].
145 Olson J, Forbes C, Belzer M. Management of the transgender adolescent. Arch Pediatr Adolesc Med. Feb. 2011;165(2):171-6. [pmid: 21300658].
146 Haldeman D. Guidelines for psychological practice with lesbian, gay, and bisexual clients. Am Psychol. 2012;67(1):10-42. [pmid: 21875169].
147 McNair RP, Hegarty K. Guidelines for the primary care of lesbian, gay, and bisexual people: a systematic review. The Annals of Family Medicine. 2010;8(6):533-41. [pmid: 21060124].
148 Makadon HJ. Improving health care for the lesbian and gay communities. N Engl J Med. Mar. 2. 2006;354(9):895-7. [pmid: 16510743].
149 Khan A, Plummer D, Hussain R, et al. Does physician bias affect the quality of care they deliver? Evidence in the care of sexually transmitted infections. Sex Transm Infect. Apr. 2008;84(2):150-1. [pmid: 17974595].
150 Makadon HJ. The Fenway guide to lesbian, gay, bisexual, and transgender health. ACP Press. 2008.
151 Safren SA, O'Cleirigh CM, Skeer M, et al. Project enhance: a randomized controlled trial of an individualized HIV prevention intervention for HIV-infected men who have sex with men conducted in a primary care setting. Health Psychol. Feb. 2013;32(2):171-9. [pmid: 22746262].
152 Gore-Felton C, Rotheram-Borus MJ, Weinhardt LS, et al. The Healthy Living Project: an individually tailored, multidimensional intervention for HIV-infected persons. AIDS Educ Prev. Feb. 2005;17(1 Suppl A):21-39. [pmid: 15843115].
153 Institute of Medicine. Access to health care in America: a model for monitoring access. Washington, DC. National Academy Press. 1993.
154 Cooper LA, Hill MN, Powe NR. Designing and evaluating interventions to eliminate racial and ethnic disparities in health care. J Gen Intern Med. Jun. 2002;17(6):477-86. [pmid: 12133164].
155 Metzl JM, Hansen H. Structural competency: theorizing a new medical engagement with stigma and inequality. Soc Sci Med. Feb. 2014;103:126-33. [pmid: 24507917].
156 Paradies Y. A systematic review of empirical research on self-reported racism and health. Int J Epidemiol. Aug. 2006;35(4):888-901. [pmid: 16585055].
157 Williams DR, Mohammed SA. Discrimination and racial disparities in health: evidence and needed research. J Behav Med. Feb. 2009;32(1):20-47. [pmid: 19030981].
158 Weech-Maldonado R, Hall A, Bryant T, et al. The relationship between perceived discrimination and patient experiences with health care. Medical Care. Sep. 2012;50(9 Suppl 2):S62-8. [pmid: 22895233].
159 Paradies Y, Truong M, Priest N. A systematic review of the extent and measurement of healthcare provider racism. J Gen Intern Med. Feb. 2014;29(2):364-87. [pmid: 24002624].
160 Thorburn S, De Marco M. Insurance-based discrimination during prenatal care, labor, and delivery: perceptions of Oregon mothers. Matern Child Health J. Nov. 2010;14(6):875-85. [pmid: 19882241].
161 Jones CP. Levels of racism: a theoretic framework and a gardener's tale. Am J Public Health. Aug. 2000;90(8):1212-5. [pmid: 10936998].
162 Institute of Medicine. Unequal treatment: confronting racial and ethnic disparities in health care. Washington, DC. National Academy Press. 2002.
163 Lillie-Blanton M, Hoffman C. The role of health insurance coverage in reducing racial/ethnic disparities in health care. Health Affairs. Mar-Apr. 2005;24(2):398-408. [pmid: 15757923].
164 Kaiser Family Foundation. Facts on health reform. Available at: www.kff.org. July 7, 2011.
165 Han X, C K, Pintor JK, Alarcon-Espinoza G, Simon AB. Reports of insurance-based discrimination in health care and its association with access to care. Forthcoming. AJPH.
166 Centers for Disease Control and Prevention. CDC health disparities and inequalities report—United States. 2013. Available at: www.cdc.gov/minorityhealth/CHDIReport.html. March 12, 2015.
167 Cross TL, B B, Dennis KW, Isaacs MR. Towards A Culturally Competent System of Care, Volume I. Washington, DC. Georgetown University Child Development Center, CASSP Technical Assistance Center. 1989.
168 Goode TD, Dunne MC, Bronheim S. The evidence base for cultural and linguistic competency in health care. New York. Commonwealth Fund. 2006.
169 Field C, Caetano R. The role of ethnic matching between patient and provider on the effectiveness of brief alcohol interventions with Hispanics. Alcohol Clin Exp Res. Feb. 2010;34(2):262-71. [pmid: 19951297].
170 Imel ZE, Baldwin S, Atkins DC, et al. Racial/ethnic disparities in therapist effectiveness: a conceptualization and initial study of cultural competence. J Couns Psychol. Jul. 2011;58(3):290-8. [pmid: 21534654].
171 White C, Ip S, McPheeters M, et al. Using existing systematic reviews to replace de novo processes in conducting Comparative Effectiveness Reviews. Rockville, MD. Agency for Healthcare Research and Quality. 2009. http://effectivehealthcare.ahrq.gov/repFiles/methodsguide/systematicreviewsreplacedenovo.pdf.
172 Truong M, Paradies Y, Priest N. Interventions to improve cultural competency in healthcare: a systematic review of reviews. BMC Health Serv Res. 2014;14:99. [pmid: 24589335].
173 Aragones A, Schwartz MD, Shah NR, et al. A randomized controlled trial of a multilevel intervention to increase colorectal cancer screening among Latino immigrants in a primary care facility. J Gen Intern Med. Jun. 2010;25(6):564-7. [pmid: 20213208].
174 Penner LA, Gaertner S, Dovidio JF, et al. A social psychological approach to improving the outcomes of racially discordant medical interactions. J Gen Intern Med. Sep. 2013;28(9):1143-9. [pmid: 23377843].
175 Cooper LA, Ghods Dinoso BK, Ford DE, et al. Comparative effectiveness of standard versus patient-centered collaborative care interventions for depression among African Americans in primary care settings: the BRIDGE Study. Health Serv Res. Feb. 2013;48(1):150-74. [pmid: 22716199].
176 Alegria M, Carson N, Flores M, et al. Activation, self-management, engagement, and retention in behavioral health care: a randomized clinical trial of the DECIDE intervention. JAMA Psychiatry. May. 2014;71(5):557-65. [pmid: 24647680].
177 Alegria M, Polo A, Gao S, et al. Evaluation of a patient activation and empowerment intervention in mental health care. Medical Care. Mar. 2008;46(3):247-56. [pmid: 18388839].
178 Michalopoulou G, Falzarano P, Arfken C, et al. Implementing Ask Me 3 to improve African American patient satisfaction and perceptions of physician cultural competency. J Cult Divers. 2010;17(2):62-7. [pmid: 20586368].
179 Breitkopf CR, Dawson L, Grady JJ, et al. Intervention to improve follow-up for abnormal Papanicolaou tests: a randomized clinical trial. Health Psychol. Apr. 2014;33(4):307-16. [pmid: 23730719].
180 Burrow-Sanchez JJ, Wrona M. Comparing culturally accommodated versus standard group CBT for Latino adolescents with substance use disorders: a pilot study. Cultur Divers Ethni Minor Psychol. Oct. 2012;18(4):373-83. [pmid: 22866693].
181 Calsyn DA, Burlew AK, Hatch-Maillette MA, et al. Real men are safe-culturally adapted: utilizing the Delphi process to revise real men are safe for an ethnically diverse group of men in substance abuse treatment. AIDS Educ Prev. Apr. 2012;24(2):117-31. [pmid: 22468973].
182 D'Eramo Melkus G, Chyun D, Vorderstrasse A, et al. The effect of a diabetes education, coping skills training, and care intervention on physiological and psychosocial outcomes in black women with type 2 diabetes. Biol Res Nurs. Jul. 2010;12(1):7-19. [pmid: 20484058].
183 Kim SS, Kim SH, Fang H, et al. A culturally adapted smoking cessation intervention for Korean Americans: a mediating effect of perceived family norm toward quitting. Journal of Immigrant and Minority Health. 2015;17(4):1120-9. [pmid: 24878686].
184 Kohn LP, Oden T, Munoz RF, et al. Adapted cognitive behavioral group therapy for depressed low-income African American women. Community Ment Health J. Dec. 2002;38(6):497-504. [pmid: 12474937].
185 Lee CS, Lopez SR, Colby SM, et al. Culturally adapted motivational interviewing for Latino heavy drinkers: results from a randomized clinical trial. J Ethn Subst Abuse. 2013;12(4):356-73. [pmid: 24215227].
186 Marsiglia FF, Bermudez-Parsai M, Coonrod D. Familias Sanas: an intervention designed to increase rates of postpartum visits among Latinas. J Health Care Poor Underserved. Aug. 2010;21(3 Suppl):119-31. [pmid: 20675950].
187 Pan D, Huey SJ Jr., Hernandez D. Culturally adapted versus standard exposure treatment for phobic Asian Americans: Treatment efficacy, moderators, and predictors. Cultur Divers Ethni Minor Psychol. Jan. 2011;17(1):11-22. [pmid: 21341893].
188 Calsyn DA, Burlew AK, Hatch-Maillette MA, et al. An HIV prevention intervention for ethnically diverse men in substance abuse treatment: pilot study findings. Am J Public Health. May. 2013;103(5):896-902. [pmid: 23488494].
189 Ell K, Katon W, Xie B, et al. One-year postcollaborative depression care trial outcomes among predominantly Hispanic diabetes safety net patients. Gen Hosp Psychiatry. Sep-Oct. 2011;33(5):436-42. [pmid: 21774987].
190 Le H, Wong S, Iftikar T, et al. Characterization of factors affecting attainment of glycemic control in Asian Americans with diabetes in a culturally specific program. Diabetes Educ. Jul-Aug. 2013;39(4):468-77. [pmid: 23771841].
191 Smith SS, Rouse LM, Caskey M, et al. Culturally tailored smoking cessation for adult American Indian smokers: A clinical trial. The Counseling Psychologist. 2014;42(6):852-86. [pmid: 26973352].
192 Beach MC, Price EG, Gary TL, et al. Cultural competence: a systematic review of health care provider educational interventions. Medical Care. Apr. 2005;43(4):356-73. [pmid: 15778639].
193 Bhui K, Warfa N, Edonya P, et al. Cultural competence in mental health care: a review of model evaluations. BMC Health Serv Res. 2007;7:15. [pmid: 17266765].
194 Chipps JA, Simpson B, Brysiewicz P. The effectiveness of cultural-competence training for health professionals in community-based rehabilitation: a systematic review of literature. Worldviews Evid Based Nurs. 2008;5(2):85-94. [pmid: 18559021].
195 Henderson S, Kendall E, See L. The effectiveness of culturally appropriate interventions to manage or prevent chronic disease in culturally and linguistically diverse communities: a systematic literature review. Health Soc Care Community. May. 2011;19(3):225-49. [pmid: 21208326].
196 Lie DA, Lee-Rey E, Gomez A, et al. Does cultural competency training of health professionals improve patient outcomes? A systematic review and proposed algorithm for future research. J Gen Intern Med. Mar. 2011;26(3):317-25. [pmid: 20953728].
197 Downing R, Kowal E, Paradies Y. Indigenous cultural training for health workers in Australia. Int J Qual Health Care. Jun. 2011;23(3):247-57. [pmid: 21467076].
198 Kokko R. Future nurses' cultural competencies: what are their learning experiences during exchange and studies abroad? A systematic literature review. J Nurs Manag. Jul. 2011;19(5):673-82. [pmid: 21749541].
199 McQuilkin D. Transcultural nursing clinical education: a systematic review of the literature since 2005 with recommendations for international immersion clinical courses: (Doctoral dissertation, University of South Carolina). 2012.
200 Pearson A, Srivastava R, Craig D, et al. Systematic review on embracing cultural diversity for developing and sustaining a healthy work environment in healthcare. International Journal of Evidence-Based Healthcare. Mar. 2007;5(1):54-91. [pmid: 21631782].
201 Anderson LM, Scrimshaw SC, Fullilove MT, et al. Culturally competent healthcare systems. A systematic review. Am J Prev Med. Apr. 2003;24(3 Suppl):68-79. [pmid: 12668199].
202 Forsetlund L, Eike MC, Vist GE. Effect of interventions to improve health care services for ethnic minority populations. Norsk epidemiologi. 2010;20(1):41-52.
203 Fisher TL, Burnet DL, Huang ES, et al. Cultural leverage: interventions using culture to narrow racial disparities in health care. Med Care Res Rev. Oct. 2007;64(5 Suppl):243S-82S. [pmid: 17881628].
204 Kardong-Edgren S, Cason CL, Brennan AM, et al. Cultural competency of graduating BSN nursing students. Nurs Educ Perspect. Sep-Oct. 2010;31(5):278-85. [pmid: 21086864].
205 Sequist TD, Fitzmaurice GM, Marshall R, et al. Cultural competency training and performance reports to improve diabetes care for black patients: a cluster randomized, controlled trial. Ann Intern Med. Jan. 5. 2010;152(1):40-6. [pmid: 20048271].
206 Harmsen H, Bernsen R, Meeuwesen L, et al. The effect of educational intervention on intercultural communication: results of a randomised controlled trial. Br J Gen Pract. May. 2005;55(514):343-50. [pmid: 15904552].
207 Thom DH, Tirado MD, Woon TL, et al. Development and evaluation of a cultural competency training curriculum. BMC Med Educ. 2006;6:38. [pmid: 16872504].
208 Wade P BB. Culture sensitivity training and counselor's race: effects on black female clients' perceptions and attrition. J Couns Psychol. 1991;38(1):9-15.
209 Jackson J, Kennedy BL, Mandel D, et al. Derivation and pilot assessment of a health promotion program for Mandarin-speaking Chinese older adults. Int J Aging Hum Dev. 2000;50(2):127-49. [pmid: 10791612].
210 Sheppard VB, Williams KP, Harrison TM, et al. Development of decision-support intervention for Black women with breast cancer. Psychooncology. Jan. 2010;19(1):62-70. [pmid: 19267384].
211 Attridge M, Creamer J, Ramsden M, Cannings-John R, Hawthorne K. Culturally appropriate health education for people in ethnic minority groups with type 2 diabetes mellitus. 2014.
212 Skelly AH, C J, Leeman J, Soward A, Burns D. Controlled trial of nursing interventions to improve health outcomes of older African American women with type 2 diabetes. Nurs Res. 2009;58(6):410-8. [pmid: 19851122].
213 Ratzliff ADH, Ni K, Chan Y-F, et al. A collaborative care approach to depression treatment for Asian Americans. Psychiatr Serv. May. 1. 2013;64(5):487-90. [pmid: 23632577].
214 Levine DM, Bone LR, Hill MN, et al. The effectiveness of a community/academic health center partnership in decreasing the level of blood pressure in an urban African-American population. Ethn Dis. 2003;13(3):354-61. [pmid: 12894960].
215 Fisher EB, Strunk RC, Highstein GR, et al. A randomized controlled evaluation of the effect of community health workers on hospitalization for asthma: the asthma coach. [Erratum appears in Arch Pediatr Adolesc Med. 2009 May;163(5):493]. Arch Pediatr Adolesc Med. Mar. 2009;163(3):225-32. [pmid: 19255389].
216 Grote NK, Swartz HA, Geibel SL, et al. A randomized controlled trial of culturally relevant, brief interpersonal psychotherapy for perinatal depression. Psychiatr Serv. Mar. 2009;60(3):313-21. [pmid: 19252043].
217 West DS, Greene P, Pulley L, et al. Stepped-care, community clinic interventions to promote mammography use among low-income rural African American women. Health Educ Behav. Aug. 2004;31(4 Suppl):29S-44S. [pmid: 15296690].
218 Ukoli FA, Patel K, Hargreaves M, et al. A tailored prostate cancer education intervention for low-income African Americans: impact on knowledge and screening. J Health Care Poor Underserved. Feb. 2013;24(1):311-31. [pmid: 23377736].
219 Hart A, Hall V, Henwood F. Helping health and social care professionals to develop an ‘inequalities imagination’: a model for use in education and practice. J Adv Nurs. Mar. 2003;41(5):480-9. [pmid: 12603573].
220 Chang Es, Simon M, Dong X. Integrating cultural humility into health care professional education and training. Adv Health Sci Educ Theory Pract. May. 2012;17(2):269-78. [pmid: 21161680].
221 Lewis A. Disability disparities: a beginning model. Disabil Rehabil. 2009;31(14):1136-43. [pmid: 19802930].
222 Garrett PW, Dickson HG, Whelan AK, et al. What do non-English-speaking patients value in acute care? Cultural competency from the patient's perspective: a qualitative study. Ethnicity & Health. Nov. 1. 2008;13(5):479-96. [pmid: 18850371].
223 Schim SM, Doorenbos A, Benkert R, et al. Culturally congruent care: putting the puzzle together. J Transcult Nurs. Apr. 2007;18(2):103-10. [pmid: 17416711].
224 Rust G, Kondwani K, Martinez R, et al. A crash-course in cultural competence. Ethn Dis. 2006;16(2 Suppl 3):S3-29-36. [pmid: 16774021].
225 Kleinman A, Benson P. Anthropology in the clinic: the problem of cultural competency and how to fix it. PLoS Med. Oct. 2006;3(10):e294. [pmid: 17076546].
226 McNeil JI. A model for cultural competency in the HIV management of African American patients. Journal of the National Medical Association. Feb. 2003;95(2 Suppl 2):3S-7S. [pmid: 12656426].
227 Chong N. The Latino Patient: A cultural guide for health care providers. Boston, MA. Intercultural Press. 2002.
228 Purnell L. The Purnell Model for Cultural Competence. J Transcult Nurs. Jul. 2002;13(3):193-6. discussion 200-1. [pmid: 12113149].
229 Levin S, Like R, Gottlieb J. ETHNIC: a framework for culturally competent clinical practice. In Appendix: useful clinical interviewing mnemonics. Patient Care. 2000;34(9):188-1889.
230 Brach C, Fraser I. Can cultural competency reduce racial and ethnic health disparities? A review and conceptual model. Med Care Res Rev. Suppl 1. 2000;57:181-217. [pmid: 11092163].
231 Campinha-Bacote J. A model and instrument for addressing cultural competence in health care. J Nurs Educ. May. 1999;38(5):203-7. [pmid: 10438093].
232 Lister P. A taxonomy for developing cultural competence. Nurse Educ Today. May. 1999;19(4):313-8. [pmid: 10595067].
233 Papadopoulos I, Tilki M, Taylor G. Transcultural Care: a guide for health care professionals. Salisburyr. Quay Books. 1998.
234 Narayanasamy A. Transcultural mental health nursing. 2: Race, ethnicity and culture. Br J Nurs. Jun. 10-23. 1999;8(11):741-4. [pmid: 10624212].
235 Culhane-Pera KA, Reif C, Egli E, et al. A curriculum for multicultural education in family medicine. Family Medicine. Nov-Dec. 1997;29(10):719-23. [pmid: 9397362].
236 Giger J, Davidhizar R. Transcultural nursing: Assessment and intervention. St. Louis. C.V. Mostby Year Book. 1995.
237 Stuart M, Lieberman J. The fifteen minute hour: applied psychotherapy for the primary care physician. 2nd ed. Westport, Conn. Praeger. 1993.
238 Borkan JM, Neher JO. A developmental model of ethnosensitivity in family practice training. Family Medicine. Mar-Apr. 1991;23(3):212-7. [pmid: 2016014].
239 Kittler PG, Sucher KP. Diet counseling in a multicultural society. Diabetes Educ. Mar-Apr. 1990;16(2):127-34. [pmid: 2311505].
240 Cross T, Bazron B, Dennis K, et al. Toward a culturally competent system of care, volume 1: a monograph on effective services for minority children who are severely emotionally disturbed. Washington, DC. Georgetown University Child Development Center, CASSP Technical Assistance Center. 1989.
241 Leininger MM. Leininger's theory of nursing: cultural care diversity and universality. Nurs Sci Q. Nov. 1988;1(4):152-60. [pmid: 3205480].
242 Berlin E, Fowkes WJ. A teaching framework for cross-cultural competence: application in family practice. West J Med. 1983;139:934-8. [pmid: 6666112].
243 Williamson M, Harrison L. Providing culturally appropriate care: a literature review. Int J Nurs Stud. Jun. 2010;47(6):761-9. [pmid: 20138275].
244 Iezzoni L. Targeting health care improvement for persons with disabilities. Int J Qual Health Care. 2003;15(4):279-81. [pmid: 12930042].
245 Joint Commission. Advancing Effective Communication, Cultural Competence, and Patient- and Family-Centered Care for the Lesbian, Gay, Bisexual, and Transgender (LGBT) Community: A Field Guide. Oak Brook, IL. LGBTFieldGuide.pdf. Oct. 2011. http://www.jointcommission.org/assets/1/18/LGBTFieldGuide.pdf.
246 Fortiere JP, Brach C, Bishop D. Setting the agenda for research on cultural competence in health care. US Department of Health and Human Services Office of Minority Health and Agency for Healthcare Research and Quality. 2004.
247 Weech-Maldonado R, Carle A, Weidmer B, et al. The Consumer Assessment of Healthcare Providers and Systems (CAHPS®) Cultural Competence (CC) Item Set. Medical care. 2012;50(9 0 2):S22-31. [pmid: 22895226].
248 Chin MH, Clarke AR, Nocon RS, et al. A roadmap and best practices for organizations to reduce racial and ethnic disparities in health care. J Gen Intern Med. 2012;27(8):992-1000. [pmid: 22798211].
249 Price EG, Beach MC, Gary TL, et al. A systematic review of the methodological rigor of studies evaluating cultural competence training of health professionals. Acad Med. Jun. 2005;80(6):578-86. [pmid: 15917363].
250 Smedley BD, Stith AY, Nelson AR, editors. Unequal treatment: confronting racial and ethnic disparities in health care. Washington, D.C. National Academies Press. 2002. Care CoUaERaEDiH, ed. Board on Health Sciences Policy.
251 Clarke SP, Davis BL, Nailon RE. Racial segregation and differential outcomes in hospital care. West J Nurs Res. Oct. 2007;29(6):739-57. [pmid: 17630385].
252 Epstein AM. Health care in America--still too separate, not yet equal. New England Journal of Medicine. Aug. 5. 2004;351(6):603-5. [pmid: 15295055].
253 White K, Haas JS, Williams DR. Elucidating the role of place in health care disparities: the example of racial/ethnic residential segregation. Health Serv Res. Jun. 2012;47(3 Pt 2):1278-99. [pmid: 22515933].
254 Varkey AB, Manwell LB, Williams ES, et al. Separate and unequal: clinics where minority and nonminority patients receive primary care. Arch Intern Med. Feb. 9. 2009;169(3):243-50. [pmid: 19204215].
255 Jackson KF, Hodge DR. Native American youth and culturally sensitive interventions: A systematic review. Research on Social Work Practice. 2010;20(3):1-11.
256 Ranji U, Beamesderfer A, Kates J, et al. Health and access to care and coverage for lesbian, gay, bisexual, and transgender individuals in the US. The Henry J. Kaiser Family Foundation. December. 2014.
257 Betancourt JR, Green AR. Commentary: linking cultural competence training to improved health outcomes: perspectives from the field. Acad Med. Apr. 2010;85(4):583-5. [pmid: 20354370].
258 Meyer IH. Prejudice, social stress, and mental health in lesbian, gay, and bisexual populations: conceptual issues and research evidence. Psychol Bull. Sep. 2003;129(5):674-97. [pmid: 12956539].
259 van Ryn M, Burgess DJ, Dovido J, et al. The impact of racism on provider cognition, behavior, and clinical decision-making. Du Bois Review. 2011;8(1):199-218. [pmid: 24761152].
260 Mays VM, Cochran SD, Barnes NW. Race, race-based discrimination, and health outcomes among African Americans. Annu Rev Psychol. 2007;58:201-25. [pmid: 16953796].
261 Van Houtven CH, Voils CI, Oddone EZ, et al. Perceived discrimination and reported delay of pharmacy prescriptions and medical tests. J Gen Intern Med. Jul. 2005;20(7):578-83. [pmid: 16050850].
262 Beach MC, Gary TL, Price EG, et al. Improving health care quality for racial/ethnic minorities: a systematic review of the best evidence regarding provider and organization interventions. BMC Public Health. 2006;6:104. [pmid: 16635262].
263 Kao H-FS, Hsu M-T, Clark L. Conceptualizing and critiquing culture in health research. J Transcult Nurs. Oct. 2004;15(4):269-77. [pmid: 15359059].
264 Meyers AR, Andresen EM. Enabling our instruments: accomodation, universal desgin, and access to participation in research. Arch Phys Med Rehabil. 2000;81(12 Suppl 2):S5-9. [pmid: 11128904].
265 Chao GT, Moon H. The cultural mosaic: a metatheory for understanding the complexity of culture. J Appl Psychol. Nov. 2005;90(6):1128-40. [pmid: 16316269].
266 Drevdahl DJ, Canales MK, Dorcy KS. Of goldfish tanks and moonlight tricks: can cultural competency ameliorate health disparities?. ANS Adv Nurs Sci. Jan-Mar. 2008;31(1):13-27. [pmid: 20531266].