# Peer Reviewers

Prior to publication of the final evidence report, EPCs sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report do not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

- Harvey Makaton, M.D.
  Director
  National LGBT Health Education Center
  Harvard Medical School
  Boston, MA
- Suzanne McDermott, Ph.D.
  Professor of Epidemiology and Biostatistics
  Arnold School of Public Health
  University of South Carolina
  Columbia, SC
- Yin Paradies, Ph.D.
  Professor
  Deakin University
  Melbourne, Victoria, Australia
- Jae Sevelius, Ph.D.
  Assistant Professor
  University of California, San Francisco
  San Francisco, CA