# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who provided input to this report follows:

- Marshall Chin, M.D., M.P.H.
  Associate Professor of Medicine
  University of Chicago
  Chicago, IL
- Rashida Dorsey, Ph.D., M.P.H.^*^
  * TEP members who also provided peer reviews.
  Director
  Division of Policy and Data
  Office of Minority Health
  U.S. Department of Health and Human Services
  Rockville, MD
- Lex Frieden, M.A.
  Director
  Independent Living Research Utilization Program
  TIRR Memorial Hermann Hospital
  Houston, TX
- Robert C. Like, M.D., M.S.^*^
  Professor and Director
  Center for Healthy Families and Cultural Diversity
  Department of Family Medicine and Community Health
  Rutgers Robert Wood Johnson Medical School
  New Brunswick, NJ
- Amanda Reichard, Ph.D., M.S.^*^
  Research Assistant Professor
  Institute on Disability
  University of New Hampshire
  Durham, NH
- Tumaini Rucker Coker, M.D., M.B.A.
  Assistant Professor of Pediatrics
  UCLA School of Medicine
  UCLA Children's Health Center
  Los Angeles, CA
- Somnath Saha, M.D., M.P.H., Ph.D.
  Professor of Medicine
  Oregon Health & Science University
  SOM-DOM General Internal Medicine
  Portland, OR