# Key Informants

In designing the study questions, the EPC consulted several Key Informants who represent the end-users of research. The EPC sought the Key Informant input on the priority areas for research and synthesis. Key Informants are not involved in the analysis of the evidence or the writing of the report. Therefore, in the end, study questions, design, methodological approaches, and/or conclusions do not necessarily represent the views of individual Key Informants.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any conflicts of interest.

The list of Key Informants who provided input into this report follows:

- Judy Bradford, Ph.D.
  Director
  Center for Multicultural
  Mental Health Research
  Cambridge Health Alliance and Harvard Medical School
  Boston, MA
- Lex Frieden, M.A.
  Director
  Independent Living Research Utilization Program
  TIRR Memorial Hermann Hospital
  Houston, TX
- Willi Horner-Johnson, Ph.D.
  Assistant Professor
  Public Health and Preventive Medicine
  Oregon Health & Science University
  Portland, OR
- Robert C. Like, M.D., M.S.
  Professor and Director
  Center for Healthy Families and Cultural Diversity
  Department of Family Medicine and Community Health
  Rutgers Robert Wood Johnson Medical School
  New Brunswick, NJ
- Amanda Reichard, Ph.D., M.S.
  Research Assistant Professor
  Institute on Disability
  University of New Hampshire
  Durham, NH
- Tumaini Rucker Coker, M.D., M.B.A.
  Assistant Professor of Pediatrics
  UCLA School of Medicine
  UCLA Children's Health Center
  Los Angeles, CA
- Somnath Saha, M.D., M.P.H., Ph.D.
  Professor of Medicine
  Oregon Health & Science University
  SOM-DOM General Internal Medicine
  Portland, OR