# Acknowledgments

We thank Jeannine Ouellette, Marilyn Eells, and Cheryl Cole-Hill for their editorial help bringing the report to completion. We also thank Cecilia Casale, Aysegul Gozu, and Tim Carey for their helpful editorial comments.