# Models and Cross-Cutting Themes

## Introduction

This report addresses cultural competence as a construct that can be applied to diverse subgroups. Each subgroup has its own culture. Elements such as alienation and prejudice are likely common to all; but other elements, such as language and physical access, may affect some groups more or differently than others. This chapter provides an overview of models that have been used to conceptualize cultural competence and culturally appropriate care in health contexts. The discussion section examines overarching themes that transcend the three populations of interest: people with disabilities; lesbian, gay, bisexual, and transgender (LGBT) people; and racial and ethnic minority groups.

## Cultural Competence Models

To help inform the review process, we undertook a review of cultural competence conceptual models. Specific methods pertinent to this review process are in Appendix A, along with the search algorithm used. We identified 857 unique English language citations from 1990 to February 2014. After excluding articles at title and abstract, full texts of 89 articles were considered as possible sources of models. After checking full text, references, and consolidating models identified, 24 models were identified for examination.

We expected the models to map with the included intervention literature in a useful way and provide an overarching framework for mapping the literature. Instead, the models connected very little with the intervention literature, and the literature was so sparse that a mapping exercise would interfere with the overarching key messages drawn from each priority population group. Here we present the models briefly for informational purposes, while drawing a few high level themes of interest.

All models but one were developed in response to racial and ethnic group concerns (the groups to which cultural competence was first applied) (Table 21). The Inequalities Imagination model intends to cover a much broader set of populations that may be disadvantaged in a formal health care system.219 The model explicitly includes people with disabilities. Because it uses broad definitions of disadvantaged people who have experienced prejudice or discrimination, the model can also be viewed as covering people from the race/ethnic and LGBT groups. Models other than the Inequalities Imagination model would include disability and LGBT groups only implicitly. The Inequalities Imagination model also goes further than the populations included in this report by explicitly naming people from impoverished situations, although there can be considerable overlap of poverty and people from any of the three priority populations.

Table 21 Cultural competence models

Model | Focus | Description | Use
Disadvantaged populations
Inequalities Imagination model Hart, 2003^219^ | Provider | 7 factors: equalities analysis, equalities awareness, equalities skill, equalities action, cultural knowledge, cultural encounter. Disadvantaged populations: Mental or physical impairment, historical prejudice and discrimination; current prejudice or discrimination, poverty | Training for providers
Models motivated by race/ethnic populations
QIAN model for cultural humility Chang, 2012^220^ | Provider | 4 principles: self-questioning and critique; bi-directional cultural immersion; mutually active-listening; flexible negotiation. Affects patient-provider dyad, and elicit support of family, health care system, and community at large | Training for providers
Disability disparities model Lewis, 2009^221^ | Patient | Includes hypothesized view of what accounts for disparities, macrolevel concepts (5 domains), and microlevel aspects. Incorporates cultural competence aspects, such as disability group's culturally driven help seeking tradition, the extent to which the provider is viewed as culturally competent, patient/provider trust, extent outcomes align with culture | Training for providers
Cultural Empowerment model Garrett, 2008^222^ | Patient | 6 domains: facilitating language (removing language barriers); negotiating family involvement; understanding patient beliefs, expectations, experiences, and constructions; being compassionate and respecting patient and human rights; negotiating a care partnership; providing systems so services and providers can be competent Empirically developed from patient views | Training for providers
3-D Puzzle Model of culturally congruent care Schim, 2007^223^ | Patient | Extends Leininger's Sunrise Model (see below) to include patients as part of the system and how the interaction of patients and providers contribute to culturally congruent care. | Training for providers
CRASH model Rust, 2006^224^ | Patient/provider | 7 elements: Importance of culture; respect; assess within-group differences, affirm the positive values behind behaviors seen as different, sensitivity, self-awareness, humility in practicing but not achieving mastery of cultural competence | Training for providers
Explanatory models approach Kleinman, 2006^225^ | Patient | 6-step mini-ethnography: ethnic identity; what is at stake; illness narrative; psychosocial stresses; influence of culture on clinical relationships; problems of cultural competency approach | Practice tool for clinical encounter
BESAFE model McNeil, 2003^226^ | Patient | 6 core elements: barriers to health care, ethics in cultural competency, sensitivity of the provider, assessment appropriate to a cultural determination, facts related to ethnocentric physiologic differences, encounters | Practice tool for clinical encounter
GREET model Chong, 2002^227^ | Patient | Specific to non-native patients: generation (how acculturated is patient), reason (for immigration), extended family, ethnic behavior, time living in U.S. | Practice tool for clinical encounter
Model for Cultural Competence Purnell, 2002^228^ | Patient/provider | Systems approach to 12 domains from person through family and community to global society. Domains: communication; overview/heritage; family roles and organization; workforce issues; bio-cultural ecology; high-risk behaviors, nutrition, pregnancy and childbearing practices; death rituals; spirituality; health care practices; health care practitioner concepts | Practice tool for clinical encounter
ETHNIC model Levin, 2000^229^ | Patient | Facilitate communication by asking questions in 6 areas of process: explanation, treatment, healers, negotiation, intervention, collaboration | Practice tool for clinical encounter
9 cultural competence techniques/ reducing disparities Brach, 2000^230^ | Patient | 9 cultural competence techniques that facilitate changes in clinician and patient behavior, which lead to provision of appropriate services, which lead to good outcomes (Model focused on provider side. Other contributors to health disparities not included) | Framework: providers and systems
Model of Cultural Competency Campinha-Bacote, 1999^231^ | Patient/provider | 5 constructs of cultural competence: cultural awareness (including self-awareness), skills, knowledge, encounters (applying knowledge and skills to specific patient care), and desire to understand cultural issues | Training for providers
Taxonomy for Culturally Competent Care Lister, 1999^232^ | Patient | Five elements: Awareness, knowledge, understanding, sensitivity, and competence | Training for providers
Model of Culturally Competent Health Care Practice Papadopoulos, 1998^233^ | Patient | 4 stages moving through cultural awareness, cultural knowledge, cultural sensitivity (where patients are considered true partners), to cultural competence | Training for providers
ACCESS model Narayanasamy, 1999^234^ | Patient | 6 domains: assessment, communication, cultural negotiation and compromise, establishing respect and rapport, sensitivity, safety | Training for providers
Cultural Competence Model Culhane-Pera, 1997^235^ | Provider/patient | 5 stages of development from no insight, through minimal emphasis, acceptance, incorporation, and integration of attention to culture in all areas of professional life | Training for providers
Transcultural Model Giger and Davidhizar, 1995^236^ | Patient | 5 domains: communication, space, social organization, time, environmental factors, and biological variations | Practice tool for clinical encounter
BATHE model Stuart, 1993^237^ | Patient | Focus on providing culturally competent environment: background, affect, trouble, handling, empathy | Practice tool for clinical encounter
Developmental Model of Ethnosensitivity Borkan, 1991^238^ | Provider | 7 stages of developmental from ethnocentric to ethnosensitive: fear, denial, superiority, minimization, relativism, empathy, integration | Training for providers
Four-step Approach to Providing Culturally Sensitive Patient Teaching Kittler, 1990^239^ | Patient/provider | Four-step process of self-evaluation, pre-interview research, in-depth interviewing, and unbiased data analysis | Practice tool for clinical encounter
Cultural competence continuum model Cross, 1989^240^ | System | System development through 6 stages: cultural destructiveness, cultural incapacity, cultural blindness, cultural precompetence, cultural competence, cultural proficiency | Training for providers
Sunrise Model Leininger, 1988^241^ | Patient | Holistic view of sociocultural and worldview factors that influence care patterns, which in turn influence well-being; incorporates nursing subsystem. Focuses on views of patient | Practice tool for clinical encounter
LEARN model Berlin, 1983^242^ | Patient | Facilitate communication regarding health belief systems: Listen, explain, acknowledge, recommend, negotiate | Practice tool for clinical encounter

The majority of models, whether created for training purposes or to provide a practice tool for clinical encounters, focused on patient factors. That is, the model describes what patients bring to the clinical encounter, often based on attributes believed to be associated with cultural groups. A much smaller set focuses more on what the provider brings to the encounter. With the provider-focused models, providers are encouraged to self-reflectively examine their own biases and habits of thought. However, the distinctions between patient-focused and provider-focused categories should not be overemphasized. All models necessarily incorporated both views and differed primarily in their degree of emphasis.

Of the provider-focused models, the Inequalities Imagination model is unique in its main focus on encouraging the provider to move beyond “politically correct” thinking and develop true empathy by imagining experiences from the perspective of the patient.219 The imagination process is explicated as a specific learning technique. First, a provider must bring to mind the experiences of others and consider how previous behaviors could be changed. The provider is further challenged to bring to light cognitive processes from the subconscious levels.

Another model is noteworthy for its development process. The Cultural Empowerment model was developed by gathering information from focus groups about the factors that non-English speaking patients view as constructing culturally competent care.222 This patient-centered process to construct a culturally competent care model is concordant with the models generated through academic expert-based or theoretically driven models.

The trend over time is that newer models are more provider-focused. They reflect developments in the conceptualization of cultural competence, particularly cultural empowerment and cultural humility, which encourage providers to consider their own place of privilege. These models emphasize that providers do not have to know everything, and patients can have expertise in their own experience and an active role in sharing information. Newer models also focus on external factors, such as structural and individual discrimination (present and historical), that priority populations face in the health care system.

Two other reviews of the cultural competence literature are notable. A 2010 review by Williamson and Harrison categorized cultural competence models related to midwifery and nursing into two groups.243 One group of models used approaches that were patient-focused, attending to the characteristics of the group itself, explaining health status using individual behaviors and beliefs. The other group focused on the larger social structure within which the patient-group lives, including the impact of colonial processes on patient/provider relationships. These frameworks concentrated on social position rather than individual beliefs and values as health determinants.

In the second paper, Saha and colleagues conducted a review of cultural competence models in order to derive a measure for provider cultural competence.75 The final measure used 20 items that mapped to six domains: concept of culture; relevance of sociocultural context; disparities in health and health care; diverse beliefs and behaviors; cross-cultural care; and patient-centered communication.

## Overview of Cross-Cutting Themes

Overall, the literature on interventions to improve cultural competence in the health care system is very sparse. Not surprisingly, the largest blocks of literature addressed provider training. However, although the cultural competence training is intended to improve quality of care and downstream health disparities, no studies included outcomes that demonstrated whether a health disparity gap had been reduced. This holds true for interventions aimed at improving provider/patient communication, or attempts to culturally tailor interventions to better meet specific priority population group's needs. Further, large segments of vulnerable or disadvantaged populations remain essentially invisible in the cultural competence literature, including children with disabilities, people who may be gender nonconforming or transgender, or numerous racial or ethnic groups including Native Americans or Alaskan Natives. This is compounded for people who are members of more than one priority population.

While many advocacy, professional, and government organizations (as well as individual researchers) have published recommendations on ways to create more culturally competent health care environments,77,244-248 peer reviewed published evidence for the effectiveness of interventions at the system level are also rare. We found only five studies, two each in disabilities38,39 and LGBT populations120,121 and one in the race/ethnic groups,173 which tested interventions aiming to integrate cultural competence into the health care system itself by intervening structurally at the point of care of patient/provider interaction using formal system documents, not a one-time training or a brochure picked up in the lobby. The strategies involved prompting clinicians to provide culturally competent care, regardless of any individual clinician's placement on a cultural competence developmental continuum. The published literature was also silent on system-level concerns such as designing welcoming environments or physically accessible spaces into conventional health care system spaces.

The challenges with the methodological rigor of the studies are pervasive across the priority populations. A 2005 review noted that the lack of rigor limited the ability to assess the impact of provider training on racial and ethnic minorities.249 We found essentially the same challenges after we extended the scope of groups covered to include disability and LGBT populations and broadened the potential range for cultural competence interventions. One of the most common reasons for excluding an article was lack of study design rigor.

### Differences Among Populations

All three priority populations, race/ethnicity, disability, and LGBT, face historical and current stigma and discrimination in society and the medical community. This fosters social distance, mistrust, differential treatment, and downstream disparities. However, cultural competence interventions need to recognize the differences in underlying constructs and social formulations used by each priority population. Interventions must also recognize within-population differences as well. Table 22 provides examples of population differences in what may be salient aspects of cultural competence.

Table 22 Examples of different aspects of cultural competence by subgroup

Aspect | Race/Ethnicity | Disability | LGBT
Physical Environment | (Not as applicable) | Access to clinic, examining table, remote access | Accessible restrooms
Social Environment | Sense of being welcomed, absence of prejudice | Sense of being welcomed, absence of prejudice | Sense of being welcomed, absence of prejudice
Cultural Mores | Talking to elder; not discussing death | (Not as applicable) | (Not as applicable)
Language | Need for translation; assuring you are understood | Need for translation (deaf community); assuring understanding | Misusing terms
Clinical | Recognizing disease presentation; assuming most probable cause of a problem | Managing a common clinical problem in the context of the disability; managing complications of the disability | Knowing what problems may be associated with sexual behaviors and/or gender transition

LGBT = lesbian, gay, transsexual, transgender.

The IoM 2002 report carefully noted that health disparities for racial and ethnic minorities arise from both biologic/genomic differences and larger ecological/environmental sources of health determinants outside the health care systems.250 The report also clearly laid out the challenges to addressing health disparities, especially discrimination and implicit bias at the individual and clinical encounter level, and institutional stigma and discrimination at the system level.250

Efforts to improve cultural competence for the care of people of different racial and ethnic backgrounds must go beyond weaker types of interventions such as language translation, tailoring existing media such as health promotion videos or patient education brochures, or the assumption that hiring a bilingual or bicultural worker is sufficient for cultural competence. Interventions must simultaneously address fundamental beliefs people hold about the nature of disease, what are causal mechanisms, and expectations of treatment. Another key piece to address is the impact of discrimination within and outside of health care, which are experienced by these groups and affect many aspects of health and health care (such as adherence, utilization, and substance use).157 Other issues that affect racial/ethnic minorities include the enduring effects of residential segregation,251-253 which also affects the clustering of racial/ethnic minorities into certain health care facilities, which have been shown to have fewer resources than facilities where nonminorities get care.252,254

Another confounder is the frequent association between racial/ethnic minority status and poverty. Medicaid disproportionate coverage may pose limitations to access to care or restrictions in options. Medicaid coverage also adds another layer of stigma to populations experiencing discrimination within the health care system.

For disability groups, the underlying political and social culture is based on achieving equity of access to all of life's opportunities. Major advances such as the Americans with Disabilities Act have been based on a civil rights platform. Many people with disabilities do not view their disability as a medical problem, although it may complicate the receipt of medical care for clinical problems unrelated to the disability. For this subgroup of people, the goals of disability specific health care may be less curative and more focused on maximizing function and optimizing potential opportunities. Other people may frame their disability within a medical model. Therefore, treatment goals, as captured by outcomes of care, can differ based on disability definitions, disability models, and the professional perspectives of the care being provided in support of different service goals.255 While the goals of the care need to be individualized, there are some common barriers people with disabilities face to accessing competent medical care, including: getting care in the context of their disability (many medical providers have limited experience treating a traditional medical problem experienced by someone whose underlying disability that may affect treatment and prognosis); getting physical access to medical facilities (e.g., transportation, entrance, examining tables, etc.), and the general discomfort some clinicians may feel caring for patients with disabilities. For some people with disabilities, cognition may pose a problem in understanding of treatment options. However, this same problem applies to older people with cognitive impairment, except for the risk of stereotyping and premature judgment about cognitive abilities. Many people with disabilities may be covered by Medicaid and face the same limitations to access to care or restrictions in options faced by racial/ethnic minorities.

Cultural competence interventions in the LGBT population need to be sensitive to the invisibility of the population. While the race and disability populations likely produce an implicit bias or social distance on sight, LGBT people may elicit a straight bias from clinicians who do not consider sexual orientation status. People with disabilities that are not immediately apparent (such as mental health disabilities and autism spectrum disorders) may experience disparities associated with their hidden disabilities. Similar to the visible disability populations, LGBT people may not feel welcomed by clinicians and staff and may face clinical ignorance about how to address (or even raise) salient health-related issues. Internal and external stigma may interfere with disclosure and the ability to receive effective care. LGBT people are more educated, on average, than the general population but may have less access to insurance than their straight counterparts.256

## Conceptualization of Cultural Competence for Various Populations

Much has been written deconstructing and/or constructing the concepts and common uses of cultural competence. The cultural competence construct is not an entirely comfortable fit for disability populations, because identification with disability is not always viewed as a positive in-group dynamic. Concerns have also been raised about cultural competence programs that use a group-specific approach to teach providers about the attitudes, values, and beliefs of a specific cultural group. Such approaches can lead to stereotyping and oversimplifying the diversity within a particular priority group.257 Indeed, our review identified one study that resulted in this adverse consequence for the disability population.23 As long as cultural competence models focus on tailoring interventions for specific populations, outcomes will depend on the degree to which a person identifies as part of the target “culture.”

The broader concept of diversity competence may be more appropriate in regard to the full range of populations that experience health disparities. The recent shift towards cultural empowerment and cultural humility is encouraging and also consistent with the recommended shift toward structural equity-focused interventions.

A large body of literature has shown how discrimination and inequality harms the health of socially disadvantaged groups through multiple pathways, resulting in disparities.157,258,259 Repeated discrimination is a source of chronic stress, resulting in damage to the immune system, inflammatory disorders, and cardiovascular disease, as well as mental health disorders and cognitive impairment (see Mays et al., 2007,260 for a review). Discrimination is also associated with lower levels of adherence and health care use, greater mistrust in health care, and poorer communication with providers.258,260,261 Unconscious bias can lead to poorer communication on the part of health care providers and biased clinical decisionmaking. Many of the cultural competency interventions we reviewed addressed these barriers by seeking to reduce stigma among health care professionals or improving health care providers' skills at communicating with members of racial minority groups. Given this, it seems problematic to use the cultural competency label to describe interventions designed to reduce disparities. Cultural competency focuses too much attention on the internal characteristics of groups (i.e., their culture) while drawing attention away from the external factors (discrimination, exclusion) that contribute to disparities. Instead, we might call such interventions “equity interventions” to more accurately emphasize their goal.

## Research Directions

We need an evidence-base for cultural competence interventions. Two other reviews found that, similar to our findings, the research was not connected to disparities-related outcomes, the disparities addressed were minimally defined, and little concrete detail was provided on the cultural competence strategies used.230,262 However, the sheer number of studies that would be needed to address every possible subset of disability, LGBT, and racial/ethnic groups is daunting. A key direction for future research requires shifting models. Rather than attributional models that focus on the internal characteristics (or “culture”) of groups, research can use relational models that focus on the devaluation and exclusion of these groups within the broader society. This approach may also help to mitigate unintended consequences that could develop if research based on attributional models is generalized to a population for whom that particular approach is not a good fit.

Cultural competence research for the wider priority populations will require interdisciplinary approaches. These interdisciplinary teams will need to draw from the same skill pool as they reach across different academic, policy, and layperson cultures. As a simple example, team members for this project were drawn from diverse fields, disciplines, and research interests. The research process required synching language, since terms used in one academic culture did not automatically transfer to other academic cultures. While the process was complicated by the multiple perspectives brought to the task, those variations facilitated broader examinations of the constructs, and produced a more nuanced examination of cultural competence.

A call has been made to employ cultural sensitivity within the general health services research process.263 This call is similar to exhortations to incorporate the concept of universal design into health services research that reaches beyond disability-specific research.264 Research teams that include inside and outside perspectives (of study populations and researchers) can better capture both nuance and missed opportunities. Interdisciplinary and culturally sensitive research teams would weigh the trade-offs between generic instruments (that maximize what is common across groups) and culturally sensitive instruments (that narrow in on the issues most salient to a specific cultural group, or what works for whom). As the common wisdom says, we pay attention to what we measure.

Patients should be seen as active participants in the complex patient/provider/health care system. The relational models are better suited to working with patients who are not just members of a singular culture but rather a mosaic of cultural influences.265 Ultimately, the ability to provide culturally appropriate care may rely on some capable patients to act as an active part of the system by providing meaningful feedback so the system can learn. Involving patients in a participatory research process to help determine the concerns and outcomes of most interest to each group is common across all the priority populations.

All of this research would benefit from designs that follow downstream effects to capture whether the interventions closed the disparities gap. Interventions that raise the quality of care for all patients regardless of group membership is certainly welcome, but does not necessarily help reduce the difference.

## Conclusion

The HHS Office of Minority Health has dedicated an initiative to supporting cultural competence and has set cultural and linguistic standards for organizations to meet. Organizations also feel the pressure of legislative mandates and the need to be competitive in serving diverse groups and populations.266 These efforts are aimed at worthy social goals of reduced disparities and health equity.

Despite the effort dedicated to cultural competence, evidenced by the numerous models that have been published, the empiric work testing interventions identified in this review in support of cultural competence is sparse. There is not a consensus definition for cultural competence, particularly in the LGBT and disability populations. It is often conflated with patient-centered, or individualized care. None of the included studies measured the effect of cultural competence interventions on health care disparities. Interventions that altered existing protocols, empowered patients to interact with the formal health care system, or prompted provider behavior at the point of care were more likely to measure patient-centered outcomes. Actual tests of intervention effectiveness and harms or unintended consequences, whether model-based or empiric-based, would be of benefit.

The most prevalent type of cultural competence intervention is provider training. Yet, little evidence supports the effectiveness of provider trainings. Long-term effects of such programs on provider behavior in the clinical setting and subsequent patient health outcomes have not been evaluated. Further, traditional provider cultural competence trainings based on attributions of a culture have the potential for unintended consequences, such as reinforcing stereotypes or increasing stigma.

For each population, we identified interventions at the individual level to improve patient/provider interactions, often with cultural tailoring. These studies met inclusion criteria if they targeted a population of interest and were conducted by a medical professional in a formal health care system. Frequently, these interventions placed responsibility on patients more than providers or systems, without requiring either the provider or the system to become more competent. These programs tended to weigh heavily on common identity and cultural attributions and, in some cases, were less effective in subpopulations that were less tied to the community.

Five system-level interventions were identified that address disparities in one of the target populations, but do not necessarily require a provider to be competent. The most prominent example of such an intervention was patient-held medical records that prompt providers to evaluate areas of known disparity for a specific population. These point-of-care interventions were seen in all three population groups.

We need better understanding of how cultural competence differs between and within groups. For example, people with a physical disability experience more screening disparities because of limitations of the physical plant, whereas people with intellectual disabilities are more likely to not have secondary conditions diagnosed and treated. The interventions to address these disparities must also be different. There is also significant between- and within-group variation in population visibility that affects interventions to reduce disparities. For members of sexual minority populations, which are more invisible, cultural competence interventions may focus on reducing heterosexual bias among providers; for example, providers may not know that the patient is an LGBT person. In contrast, provider bias to racial and ethnic minority populations is immediate and based on characteristics perceived by the provider.

The “cultural competency” label itself may be outdated, because it emphasizes the “internal culture” of groups. A more useful term might be “equity interventions,” which emphasizes equity as the desired outcome. More important than labels is that interventions address structural barriers faced by priority populations in order to attain health equity. Future research with greater methodological rigor and greater attention to relational rather than attributional dimensions to meet the heterogeneity of these populations is needed.