# Disability Populations

## Introduction

Americans with disabilities represent a large and heterogeneous segment of the population. The prevalence of disability varies by age group and definition. Based on the U.S. Census Bureau's 2013 American Community Survey (ACS), which describes disability in terms of functional limitations, 12.6 percent of the civilian U.S. noninstitutionalized population (which excludes people living in institutional settings such as nursing homes) has a disability (defined as difficulty in hearing or vision, cognitive function, ambulation, self-care, or independent living). The U.S. Department of Education (2012), which uses categorical disability labels, estimates that 13 percent of children and youth ages 3 to 21 have a disability (defined as specific learning disabilities, speech or language impairments, intellectual disability, emotional disturbance, hearing impairments, orthopedic impairments, other health impairments, visual impairments, multiple disabilities, deaf-blindness, autism, traumatic brain injury, or developmental delay).

### Health Disparities

The International Classification of Functioning, Disability, and Health (ICF) describes body functions and structures, activities and participation, environmental factors, and personal factors that interact to influence a person's function and disability.4 Within the ICF framework, health disparities research examines how differences in health activities, health care participation, and health outcomes relate to differences in body function or structure, personal characteristics (such as age, sex, race, sexual orientation, health conditions, fitness, life experience, individual psychological assets, education, socioeconomic status), or features of the immediate (settings such as home, workplace and school) or societal (such as social structures, services, social networks, laws, rules, attitudes, and ideologies) environment in which a person lives.

People with disabilities experience many health disparities. Some documented disparities include poorer self-rated health; higher rates of obesity, smoking, and inactivity; fewer cancer screenings (particularly mammography and Pap tests); fewer breast conserving surgeries when breast cancer is diagnosed; and higher rates of death from breast or lung cancer.5

Health disparities research has developed through four generations: (1) documenting the disparities, (2) exploring possible reasons for the disparities, (3) providing evidence for solutions, and (4) moving towards structural, multi-level interventions.6 This review focuses on studies that test interventions to reduce health disparities (third and fourth generation disparities research). However, disability health disparities research is largely first generation,7 focused on accurately documenting the health care disparities experienced by its diverse subpopulations. Documenting health care disparities is difficult for many reasons, including the presence of multiple disability subpopulations and ways of defining these subpopulations, and the lack of national surveillance data for specific subpopulations that results in many small, convenience sample studies.8

### Cultural Competence

Cultural competence has been widely promoted as one approach to reduce health disparities. Since cultural competence remains variously defined and operationalized, it has become a blanket term to describe a broad range of system- or provider-level interventions. Initially, cultural competence focused mostly on racial and ethnic differences. More recently, it has been expanded to other marginalized population groups who are at risk for stigmatization for reasons other than race and ethnicity and/[underlined: or] who have differences in health care needs that result in health disparities. People with disabilities comprise some of these other populations. Culture competence implies the existence of a shared culture. Gill described the values of disability culture to include: viewing interdependence and helping as typical; accepting diversity in all its forms; being able to laugh at ones situation; planning for multiple potential outcomes and maintaining the ability to adapt; and being able to read people well under various conditions.9 Eddey and Robey described professional competencies related to the culture of disability, including: communicating with patients who have verbal deficits; understanding the values of people with disabilities and of disability culture including interdependence; and encouraging self-advocacy for patients and families.10 The authors acknowledge that, similar to other populations that experience health disparities, the degree to which a person identifies with disability culture varies and depends on a number of factors, including: the stage of life in which a disability is acquired; the visibility and/or severity of the disability; and the amount of organizational support for disability culture in the area where one lives.11 The interventions described in this review attempt to reduce disparities for persons with disabilities by affecting change in providers or health care systems. This review tries not to take a position on the concept of disability culture.

### Scope and Key Questions

#### Scope of the Review

This review examines the evidence for the effectiveness of system- or provider-level cultural competence interventions designed to address known or suspected health disparities among individuals with disabilities. We do not address policy-level evaluations. Because the language of cultural competence has not been widely applied to disabilities, and interventions have not necessarily been framed as targeting cultural competence, clarity about which interventions fall within the scope of cultural competence is important but challenging. We focus mainly on interventions that aim to change clinicians' behaviors (such as communication and clinical decisionmaking), the patient-provider relationship, and/or clinical systems to result in better outcomes for patients with disabilities. Within the clinical context, interventions aimed at improving care for all patients (such as patient-centered care, patient-centered medical homes, health literacy), are excluded.

#### Key Question

KQ: What is the effectiveness of interventions to improve culturally appropriate health care for children and adults with disabilities?

#### PICOTS

Table 2 provides the populations, interventions, comparators, outcomes, timing, and settings (PICOTS) of interest. The analytic framework can be found in Chapter 1 and Appendix A.

Table 2 Review PICOTS—disability populations

PICOTS | Criteria
Population | Children and adults described as having disabilities, with older adults' focus on aging with a disability, rather than aging into a disability
Intervention | Cultural competence/culturally appropriate care provider education and training Cultural competence/culturally appropriate care clinic-based interventions targeted to patients Cultural competence/culturally appropriate care clinic-based interventions targeted to providers
Comparator groups | Usual care Head-to-head trials of different strategies
Outcomes | Intermediate outcomes; - Provider training and motivation outcomes (competencies, knowledge, changes in attitudes); - Provider behavior, such as clinical decisionmaking, communication; - Provider beliefs/cognitions about the priority population, reduction in stereotyping and stigmatization; - Improved access to health services; - Utilization of health services; - Patient experience/satisfaction; - Patient health behaviors; - Use of preventive services and other access to care measures; Final health or patient-centered outcomes—reduced disparities in terms of:; - Patient medical care outcomes; - Patient mental health care outcomes (depression, substance use); Adverse effects of intervention(s); - Unintended negative consequences of intervention
Timing | Variable—depends on the purpose of the intervention
Setting | U.S. inpatient, outpatient, and community settings in which patients from priority populations are interacting with health care providers

PICOTS = population, intervention, comparator, outcomes, timing, and setting.

## Methods

This review followed the methods suggested in the AHRQ Methods Guide for Effectiveness and Comparative Effectiveness Reviews (available at www.effectivehealthcare.ahrq.gov/methodsguide.cfm); certain methods map to the PRISMA checklist.12 We recruited a technical expert panel to provide high-level content and methodological expertise feedback on the review protocol. The protocol was posted on July 8, 2014 at www.effectivehealthcare.ahrq.gov. This section summarizes the methods used.

### Literature Search Strategy

We searched Ovid MEDLINE®, PsychInfo, and Cochrane EPOC from 1990 to June 2015. Because the concept of cultural competence interventions in the disability community is not well defined, the initial search cast a wide net into the disability literature. Searches were performed iteratively to identify concept boundaries and tighten the working definitions and eligibility criteria to balance search sensitivity and specificity with feasible numbers of references to screen. The initial search strategy included cultural competence specific intervention terms, adapted from the race/ethnicity literature, and more general terms targeting health accessibility and health promotion. These more general terms were included because the exemplar articles identified by members of the technical expert panel were focused on improving physical access to care for individuals with disabilities and reminding providers to see the “whole person” with regard to providing preventive care and care for comorbid conditions. The health promotion, primary prevention, and health service accessibility terms had the greatest yield and were, therefore, the focus of the revised search. Other terms included in the revised search highlighted attitudes of health personnel, health care disparities, and the presence of stigma. The final search algorithms are provided in Appendix B. We also manually searched reference lists from systematic reviews and used back and forward searching of key articles recommended by experts.

### Study Selection

We reviewed bibliographic database search results for randomized controlled trials (RCTs) systematic reviews, nonrandomized controlled trials, before and after observational studies with comparators, and interrupted time series studies published in English language relevant to our PICOTS framework. All studies identified by title and abstract as potentially relevant by either of two independent investigators underwent full-text screening. Two investigators independently performed full-text screening to determine if inclusion criteria were met. (Excluded articles at full text provided in Appendix C with reasons for exclusion.)

The full team vetted initial search results and adopted inclusion decision rules to clarify search results to address the review scope. This led to several refinements to the inclusion criteria. Patients with nonsevere mental health conditions, such as mild to moderate depression, did not meet our disability criteria; therefore, interventions integrating mental health services into primary care did not meet inclusion criteria. However, interventions targeting the attitudes of physicians toward people with mental illness, to the extent the condition qualifies as a disability, were eligible and included.

We had difficulty drawing tight boundaries around the interventions because the disability literature is often not identified by the terms “cultural competence” or “culturally appropriate.” Under our normative definition of cultural competence for this population, remote (e.g., web- or phone-based) medicine as an intervention was deemed culturally competent to the extent that it increases access for people whose disabilities make travel difficult. Although these interventions are not “clinic-based,” virtual interventions involving the formal health system (essentially replacing the need to travel to the doctor's office) create access in a unique way for the target population. These interventions are seen as conceptually parallel to infrastructure changes that improve access for people with physical disabilities.

Interventions aimed at improving physician or patient knowledge of existing treatment guidelines for conditions experienced by people with a disability are not included unless they also targeted physician perceptions and/or patient access to care. School-based interventions targeting the attitudes of teachers, classmates, and other professionals were excluded as outside the scope of this review, as were studies aimed at changing the attitudes of providers of long-term disability supports and services in community settings. Only studies that examined interactions with formal health care providers were included. As a result, several trials aimed at improving wellness and secondary disease prevention among people with disabilities in home and community settings, including some virtual interventions, were excluded.

Due to the limited available literature, we also expanded the criteria to include studies from other developed countries that tested interventions that could possibly transfer to U.S. health care.

In order to focus on the literature most likely to be informative, we also found it necessary to create decision rules for study comparators. Studies that used comparators that did not allow for direct testing of the cultural competence intervention/intervention component were excluded.

Differences of opinion regarding eligibility were resolved through consensus adjudication.

### Risk of Bias, Data Extraction, Synthesis, and Presentation

We evaluated the risk of bias in included studies according to study design using criteria from the Cochrane risk-of-bias tool in interventional studies (Appendix D). Given the heterogeneity of the study populations and interventions and the high risk of bias assessment for most of the included studies, we were unable to draw meaningful conclusions from the literature. Because the literature did not provide adequate studies for quantitative analysis, results are summarized into evidence tables and qualitatively synthesized by common characteristics of interventions and outcome measures. Barriers to forming inferences from study results are also presented. One investigator abstracted the relevant data from eligible trials directly into evidence tables. A second investigator reviewed evidence tables and verified them for accuracy.

## Results

### Literature Search Results

We identified 17,684 unique English language citations (Figure 4) from 1990 to June 2015. After excluding articles based on title and abstract, full texts of 80 articles were reviewed to determine final inclusion.

Figure 4 Literature flow diagram—disability populations

Figure 4 is the literature flow diagram describing the number of references identified through our bibliographic literature search for the disability populations, the number that were identified through title and abstract screening as needing full text review, the number from the search eligible for our review, the number eligible identified through hand searching to the total number of references included.

Examples of studies excluded at full text for methodological reasons included: studies with a pre-post design or analysis,13-15 studies with a weaker comparator population than included studies,16,17 or studies where the intervention or outcomes were difficult abstract or interpret.18-20

Twenty of the 25 included studies were RCTs; five were controlled trials.21-25 Included studies fall into three main categories: interventions, predominantly trainings and curricula, aimed at changing professionals' attitudes towards individuals with disabilities (n=16); interventions aimed at increasing quality at the point of care by prompting patient and physician interaction (n=5); and interventions aimed at reducing barriers to accessing care (n=4). Table 3 describes the included studies by intervention type, disability population, and provider population. Studies were generally high risk of bias (Appendix D). Since the risk of bias and heterogeneity of the studies precluded any strength of evidence other than insufficient, we describe the studies by emergent patterns.

Table 3 Cultural competence intervention type by disability and provider populations

Type of Cultural Competence Interventions | Number of Studies | People With a Mental Illness or Substance Use Disorder | People With a Physical Disability | People With an Intellectual or Learning Disability | People With Lower Back Pain | Children With ADHD | People With Multiple Sclerosis | People With Arthritis
Trainings and curricula aimed at changing professional attitudes towards individuals with disabilities | 16 | Student nurses Clement, 2012^26^ Medical Students Bannatyne, 2015^27^ Cutler, 2012^28^ Friedrich, 2013^29^ Kassam, 2011^21^ Papish, 2013^30^ Pharmacy Students Nguyen, 2012^25^ O'Reilly, 2011^31^ Patten, 2012^32^ Mental Health Nurses Munro, 2007^33^ Mental Health Providers Michaels, 2014^34^ | Nursing Students Goddard, 1998^22^ Medical Students Kirby, 2011^35^ Symons, 2014^23^ a | Medical Students Symons, 2014^23^ a Primary Care Nurses Melville, 2006^24^ | Physical Therapy Students Domenech, 2011^36^ | NF | NF | NF
Interventions prompting interaction between patients and physicians or patients and the health care system | 5 | NF | Primary Care Screening Peterson, 2012^37^ | Primary Care Physicians Lennox, 2007^38^ Turk, 2010^39^ Dentists Meurs, 2010^40^ | NF | Primary Care Physicians Wolraich, 2005^41^ | NF | NF
Virtual interventions that reduce barriers to accessing care | 4 | Clinical Psychologists Knaevelsrud, 2010^42^ | NF | NF | NF | NF | Occupational therapists Finlayson, 2011^43^ Masters Level Therapists Patten, 2012^32^ | Masters Prepared Counselor Shigaki, 2013^44^

ADHD = attention-deficit hyperactivity disorder; NF = not found.

a The Symons et al.23 curriculum addresses physician attitudes toward various disability types including: sensory, physical, and intellectual disabilities. Therefore, this article appears in two population categories.

Among the 16 studies aimed at changing professionals' attitudes through training or curricula, the majority focused on changing the attitudes and beliefs of medical (n=7),21,23,27,29,30,35,45 nursing (n=2),22,26 pharmacy (n=3),25,31,32 or physical therapy (n=1)36 students. Three studies targeted practicing professionals: one studied primary care practice nurses;24 and two studied mental health professionals.33,34 Eleven of the 16 studies focused on physician attitudes toward people with a mental illness,21,25-27,29-34,45 three focused on attitudes toward people with a physical disability,22,23,35 two studies focused on attitudes toward people with an intellectual disability,23,24 and one study focused on attitudes towards people with lower back pain.36 One study focused on a dually diagnosed population that had mental health and substance use concerns.33

Five included studies attempt to reduce disparities at the point of care. Four of the five studies provide additional information about the patient and prompt physicians to pay attention to areas of known disparities during the routine clinical exam. One study teaches and empowers women with mobility impairments to get Pap tests and mammograms. All five studies promoting interaction between patients and physicians (or patients and the health care system) were conducted in the primary care setting; three focused on people with intellectual or learning disabilities, one focused on children with attention-deficit hyperactivity disorder, and one focused on women with mobility impairments.

The studies aimed at reducing barriers to accessing care were delivered by psychologists, occupational therapists, and masters prepared counselors. One of the four studies targeted people with mental illness, one focused on people with arthritis, and two focused on people with multiple sclerosis.

### Interventions Aimed at Changing Health Professionals' Attitudes

The framing of these articles generally spoke to reducing stigma,26,27,29-31,34,45 changing stereotypic views,21,33 filling gaps in training and understanding,23,24 and familiarizing physicians with supportive equipment.35 Table 4 summarizes the 16 studies of trainings or curricula aimed at changing health professionals' attitudes toward persons with disabilities.

Table 4 Summary of interventions targeting provider attitudes by disability type

Study, Design, Setting | Aim | Sample Size Population | Intervention Comparators | Reported General Findings
Bannatyne, 2015^27^ Randomized trial Queensland Australia | To compare the effect of biogenic education versus traditional multi-factual education versus no education on volitional stigma towards patients with anorexia nervosa. | 41 fourth-year medicine students | The two active interventions were one-time, 3 hour courses that were identical in all respects, except information regarding the etiology of anorexia nervosa: the biogenetic arm emphasized potential genetic underpinnings of the disease: the multifactorial arm emphasized interaction between psychological and social etiologies. | Participants in both the biogenic and multifactorial arms had significantly less overall stigma, blame and responsibility associated with the patient with anorexia, and were significantly less likely to consider anorexia a vain or selfish illness, compared with the no intervention control. There were fewer significant findings between active intervention types.
Clement, 2012^26^ Randomized trial University, UK | To compare the effect of a DVD or a live intervention followed by discussion, and a lecture control in reducing stigma about mental illness | 216 student general nurses | Video vs. live interventions with similar content: personal narratives and experiences from mental health consumers and providers vs. lecture on stigma | Both intervention formats decreased stigmatizing attitudes and increased intended social proximity compared with control.
Cutler, 2012^45^ Controlled study University, U.S. | To determine the effect of a one-time exposure to an art exhibit featuring art created by people with chronic mental illness on medical student attitudes. | 174 pre-clinical medical students enrolled in a psychiatric medicine course | 64 students toured the art studio that was housed in state psychiatric facility, 44 of the 64 interacted with an artist (a person with a chronic mental health condition). The control group consisted of 110 students who had not visited the exhibit | Overall students who visited the museum had more positive feelings toward people with chronic mental illness and identified more positive personality traits in the population. However, among those who spoke directly to a person with a chronic mental health condition, there was an increase in perceived hopelessness of people with chronic mental illness.
Domenech, 2011^36^ Cluster-randomized trial University, Spain | To determine the effect of two brief educational modules (biopsychosocial or biomedical) on the attitudes of students and changes in the recommendations given to their patients | 170 second-year physical therapy students | Education based on the biopsychosocial model of lower back pain management vs. lectures on the biomechanics of the spine | Intervention participants had more positive attitudes and less fear in recommending general physical activity for people with lower back pain.
Friedrich, 2013^29^ Randomized trial Four medical schools, UK | To determine the effect of a voluntary training to reduce mental health stigma on medical students' mental health-related knowledge, attitudes, and intended behavior | 1,452 third-year medical students at baseline, 625 immediately after intervention, 137 at 6 month followup | Lecture, stories from patients and providers about mental health problems and stigma and role plays in small groups vs. no intervention | Intervention group had improvements in mental health stigma-related knowledge, attitudes, intended behavior at immediate followup but not at 6 months.
Goddard, 1998^22^ Pre-Post, historical control University, Texas | To determine the effect of Sensitivity Lab on students' attitudes toward persons with disabilities immediately after the lab and at 6 weeks and 6 months | 121 nursing students enrolled in course on a chronic illness | Sensitivity Lab, 8 hours: (1) simulation of various disabilities, (2) panel presentations by persons with disabilities and their caregivers, (3) small groups discussion vs. same course with no sensitivity lab | Nursing students had relatively positive scores on the Attitudes Toward Disabled Persons scale, with no significant differences among groups.
Kassam, 2011^21^ Clustered trial University, UK | To compare the effect of 3 interventions on students' mental illness related knowledge, attitudes and behavior toward people with mental illness | 188 third-year medical students at baseline, 110 with pre- and post- scores | Presentation (1 hour) on mental illness related stigma including personal testimonies from a patient and caregiver and discussion vs. presentation plus role-plays (20 minutes) vs. no intervention | Knowledge increased in both of the intervention arms compared with the control, but with no differences in physician attitudes or behaviors.
Kirby, 2011^35^ Randomized trial University, Canada | To assess the effect of workshop tailored for undergraduate medical students in improving wheelchair-related knowledge, skills, and attitudes | 26 first- and second-year medical students | Wheelchair Education Workshop (4 hours: 45 minutes lecture, 2 hours wheelchair skill practicing, 1 hour community experience, a 15 minute debrief) vs. no intervention | Intervention group had higher scores on the written wheelchair knowledge test and practical wheelchair skills examination, with no difference in attitudes between the groups.
Melville, 2006^24^ Controlled trial Glasglow, Scotland | To assess the effect of training for nurses designed to reduce access barriers for people with intellectual disabilities on nurses' knowledge and self-efficacy | 123 nurses in primary care | Training pack (45 pages) plus face-to-face training (3 hours, on knowledge and self-efficacy in care for people with intellectual disability) vs. training pack only vs. no intervention | The combination group had increased knowledge and self-efficacy compared with the no intervention, with no difference between the training pack only group and the other two arms.
Michaels, 2014^34^ 2 Randomized controlled trials Maryland, U.S. | To assess the effect of a workshop designed to reduce stigma surrounding mental illness for people with mental illness and providers of services to people with mental illness. | 127 people with mental illness and 131 mental health service providers were randomized. | The 3 hour Anti-Stigma Project workshop (ASP) includes: a facilitated small-group discussion in which participants share their own experience of stigma, a video on the impact of public stigma on mental health services, and a group discussion of ways to combat public stigma on both a personal and systemic level. The control arms watched 3-hour videos on unrelated topics. | For providers, the workshop significantly improved awareness of stigma, reduced levels of prejudice towards people with psychiatric disabilities, and increased acceptability of a wide variety of personal goals of persons with disabilities. The intervention did not significantly improve providers' opinions regarding the potential for recovery from mental illness.
Munro, 2007^33^ Randomized trial Mental health, community or hospital-based Scotland | To assess the impact of training on the therapeutic attitudes and knowledge of nurses who work with people with co-existing substance use and mental health problems | 49 mental health nurses | 4 days of training including small interactive groups and lectures vs. no intervention | Intervention group had improved attitudes immediately following the intervention and sustained at 6 months. Knowledge improved over time for both groups with no difference them.
Nguyen, 2012^25^ Controlled study Australia | To compare the effect of direct versus indirect contact with mental health consumers on stigma | 244 3^rd^ and 4^th^ year pharmacy students had complete, paired data for analysis | The direct contact arm attended a 2 hour workshop led by 3-4 mental health consumer educators and 2 pharmacists where consumers shared their personal experiences of mental illness with students. The indirect arm was 90 minutes and featured videos of consumers being interviewed as well as videos of clinical scenarios. | There was no difference in social distance by delivery method. While both delivery methods significantly decreased stigmatizing beliefs, the direct contact arm showed additional gains on several items, compared to the indirect arm.
O'Reilly, 2011^31^ Randomized trial University of Sydney, Australia | To assess the impact of delivering MHFA training for pharmacy students on their mental health literacy and stigma towards mental illness | 272 (60 intervention, 212 control) third-year undergraduate pharmacy students | MHFA course (12 hours) plus standard curriculum (9 hours plus community pharmacy placement) vs. standard curriculum only | Intervention group improved in social distance, ability to correctly identify a mental illness, and confidence in providing services in mental illness.
Papish, 2013^30^ Cluster-Randomized trial University of Calgary, Canada | To examine the impact of a one-time contact-based educational intervention on stigma of mental illness among medical students enrolled in a multimodal psychiatry course | 111 second-year medical students | Contact-based intervention (2 × 1-hour patient stories of mental illness) at the beginning vs. end of 4-week mandatory psychiatry course | Stigma toward mental illness improved for both groups after the course, with no difference between groups in the primary analysis. Stigma remained greater for mental illness than type 2 diabetes mellitus.
Patten, 2012^32^ Randomized trial University of Calgary, Canada | To examine the impact of a contact-based intervention on stigma toward persons with schizophrenia or bipolar disorder. | 74 third and fourth year pharmacy students from three Universities had data for all three time points (56.5%) of randomized population. | One-time, contact-based intervention varied in length by participating university (60-120 minute discussion featuring 2-3 consumer speakers) compared with a wait list control. | Intervention group had significantly more positive attitudes and less stigma towards people with mental illness compared with wait list controls overall, and at two of the three participating Universities.
Symons, 2014^23^ Controlled study Two public medical schools, NY | To examine the effect of a longitudinal curriculum designed to improve medical students' knowledge, attitudes, and skills pertaining to care of persons with disabilities | 244 medical students | First 3 years of 4-year curriculum addressing care for people with disabilities integrated into existing curricula (lectures from community agencies, interactions with individuals with disabilities, presentations of clinical encounters, and a precepted clinical experience treating a person with a disablity) vs. standard curriculum | Intervention group improved in comfort with people with disabilities, but worsened in negative perceptions that people with disabilities are resentful and expect special treatment.

MHFA = Mental Health First Aid.

Table 5 summarizes the common characteristics and modalities of included interventions aimed at changing provider attitudes toward persons with disability. The majority of interventions included direct contact with a person with a disability. Of the 16 included articles in this category, 11 interventions included direct contact with people with disabilities,21-23,25,26,29-32,34,45 three included role playing with people with disabilities or actors playing the part of a person with a disability,21,23,29 and two included a person with a disability as a trainer.24,25 Twelve studies used one-time trainings or experiences of varying intensity,21,22,24-26,29,31-35,45 two developed university curricula,23,30 and two tested different approaches to teaching subject matter (biomedical versus psychosocial models of lower back pain; and biogenetic versus multifactorial etiological framings of anorexia nervosa).27,36 One older study used a simulation in which providers “assumed various disabilities” for a certain amount of time22 and one focused on medical students learning to use wheelchairs.35 These last two simulation studies may be considered controversial or outdated methods of competency training by members of the disability community. Simulation exercises do not accurately portray the experience of having a disability and may have the effect of reinforcing negative stereotypes toward members of the population, and make disability an individual instead of societal problem.46

Table 5 Aggregate of interventions targeting provider attitudes by disability type

| Target of Intervention | | | | | | Intervention Characteristics | | | | Modalities
Disability Population | Medical Students | Nursing Students | Pharmacy Students | Physical Therapy Students | Nurses | Mental Health Providers | Direct Contact | Role Playing | Trainer with Disability | Simulation | Training Sessions / One-time Experience | University Curricula / Theoretical Approach
People with a mental illness21,25-27,29-34,45 | 5 | 1 | 3 | | 1 | 1 | 8 | 2 | 1 | | 9 | 2
People with a physical disability22,23,35,a | 2 | 1 | | | | | 2 | 1 | | 2 | 2 | 1
People with an intellectual disability23,24 a | 1 | | | | 1 | | 1 | 1 | 1 | | 2 | 1
People with lower back pain36 | | | | 1 | | | | | | | | 1

a The Symons et al.23 curriculum addresses physician attitudes toward various disability types including: sensory, physical, and intellectual disabilities. Therefore, this article appears in two population categories.

The form of the comparators varied. For the five studies that used no-intervention or wait-list control, the duration of the five interventions ranged from 4 hours to 4 years.22,23,29,33,35 Four studies that used the equivalent of a “usual care” control group generally embedded education or training components within curriculum that was otherwise relevant compared with the curriculum without the added component.30-32,36,45 For example, one study compared a 12-hour Mental Health First Aid (MHFA) training program plus the standard mental health curriculum to the standard mental health curriculum alone for pharmacy students.31 Another study provided a 60-90 minute, contact-based experience as part of a mental health pharmacy course; students who had the experience later in the semester served as the comparator popuation.32 Two studies compared the effect of differing educational approaches, or disability framings, on student attitudes and beliefs.27,36 Michaels et al. used a video attention control on an unrelated topic.34 In addition to testing whether training is more effective than no training or usual care, four studies considered the comparative effectiveness of delivery modality25,26 and intensity.21,24 For example, one study had three arms: watching a DVD of individuals with mental health disabilities and their caregivers describe their experiences of mental health stigma followed by a researcher-facilitated discussion; the same testimonies delivered live, followed by a research-facilitated discussion delivered live; or a lecture on stigma provided by a mental health nurse researcher (no direct or indirect contact with consumers or care providers).26 All three arms were roughly 75 minutes long.26

Table 6 organizes the studies by outcomes studied. No studies examined clinical outcomes with a controlled design, although one of the included studies assessed nurses' self-reported changes in clinical behavior following the intervention to improve the accessibility of care for people with intellectual disabilities.24

Table 6 Reported key study outcomes for trials aimed at changing provider attitudes

| Reducing Stigma or Changing Attitudes | Knowledge | Self-Efficacy or Treatment Confidence | Intended Social Proximity or Behavior
Bannatyne, 2015^27^ | ↑ (Biogenic or multifactorial vs. control – sustained for 8 weeks) | NM | NM | NM
Clement, 2012^26^ | ↑ (DVD or live vs. control) | ↔ (DVD or live vs. control) | NM | ↑ (DVD or live vs. control)
Cutler, 2012^45^ | ↕ (mostly positive, no effect on beliefs about recovery from mental illness) | NM | NM | NM
Friedrich, 2013^29^ | ↔ (Initial gains lost at 6 months) | ↔ (Initial gains lost at 6 months) | ↔ (Initial gains lost at 6 months) | ↔ (Initial gains lost at 6 months)
Goddard, 1998^22^ | ↔ | NM | NM | NM
Kassam, 2011^21^ | ↔ | ↑ (Either intervention arm vs. control) | NM | NM
Melville, 2006^24^ | NM | ↑ (Live vs. control) ↔ (Packet vs. control) | ↑ (Live vs. control) ↔ (Packet vs. control) | NM
Michaels, 2014^34^ | ↑ | NM | NM | NM
Munro, 2007^33^ | ↑ (Sustained for 6 months) | ↔ | NM | NM
Nguyen, 2012^25^ | ↑ (Direct contact more effective than indirect on several items) | NM | NM | ↔ (No difference between direct contact & indirect contact arms – both improved social distance)
O'Reilly, 2011^31^ | NM | ↑ | ↑ | ↑
Papish, 2013^30^ | ↑ (Course vs. control) ↔ (One-time vs. control) | NM | NM | NM
Patten, 2012^32^ | ↑ | NM | NM | NM
Symons, 2014^23^ | ↕ | NM | NM | NM

↑ Significant positive findings; ↔ No significant findings; ↕ Positive and negative statistically significant findings; NM = not measured.

Common outcomes included measures of stigma or attitudes,21-27,29-31,33,34,45 knowledge,21,24,29,31,33 self-efficacy or treatment confidence,24,29,31 and intended social proximity or behavior (e.g., comfort working with someone with a mental health problem).25,26,29,31 Scales used to measure stigma or attitudes included: the Attitudes toward Persons with Disabilities Scale,22,35 Community Attitudes toward the Mentally Ill (CAMI) scale,29 Opening Minds Scale for Health Care Providers (OMS-HC),30,32 Mental Illness: Clinicians Attitudes Scale (MICA) scale,21,26 Self-Determination Scale (SDS),34 Recovery Scale (RS),34 Causal Attributions Scale,27 Attribution Questionnaire (AQ-9),25,34 Opinions Scale,27 Eating Disorder Stigma Scale,27 and the Emotional Reactions to Mental Illness Scale (ERMIS).26 Cutler et al. developed a 24-item instrument to rate the attitudes and feelings of medical students toward people with chronic mental illness.45 Michaels et al. developed the Awareness Questionnaire (AwQ) to measure recognition of stigma in the mental health system and its impact on people with mental illness, and a stigma measure disguised as a knowledge test to circumvent social desirability.34 Intended social proximity was measured by Reported and Intended Behaviour Scale (RIBS)26,29 and the Social Distance Scale.25 Knowledge was measured using the Mental Health Knowledge Schedule (MAKS).29 The Jefferson Scale of Physician Empathy was used by one study.29 Munro developed a knowledge questionnaire called the Comorbidity Problems Perceptions Questionnaire (CMPPQ).33

Reported results were mixed. Twelve of the 16 studies measured physician stigma, attitudes, or beliefs.21-23,25-27,29,30,32-34,45 In six of the 12 studies, the intervention significantly improved attitudes/reduced stigma;25-27,32-34 four of the 12 studies found no significant effect of the intervention on attitudes/stigma;21,22,29 two of the 12 studies found both positive and negative effects of the intervention on attitudes toward people with a disabiltiy;23,45 one study found arms to be differentially effective on provider attidues and stigma.30 Knowledge was measured in six of the 16 studies.21,24,26,29,31,33 Interventions improved provider knowledge in three studies;21,24,31 no significant effects on knowledge were found in three studies.26,29,33 Treatment confidence was measured in three of the 12 studies.24,29,31 Significant increases in confidence were found in two studies;24,31 no significant effects on treatment confidence was found in one study.29 Provider intended social proximity was measured in four studies;25,26,29,31 half of the interventions showed significnat improvements on these outcomes.26,31 The medium to high risk of bias and different PICOT combinations in the included studies does not allow for further analysis and synthesis of these reported effects.

Two trials reported outcomes that did not fit into Table 6. One study found students with the biopsychosocial lower back pain education had more positive attitudes and less fear in recommending general physical activity for people with lower back pain leading to more guideline consistent recommendations for work and activity.36 In the other study, knowledge and skills measured were specific to wheelchairs.35 Students in the intervention had statistically higher scores on the written wheelchair knowledge test and practical wheelchair skills examination compared with controls.35 No difference in attitudes was observed between the intervention and control groups.35

### Interventions Prompting Interaction Between Patients and Physicians or the Health Care System

Table 7 summarizes five trials that prompt interactions between patients with disabilities and their physicians and health systems. Four of the five trials tested the effect of providing information or prompting clinician behavior at the point of patient interaction on the care received during that interaction.38-41 One trial provided screening education tailored to women with mobility impairments and followed up the women to determine if care was received.37 These interventions aimed to reduce disparities in provision of health or preventative care.

Table 7 Interventions targeting patient/provider interactions for disability

Study, Design, Setting | Aim | Sample Size Population | Intervention Comparators | Reported General Findings
Lennox, 2007^38^ Clustered- randomized trial at the general practitioner level Primary care, Australia | To determine the effectiveness of a CHAP vs. usual care on health promotion and prevention among adults with IDs | 453 adult participants with ID in 34 clusters of primary care physicians | CHAP (21-page booklet: medical history; prompt for physician to perform a targeted examination; list of commonly unrecognized or poorly managed conditions within the ID population; guide for caretaker to complete a health action plan) vs. usual care | Most health promotion and disease prevention outcomes in the CHAP arm were significantly increased compared with control.
Meurs, 2010^40^ Randomized trial Two dental care centers, Netherlands | To investigate whether information about a patient who is intellectually disabled would result in better cooperation during a first dental visit. | 58 people with ID | Questionnaire (e.g., on patient communication preferences, completed by guardians) read by the dentist prior to the visit vs. limited patient information (age, medical condition) | Providing additional information to the dentists did not increase patient cooperation during the dental encounter, regardless of disability severity.
Peterson, 2012^37^ Randomized trial Oregon, U.S. | To assess the effect of a program to encourage women with mobility impairments to get recommended mammograms and pap tests on receipt of these screening services. | 211 women with mobility impairments were randomized, 156 completed pre- and post-tests (74%) | 90-120 minute small group (4 women) workshop educating women on breast and cervical cancer risk, overcoming barriers to screening, and building skills to communicate with physicians followed by monthly calls for 6 months post-intervention. Intervention led by women with mobility disabilities. Control group received written material on health promotion. Both arms received money and small gifts for participation. | Intervention significantly improved receipt of pap test (among those not up-to-date) compared with control; there was no significant difference in mammography screening at 6 months (among those not up-to-date) compared with control. All outcomes self-reported.
Turk, 2010^39^ Cluster-randomized trial at practice level UK | To test the effect of a patient-carried PHP for people with learning disabilities on number of visits per year, communication, and number of health problems reported | 201 adults with learning disabilities in 40 practices | PHP (hand held health record with overview of relevant conditions and dependent on participation of both providers and patients or caregivers) vs. usual care | No difference between groups in annual visits, knowledge, or communication; increased reporting of health outcomes in the PHP group.
Wolraich, 2005^41^ Longitudinal U.S. | To test the effect of an information and communication session between parents, teachers, and primary care providers of children with ADHD on coordination of care | 234 students (Only 34% of students randomized to the intervention arm had a parent receive the intervention, and only 19% had a PCP receive the intervention.) | 1-hour session with the child, parent, teacher, and/or physician (focused on sharing information about the student with ADHD between all parties) vs. no intervention. Tools included: teacher, parent, and PCP contact sheets; daily report cards; medication side-effects checklists; and a parent ADHD manual. | The intervention did not increase communication, defined as the number of times there was verbal or written communication between physicians and teachers.

ADHD = Attention Deficit Hyperactivity Disorder; CHAP = Comprehensive Health Assessment Program; IDs = intellectual disabilities; PCP = primary care provider; PHP = personal health profile.

Four of the five studies focused on individuals with intellectual or neurobehavioral learning disabilities.38-41 The United Kingdom and Australia have implemented health checks for individuals with intellectual disabilities on a large scale. The strongest trial in this grouping is from Australia and tests the effect of a Comprehensive Health Assessment Program (CHAP).38 The CHAP is a 21-page booklet divided into three sections: a medical history completed by the carer and carried to the doctor's office on the day of the appointment; a section completed by the doctor that documents he/she has reviewed the carer's completed medical history, completed a targeted examination, and developed a heath action plan with the carer; the last section has a list of commonly unrecognized or poorly managed conditions and disability-specific comorbidities.38 Four hundred fifty-three people with intellectual disabilities participated in the cluster randomized trial. People with the intervention were significantly more likely to: have sensory deficits identified, receive a tetanus/diphtheria booster or hepatitis B serology, have their weight recorded, and women were significantly more likely to have a Pap smear and mammogram.38 Many of the effect sizes were large. The United Kingdom and Australia have implemented health checks for individuals with intellectual disabilities on a large scale.

The other three studies that attempted to prompt physician behavior at the point of interaction had major theoretical and methodological limitations.39-41 Unlike the CHAP tool that clearly prompted physician behavior (similar to checklist interventions), the Meurs et al. questionnaire provided a large amount of information without a pathway for action. The authors identified not giving dentists enough time to “digest” this information as a potential study limitation.40 The intervention drew additional attention to the limitations of the person with the disability without assisting the dentist to identify strategies to change his or her approach to be more culturally competent. Further, this study offered no opportunity for patients and/or caregivers to rate the physicians on the interaction. The Turk and Wolraich studies had low participation rates.39,41 In Turk et al., 20 percent of care providers in the intervention arm stated they had not been given a personal health profile (PHP) at followup, only 18 percent of patients and 39 percent of care providers who said they received the PHP reported using the tool, and less than a third of care providers who said they received the PHP reported taking the tool to a primary care visit.

The four previously described studies prompt physician action or physician-patient interaction at the point of care. The last study in this category prompts patients to interact with the health care system.37 Women with mobility disabilities participated in a two-hour small group (four women) workshop led by women who also had mobility disabilities. The workshop covered not only general screening benefits, but also ways to overcome physical barriers to screenings and how to communicate with physicians to facilitate screenings.37 Participants in the intervention arms also received structured phone calls for 6 months. Compared with a written information control, women in the intervention group self-reported receiving significantly more pap testing; there was no significant difference in mammography rates between the attention and control groups. The two major weaknesses of this study are the lack of attention control and the self-reported screening outcomes.

### Interventions Improving Access to Care

The four trials on access to care are part of a much larger literature on virtual care for people with disabilities. Many virtual access articles were excluded during title/abstract screening because the intervention occurred outside the formal health care system; that is, the study did not involve health care practitioners delivering health care virtually, or the focus of the study was not creating access based on the nature of the disability. For example, Morland conducted two trials of virtual care for veterans with post-traumatic stress disorder (PTSD).47,48 However, the remote care required people in remote areas to travel to a central location for group therapy. This intervention seemed more focused on creating access due to workforce shortages than creating a way to deliver care that would feel safer and less stigmatizing.

The inclusion status of the final set was influenced by article framing. Articles were framed as follows: “Despite the findings supporting the Managing Fatigue program [for people with multiple sclerosis], its major limitation to date has been its inaccessibility to individuals who cannot travel to the community sites where the program is offered;” (p.1131)43 “The Internet might provide an alternative information and treatment opportunity for people who avoid care because of concerns about the stigma of receiving mental health treatment;” (p.73)42 “For individuals with RA, travel may be difficult due to pain or functional limitations;” (p. 1578)44 and “Telephone counseling was selected as the intervention delivery mode because it is an effective behavior change approach that overcomes barriers to participation such as distance, accessibility, and limited transportation, barriers that may be even more prominent among people with MS.”(p.90).49

Table 8 summarizes the included studies providing virtual access to care.

Table 8 Summary of interventions providing virtual access to care

Study Design Setting | Aim | Sample Size Population | Intervention Comparators | Reported General Findings
Bombardier, 2013^49^ Randomized trial U.S. | To determine the effect of a telephone-based intervention to reduce severity of major depression in persons with MS by using motivational interviewing to change levels of physical activity. | 92 people with MS | An initial in-person visit was followed by seven, 30 minute telephone counseling calls and a final in-person visit compared with a wait list control group. The intervention was delivered by master's level counselors. | There was no clinically significant difference in depression symptom severity or remission rate among the treated. However, there were statistically significant differences found on secondary outcome, including: mean change in depressive symptoms, depression severity, negative affect, clinical diagnostic criteria for major depression or dysthymia, and MS-related side-effects.
Finlayson, 2011^43^ Randomized trial U.S. | To test the effect of a small-group teleconference on fatigue management among adults with MS | 191 people with MS | Six 70 minute weekly group teleconferences delivered by licensed occupational therapists vs. waitlist | Intervention had improved fatigue impact, sustained at 6 months, but no difference in fatigue severity, self-efficacy.
Knaevelsrud, 2007^50^ Randomized trial Netherlands | To test the effect of a therapist-led CBT writing intervention on PTSD symptoms | 95 people with PTSD | A CBT-based writing intervention delivered by doctoral-level clinical psychologists via email (10 over 5 weeks) vs. waitlist | Intervention group has improved PTSD and mental health symptoms, sustained at 18 months, with no difference in physical health.
Shigaki, 2013^44^ Randomized trial U.S. | To test the effect of an RA self-management intervention and weekly phone call on symptoms, self-efficacy, quality of life | 108 people with RA | RA help (10 week online cognitive-behavioral self-management group program) plus weekly one-to-one 15-30 minute phone call vs. waitlist | Intervention group has improved self-efficacy and quality of life, sustained at 9 months, with no effect on health status or pain.

CBT = cognitive behavioral therapy; MS = multiple sclerosis; PTSD = post-traumatic stress disorder; RA = rheumatoid arthritis.

While all of the studies in this group used a virtual access to care intervention, each study used different populations, intervention characteristics, and targeted outcomes. Use of waitlist controls was the only element common across studies.

The primary outcome for the counseling intervention to decrease major depression by increasing physical activity in people with MS was a reduction in depression severity, as measured by the Hamilton Depression Rating Scale (HAM-D).49 A clinically significant response to treatment was defined as a 50 percent decrease in the total HAM-D score. There was no clinically significant difference in depression severity between the treatment control groups. However, treating HAM-D scores as continuous, there was a significant decrease in depression severity among the treated, negative affect, and number of people meeting the criteria for major depressive disorder or dysthymia among the treated.49

The primary outcomes for the teleconference intervention aimed at managing fatigue in individuals with MS include: fatigue severity (measured using the Fatigue Impact Scale [FIS], fatigue impact (measured using the Fatigue Severity Scale [FSS]), and health-related quality of life (measured using the SF-36 Quality of Life Scale).43 An intent to treat analysis found significant effects of the intervention on all three subscales of the fatigue impact severity measure and the role physical subscale of the SF-36; fatigue severity, self-efficacy, and the other seven domains of the SF-36 did not differ significantly.43

Primary outcomes of the therapeutic writing intervention for PTSD include measures of: symptoms of posttraumatic stress (Impact of Event Scale, IES-R), depression and anxiety (SCL-90), self-reported physical and psychological function (SF-12), and patient and therapist agreement (Working Alliance Inventory [WAI]).42,50 Participants in the intervention arm showed significant improvements over time on all measures except physical health, compared with the waitlist control.50

Rheumatoid arthritis (RA) online outcomes included rheumatic disease specific self-report of health status and well-being (Arthritis Impact Measurement Scales 2, AIMS2), an arthritis specific self-efficacy measure (Arthritis Self-Efficacy Scale [ASES]), depression (Center for Epidemiologic Studies Depression Scale, CES-D), quality of life (QLS-15), measure of joint and pain tenderness (Rapid Assessment of Disease Activity in Rheumatology, RAPID), a measure of social connectedness (Social Provisions Scale, SPS), and a measure of loneliness (University of California, Los Angeles Loneliness Scale, version 3, LS-3).44 Immediately after interventions, significant gains in self-efficacy and quality of life were observed; these gains were maintained for 9 months post-intervention.44

## Discussion

### Overview

Despite the difficulty in locating studies that fit a cultural competence for disabilities concept due to the lack of commonly used indexing terms and the minimal application of the cultural competence concept to disability research, we identified 25 intervention studies. These 25 studies map to only a small portion of the many and diverse groups that comprise the overall set of people with disabilities.

The most traditional cultural competence intervention, provider training, was also the most common type of study found in this review. This literature was dominated by interventions aimed at reducing stigma and changing provider attitudes toward people with mental illness. Only four studies attempted to change provider attitudes and beliefs about people with physical or intellectual disabilities, two of which attempted to do so through having students participate in a disability simulation (an approach with the potential to confound stereotypic thinking). Contact-based interventions, in which providers interacted with a person with a disability, were the most common intervention type; two contact-based interventions resulted in more negative attitudes among some participants.23,45 Twelve of the 16 included trainings or curricula studies developed for students, not working professionals. Many of the available studies were not designed to capture how well initial knowledge gains or changes in attitudes are sustained over time. Of those that did have a longitudinal design, one study found changes were not sustained for 6 months,29 two studies found changes were sustained for 2 and 6 months respectively.27,33 The effectiveness of these interventions depends on students applying their pre-service training to their work in clinical settings.

We considered two other types of interventions in this review: the patient or physician prompt at the point of care; and virtual care that creates disability sensitive access. Lennox and colleagues are pioneering low-tech, seemingly effective ways to prompt universal screenings for areas of known disparities for persons with intellectual disabilities. While promising, we did not find additional high quality trials to support this work. If there is little evidence for upstream interventions, such as provider trainings,51 the research community may want to also focus on downstream, point of care interventions. Interventions that prompt the physician at the point of care work hand-in-hand with interventions that empower the person with disabilities to talk to their doctor.37

We also broadened our definition of cultural competence to include virtual interventions that addressed disability related barriers to access including difficulty traveling and not wanting to get care because of stigma. These studies have the most patient-centered outcomes. Just as focusing on the point of care does not mean giving up on changing provider attitudes and beliefs, creating a parallel system for care does not preclude making the mainstream system more disability competent.

### Research Directions

The risk of bias for most of the included studies was high (Appendix D). The major weaknesses of this literature are the lack of attention controls, lack of appropriate comparators, attrition, and social desirability bias of pre- post attitude scales. Michaels et al. is the only included study to try to address social desirability among respondents.34 More well-designed studies are needed to test the effectiveness of disability competence interventions, particularly for nonmental health related disabilities. We need to be looking for unintended effects of trainings, and the effect of trainings and one time interventions on patient-centered outcomes. Without attending to methodological concerns, it will remain difficult to answer whether such interventions improve care and reduce health disparities.

Cultural competence is not a one-size-fits-all concept across populations that experience health disparities. Much of the team's work during this review was spent defining the concept of cultural competence for the disability population. The work of developing definitions for cultural competence as well as effective solutions for improving providers' knowledge and training in the health needs of people with disabilities should involve people with disabilities. While community-based participatory research with racial and ethnic groups has a fairly strong track record, much could be done to bring the perspective of people with disabilities into the research process. Future research on disability-related health care disparities and interventions to address them should target dimensions most important to people with disabilities and include more patient-centered outcomes. Including people with disabilities in research conceptualization and design is critical to identifying more effective solutions and producing evidence that could be understood and used by various stakeholders including people with disabilities.

Many disability groups and subgroups are not represented in this literature. Many subgroups exist within the disability populations with multiple perspectives, interests, and challenges. These differences can be further complicated by factors not directly attributable to disability, such as rural or urban location, poverty status, or racial and ethnic differences. Interventions targeting the intersection of populations of interest (such as race and disability) were also not well researched for this population. Researchers have begun to document health disparities at the intersection of disability and race/ethnicity.52-56 There is also movement to align disparities research across race/ethnic and disability populations.7,55,57 However there is not a sufficient evidence base to conclude whether interventions used to promote racial and ethnic provider cultural competence will produce reductions in disparities when used to promote provider cultural competence for people with disabilities in health care contexts. Carefully designed studies conducted for race/ethnic and disability populations, as well as their intersection, are needed. Intervention types appear to be tied to disability types in the literature. Work is needed to conceptualize cultural competence to address inclusion of the many populations and interventions under the diverse disability umbrella.

### Limitations

This review is limited by the difficulty of locating literature using either MeSH® terms or natural language keywords. This difficulty is exacerbated by the new extension of the concept of cultural competence to disability cultures. This, in turn, may be influenced by a lack of consensus among disability communities about whether disability is a “culture.”

While care and attention was dedicated to defining the scope boundaries for this review, they are necessarily arbitrary; no clear lines of demarcation can be easily drawn to separate patient-centered care, health literacy, or other quality improvements from cultural competence. Interventions that focused solely on changing the patient (e.g., patient education and health promotion) were excluded because while they targeted a reduction in a health disparity experienced, they did not require change on the part of the physician or the health care system. We also excluded wellness and secondary disease prevention trials that did not target the formal health care delivery system or its providers. Those studies are, however, relevant to the larger discussion of reducing health disparities in this population.58-74

Only eight of the 25 included studies were conducted in the United States. This raises questions regarding transferability of the included studies to the U.S. health care system.

### Conclusions

The results of the search show a patchy literature set that highlights the intrapopulation diversity subsumed under the disability umbrella. The literature also fails to recognize the intersections of disability populations with other populations experiencing healthcare disparities. The broader concept of diversity competence may be more appropriate for many people at these intersections. Further discussion of population intersectionality and alternative constructions of cultural competence that address structural inequities can be found in Chapter 5. None of the included studies measured the effect of cultural competence interventions on health care disparities. The medium or high risk of bias of the included studies, the heterogeneity of populations, and the lack of measurement consensus prohibited pooling estimates or commenting about efficacy in a meaningful or responsible way.