# Description and Characteristics of Included Studies

Appendix Table D1 Description and characteristics of included studies—disability populations

Appendix Table D2 Risk of bias for cultural competence interventions targeting persons with disabilities

Appendix Table D3 Description and characteristics of included studies—LGBT

Appendix Table D4 Risk of bias for cultural competence interventions targeting gender and sexual minorities

Appendix Table D5 Risk of bias for cultural competence interventions targeting racial/ethnic minorities

Appendix Table D6 Map of studies included in Truong 2014 review of systematic reviews, with focus on provider training—racial/ethnic populations

Appendix Table D7 Quality of previous systematic reviews—racial/ethnic populations

Appendix Table D8 Outcomes reported by studies of cultural competence interventions for racial/ethnic minority populations

## References for Appendix D

1 Bannatyne A, Stapleton P. Educating medical students about anorexia nervosa: A potential method for reducing the volitional stigma associated with the disorder. Eating Disorders: The Journal of Treatment & Prevention. 2015;23(2):115-33. [pmid: 10640266].
2 Clement S, van Nieuwenhuizen A, Kassam A, et al. Filmed v. live social contact interventions to reduce stigma: randomised controlled trial. Br J Psychiatry. Jul. 2012;201(1):57-64. [pmid: 22157800].
3 Cutler JL, Harding KJ, Hutner LA, et al. Reducing medical students' stigmatization of people with chronic mental illness: a field intervention at the “living museum” state hospital art studio. Acad Psychiatry. May. 1. 2012;36(3):191-6. [pmid: 22751820].
4 Domenech J, Sanchez-Zuriaga D, Segura-Orti E, et al. Impact of biomedical and biopsychosocial training sessions on the attitudes, beliefs, and recommendations of health care providers about low back pain: a randomised clinical trial. Pain. Nov. 2011;152(11):2557-63. [pmid: 21917377].
5 Friedrich B, Evans-Lacko S, London J, et al. Anti-stigma training for medical students: the Education Not Discrimination project. Br J Psychiatry Suppl. Apr. 2013;55:s89-94. [pmid: 23553700].
6 Goddard L, Jordan L. Changing attitudes about persons with disabilities: effects of a simulation. J Neurosci Nurs. Oct. 1998;30(5):307-13. [pmid: 9816562].
7 Kassam A, Glozier N, Leese M, et al. A controlled trial of mental illness related stigma training for medical students. BMC Med Educ. 2011;11:51. [pmid: 21801355].
8 Kirby RL, Crawford KA, Smith C, et al. A wheelchair workshop for medical students improves knowledge and skills: a randomized controlled trial. Am J Phys Med Rehabil. Mar. 2011;90(3):197-206. [pmid: 21273901].
9 Melville CA, Cooper SA, Morrison J, et al. The outcomes of an intervention study to reduce the barriers experienced by people with intellectual disabilities accessing primary health care services. J Intellect Disabil Res. Jan. 2006;50(Pt 1):11-7. [pmid: 16316426].
10 Meurs D, Rutten M, de Jongh A. Does information about patients who are intellectually disabled translate into better cooperation during dental visits?. Spec Care Dentist. Sep-Oct. 2010;30(5):200-5. [pmid: 20831738].
11 Michaels PJ, Corrigan PW, Buchholz B, et al. Changing stigma through a consumer-based stigma reduction program. Community Ment Health J. May. 2014;50(4):395-401. [pmid: 23760975].
12 Munro A, Watson HE, McFadyen A. Assessing the impact of training on mental health nurses' therapeutic attitudes and knowledge about co-morbidity: a randomised controlled trial. Int J Nurs Stud. Nov. 2007;44(8):1430-8. [pmid: 16996517].
13 Nguyen E, Chen TF, O'Reilly CL. Evaluating the impact of direct and indirect contact on the mental health stigma of pharmacy students. Soc Psychiatry Psychiatr Epidemiol. Jul. 2012;47(7):1087-98. [pmid: 21755345].
14 O'Reilly CL, Bell JS, Kelly PJ, et al. Impact of mental health first aid training on pharmacy students' knowledge, attitudes and self-reported behaviour: a controlled trial. Aust N Z J Psychiatry. Jul. 2011;45(7):549-57. [pmid: 21718124].
15 Papish A, Kassam A, Modgill G, et al. Reducing the stigma of mental illness in undergraduate medical education: a randomized controlled trial. BMC Med Educ. 2013;13:141. [pmid: 24156397].
16 Patten SB, Remillard A, Phillips L, et al. Effectiveness of contact-based education for reducing mental illness-related stigma in pharmacy students. BMC Med Educ. 2012;12:120. [pmid: 23216787].
17 Symons AB, Morley CP, McGuigan D, et al. A curriculum on care for people with disabilities: effects on medical student self-reported attitudes and comfort level. Disabil Health J. Jan. 2014;7(1):88-95. [pmid: 24411512].
18 Lennox N, Bain C, Rey-Conde T, et al. Effects of a comprehensive health assessment programme for Australian adults with intellectual disability: a cluster randomized trial. Int J Epidemiol. Feb. 2007;36(1):139-46. [pmid: 17218326].
19 Peterson JJ, Suzuki R, Walsh ES, et al. Improving cancer screening among women with mobility impairments: randomized controlled trial of a participatory workshop intervention. Am J Health Promot. Mar-Apr. 2012;26(4):212-6. [pmid: 22375570].
20 Turk V, Burchell S, Burrha S, et al. An Evaluation of the Implementation of Hand Held Health Records with Adults with Learning Disabilities: A Cluster Randomized Controlled Trial. J Appl Res Intellect Disabil. 2010;23(2):100-11.
21 Wolraich ML, Bickman L, Lambert EW, et al. Intervening to improve communication between parents, teachers, and primary care providers of children with ADHD or at high risk for ADHD. J Atten Disord. Aug. 2005;9(1):354-68. [pmid: 16371681].
22 Bombardier CH, Bell KR, Temkin NR, et al. The efficacy of a scheduled telephone intervention for ameliorating depressive symptoms during the first year after traumatic brain injury. J Head Trauma Rehabil. Jul-Aug. 2009;24(4):230-8. [pmid: 19625862].
23 Finlayson M, Preissner K, Cho C, et al. Randomized trial of a teleconference-delivered fatigue management program for people with multiple sclerosis. Mult Scler. Sep. 2011;17(9):1130-40. [pmid: 21561960].
24 Knaevelsrud C, Maercker A. Internet-based treatment for PTSD reduces distress and facilitates the development of a strong therapeutic alliance: a randomized controlled clinical trial. BMC Psychiatry. 2007;7(1):13. PMID:. [doi: 10.1186/1471-244X-7-13]. [pmid: 17442125].
25 Shigaki CL, Smarr KL, Siva C, et al. RAHelp: an online intervention for individuals with rheumatoid arthritis. Arthritis Care Res (Hoboken). Oct. 2013;65(10):1573-81. [pmid: 23666599].
26 Bowen DJ, Powers D, Greenlee H. Effects of breast cancer risk counseling for sexual minority women. Health Care Women Int. Jan. 2006;27(1):59-74. [pmid: 16338740].
27 Blas MM, Alva IE, Carcamo CP, et al. Effect of an online video-based intervention to increase HIV testing in men who have sex with men in Peru. PLoS ONE. 2010;5(5):e10448. [pmid: 20454667].
28 Peck JA, Reback CJ, Yang X, et al. Sustained reductions in drug use and depression symptoms from treatment for drug abuse in methamphetamine-dependent gay and bisexual men. J Urban Health. Mar. 2005;82(1 Suppl 1):i100-8. [pmid: 15738315].
29 Shoptaw S, Reback CJ, Peck JA, et al. Behavioral treatment approaches for methamphetamine dependence and HIV-related sexual risk behaviors among urban gay and bisexual men. Drug Alcohol Depend. May. 9. 2005;78(2):125-34. [pmid: 15845315].
30 McKirnan DJ, Tolou-Shams M, Courtenay-Quirk C. The Treatment Advocacy Program: a randomized controlled trial of a peer-led safer sex intervention for HIV-infected men who have sex with men. J Consult Clin Psychol. Dec. 2010;78(6):952-63. [pmid: 20919760].
31 Marrazzo JM, Thomas KK, Ringwood K. A behavioural intervention to reduce persistence of bacterial vaginosis among women who report sex with women: results of a randomised trial. Sex Transm Infect. Aug. 2011;87(5):399-405. [pmid: 21653935].
32 Breitkopf CR, Dawson L, Grady JJ, et al. Intervention to improve follow-up for abnormal Papanicolaou tests: a randomized clinical trial. Health Psychol. Apr. 2014;33(4):307-16. [pmid: 23730719].
33 Bachmann LH, Grimley DM, Gao H, et al. Impact of a computer-assisted, provider-delivered intervention on sexual risk behaviors in HIV-positive men who have sex with men (MSM) in a primary care setting. AIDS Educ Prev. Apr. 2013;25(2):87-101. [pmid: 23514077].
34 Patel P, Bush T, Mayer K, et al. Routine brief risk-reduction counseling with biannual STD testing reduces STD incidence among HIV-infected men who have sex with men in care. Sex Transm Dis. Jun. 2012;39(6):470-4. [pmid: 22592834].
35 Kelley L, Chou CL, Dibble SL, et al. A critical intervention in lesbian, gay, bisexual, and transgender health: knowledge and attitude outcomes among second-year medical students. Teach Learn Med. Jul-Sep. 2008;20(3):248-53. [pmid: 18615300].
36 McGarry KA, Clarke JG, Cyr MG, et al. Evaluating a lesbian and gay health care curriculum. Teach Learn Med. 2002;14(4):244-8. [pmid: 12395487].
37 Beagan BL. Teaching social and cultural awareness to medical students: “it's all very nice to talk about it in theory, but ultimately it makes no difference”. Acad Med. Jun. 2003;78(6):605-14. [pmid: 12805041].
38 Alegria M, Carson N, Flores M, et al. Activation, self-management, engagement, and retention in behavioral health care: a randomized clinical trial of the DECIDE intervention. JAMA Psychiatry. May. 2014;71(5):557-65. [pmid: 24647680].
39 Cooper LA, Ghods Dinoso BK, Ford DE, et al. Comparative effectiveness of standard versus patient-centered collaborative care interventions for depression among African Americans in primary care settings: the BRIDGE Study. Health Serv Res. Feb. 2013;48(1):150-74. [pmid: 22716199].
40 Penner LA, Gaertner S, Dovidio JF, et al. A social psychological approach to improving the outcomes of racially discordant medical interactions. J Gen Intern Med. Sep. 2013;28(9):1143-9. [pmid: 23377843].
41 Aragones A, Schwartz MD, Shah NR, et al. A randomized controlled trial of a multilevel intervention to increase colorectal cancer screening among Latino immigrants in a primary care facility. J Gen Intern Med. Jun. 2010;25(6):564-7. [pmid: 20213208].
42 Michalopoulou G, Falzarano P, Arfken C, et al. Implementing Ask Me 3 to improve African American patient satisfaction and perceptions of physician cultural competency. J Cult Divers. 2010;17(2):62-7. [pmid: 20586368].
43 Alegria M, Polo A, Gao S, et al. Evaluation of a patient activation and empowerment intervention in mental health care. Medical Care. Mar. 2008;46(3):247-56. [pmid: 18388839].
44 Kim SS, Kim SH, Fang H, et al. A culturally adapted smoking cessation intervention for Korean Americans: a mediating effect of perceived family norm toward quitting. Journal of Immigrant and Minority Health. 2014:1-10. [pmid: 23054547].
45 Smith SS, Rouse LM, Caskey M, et al. Culturally tailored smoking cessation for adult American Indian smokers: A clinical trial. The Counseling Psychologist. 42. 6. 2014;42(6):852-86. PMID. [pmid: 26973352].
46 Calsyn DA, Burlew AK, Hatch-Maillette MA, et al. An HIV prevention intervention for ethnically diverse men in substance abuse treatment: pilot study findings. Am J Public Health. May. 2013;103(5):896-902. [pmid: 23488494].
47 Le H, Wong S, Iftikar T, et al. Characterization of factors affecting attainment of glycemic control in Asian Americans with diabetes in a culturally specific program. Diabetes Educ. Jul-Aug. 2013;39(4):468-77. [pmid: 23771841].
48 Lee CS, Lopez SR, Colby SM, et al. Culturally adapted motivational interviewing for Latino heavy drinkers: results from a randomized clinical trial. J Ethn Subst Abuse. 2013;12(4):356-73. [pmid: 24215227].
49 Burrow-Sanchez JJ, Wrona M. Comparing culturally accommodated versus standard group CBT for Latino adolescents with substance use disorders: a pilot study. Cultur Divers Ethni Minor Psychol. Oct. 2012;18(4):373-83. [pmid: 22866693].
50 Ell K, Katon W, Xie B, et al. One-year postcollaborative depression care trial outcomes among predominantly Hispanic diabetes safety net patients. Gen Hosp Psychiatry. Sep-Oct. 2011;33(5):436-42. [pmid: 21774987].
51 Pan D, Huey SJ Jr., Hernandez D. Culturally adapted versus standard exposure treatment for phobic Asian Americans: Treatment efficacy, moderators, and predictors. Cultur Divers Ethni Minor Psychol. Jan. 2011;17(1):11-22. [pmid: 21341893].
52 D'Eramo Melkus G, Chyun D, Vorderstrasse A, et al. The effect of a diabetes education, coping skills training, and care intervention on physiological and psychosocial outcomes in black women with type 2 diabetes. Biol Res Nurs. Jul. 2010;12(1):7-19. [pmid: 20484058].
53 Marsiglia FF, Bermudez-Parsai M, Coonrod D. Familias Sanas: an intervention designed to increase rates of postpartum visits among Latinas. J Health Care Poor Underserved. Aug. 2010;21(3 Suppl):119-31. [pmid: 20675950].
54 Kohn LP, Oden T, Munoz RF, et al. Adapted cognitive behavioral group therapy for depressed low-income African American women. Community Ment Health J. Dec. 2002;38(6):497-504. [pmid: 12474937].
55 Anderson LM, Scrimshaw SC, Fullilove MT, et al. Culturally competent healthcare systems. A systematic review. Am J Prev Med. Apr. 2003;24(3 Suppl):68-79. [pmid: 12668199].
56 Beach MC, Price EG, Gary TL, et al. Cultural competence: a systematic review of health care provider educational interventions. Medical Care. Apr. 2005;43(4):356-73. [pmid: 15778639].
57 Bhui K, Warfa N, Edonya P, et al. Cultural competence in mental health care: a review of model evaluations. BMC Health Serv Res. 2007;7:15. [pmid: 17266765].
58 Chipps JA, Simpson B, Brysiewicz P. The effectiveness of cultural-competence training for health professionals in community-based rehabilitation: a systematic review of literature. Worldviews Evid Based Nurs. 2008;5(2):85-94. [pmid: 18559021].
59 Downing R, Kowal E, Paradies Y. Indigenous cultural training for health workers in Australia. Int J Qual Health Care. Jun. 2011;23(3):247-57. [pmid: 21467076].
60 Fisher TL, Burnet DL, Huang ES, et al. Cultural leverage: interventions using culture to narrow racial disparities in health care. Med Care Res Rev. Oct. 2007;64(5 Suppl):243S-82S. [pmid: 17881628].
61 Forsetlund L, Eike MC, Vist GE. Effect of interventions to improve health care services for ethnic minority populations. Norsk epidemiologi. 2010;20(1):41-52.
62 Harun A, Harrison JD, Young JM. Interventions to improve patient participation in the treatment process for culturally and linguistically diverse people with cancer: a systematic review. Asia Pac J Clin Oncol. Jun. 2013;9(2):99-109. [pmid: 22897920].
63 Attridge M, Creamer J, Ramsden M, Cannings-John R, Hawthorne K. Culturally appropriate health education for people in ethnic minority groups with type 2 diabetes mellitus. 2014.
64 Henderson S, Kendall E, See L. The effectiveness of culturally appropriate interventions to manage or prevent chronic disease in culturally and linguistically diverse communities: a systematic literature review. Health Soc Care Community. May. 2011;19(3):225-49. [pmid: 21208326].
65 Kehoe KA, Melkus GD, Newlin K. Culture within the context of care: an integrative review. Ethn Dis. 2003;13(3):344-53. [pmid: 12894959].
66 Kokko R. Future nurses' cultural competencies: what are their learning experiences during exchange and studies abroad? A systematic literature review. J Nurs Manag. Jul. 2011;19(5):673-82. [pmid: 21749541].
67 Lie DA, Lee-Rey E, Gomez A, et al. Does cultural competency training of health professionals improve patient outcomes? A systematic review and proposed algorithm for future research. J Gen Intern Med. Mar. 2011;26(3):317-25. [pmid: 20953728].
68 Lu M, Moritz S, Lorenzetti D, et al. A systematic review of interventions to increase breast and cervical cancer screening uptake among Asian women. BMC Public Health. 2012;12:413. [pmid: 22676147].
69 McQuilkin D. Transcultural nursing clinical education: a systematic review of the literature since 2005 with recommendations for international immersion clinical courses. 2012.
70 Pearson A, Srivastava R, Craig D, et al. Systematic review on embracing cultural diversity for developing and sustaining a healthy work environment in healthcare. International Journal of Evidence-Based Healthcare. Mar. 2007;5(1):54-91. [pmid: 21631782].
71 Smith TB, Constantine MG, Dunn TW, et al. Multicultural education in the mental health professions: A meta-analytic review. J Couns Psychol. 2006;53(1):132.
72 Sumlin LL, Garcia AA. Effects of food-related interventions for African American women with type 2 diabetes. Diabetes Educ. Mar-Apr. 2012;38(2):236-49. [pmid: 22454408].
73 Whittemore R. Culturally competent interventions for Hispanic adults with type 2 diabetes: a systematic review. J Transcult Nurs. Apr. 2007;18(2):157-66. [pmid: 17416718].
74 Horvat L, Horey D, Romios P, et al. Cultural competence education for health professionals. Cochrane Database Syst Rev. 2014;5. CD009405. [pmid: 24793445].
75 Truong M, Paradies Y, Priest N. Interventions to improve cultural competency in healthcare: a systematic review of reviews. BMC Health Serv Res. 2014;14:99. [pmid: 24589335].