# Excluded Studies

## Disability Populations

### Full Text—Care Coordination/Patient Centered Care (5)

1 Bauer MS, McBride L, Williford WO, et al. Collaborative care for bipolar disorder: Part II. Impact on clinical outcome, function, and costs. Psychiatric Services. Jul. 2006;57(7):937-45. [pmid: 16816277].
2 Bickman L, Summerfelt WT, Noser K. Comparative outcomes of emotionally disturbed children and adolescents in a system of services and usual care. Psychiatric Services. Dec. 1997;48(12):1543-8. [pmid: 9406261].
3 Crowley R, Wolfe I, Lock K, et al. Improving the transition between paediatric and adult healthcare: a systematic review. Archives of Disease in Childhood. Jun. 2011;96(6):548-53. [pmid: 21388969].
4 Homer CJ, Klatka K, Romm D, et al. A review of the evidence for the medical home for children with special health care needs. Pediatrics. Oct. 2008;122(4):e922-37. [pmid: 18829788].
5 Kolko DJ, Campo JV, Kilbourne AM, et al. Doctor-office collaborative care for pediatric behavioral problems: a preliminary clinical trial. Archives of Pediatrics & Adolescent Medicine. Mar. 2012;166(3):224-31. [pmid: 22064876].

### Full Text—Descriptive/No Intervention (7)

1 Arvaniti A, Samakouri M, Kalamara E, et al. Health service staff's attitudes towards patients with mental illness. Social Psychiatry and Psychiatric Epidemiology. 2009;44(8):658-665. [pmid: 19082905].
2 Berman BA, Jo A, Cumberland WG, et al. Breast cancer knowledge and practices among D/deaf women. Disability and Health Journal. 2013;6(4):303-316. [pmid: 24060253].
3 Handler EG, Bhardwaj A, Jackson DS. Medical students' and allied health care professionals' perceptions toward the mentally retarded population. Journal of Developmental and Physical Disabilities. 1994;6(3):291-297.
4 Kassam A, Glozier N, Leese M, et al. Development and responsiveness of a scale to measure clinicians attitudes to people with mental illness (medical student version). Acta Psychiatrica Scandinavica. 2010;122(2):153-161. [pmid: 20456286].
5 Mittal D, Corrigan P, Sherman MD, et al. Healthcare providers' attitudes toward persons with schizophrenia. Psychiatric Rehabilitation Journal. 2014;37(4):297-303. [pmid: 25313529].
6 Ryan TA, Scior K. Medical students' attitudes towards people with intellectual disabilities: a literature review. Research in Developmental Disabilities. Oct. 2014;35(10):2316-28. [pmid: 24952372].
7 ten Klooster PM, Dannenberg J-W, Taal E, et al. Attitudes towards people with physical or intellectual disabilities: Nursing students and non-nursing peers. Journal of Advanced Nursing. 2009;65(12):2562-2563. [pmid: 19941543].

### Full Text—Design Methods (9)

1 Bell JS, Johns R, Chen TF. Pharmacy students' and graduates' attitudes towards people with schizophrenia and severe depression. American Journal of Pharmaceutical Education. 2006;70(4):7. [pmid: 17136150].
2 Brooks E, Novins DK, Noe T, et al. Reaching rural communities with culturally appropriate care: A model for adapting remote monitoring to American Indian veterans with posttraumatic stress disorder. Telemedicine and e-Health. 2013;19(4):272-277. [pmid: 23451811].
3 Collie K, Kreshka MA, Ferrier S, et al. Videoconferencing for delivery of breast cancer support groups to women living in rural communities: A pilot study. Psycho-Oncology. 2007;16(8):778-782. [pmid: 17253594].
4 Commons Treloar AJ. Effectiveness of education programs in changing clinician's attitudes towards treating borderline personality disorder. Psychiatric Services. 2009;60(8):1128-1131. [pmid: 19648203].
5 Hawke LD, Michalak EE, Maxwell V, et al. Reducing stigma toward people with bipolar disorder: Impact of a filmed theatrical intervention based on a personal narrative. International Journal of Social Psychiatry. 2014;60(8):741-750. [pmid: 24351967].
6 Jones RG, Kerr MP. A randomized control trial of an opportunistic health screening tool in primary care for people with intellectual disability. Journal of Intellectual Disability Research. 1997;41(5):409-415. [pmid: 9373821].
7 Kerby J, Calton T, DiMambro B, et al. Anti-stigma films and medical students' attitudes towards mental illness and psychiatry: Randomised controlled trial. Psychiatric Bulletin. 2008;32(9):345-349.
8 Pernice R, Lys K. Interventions for attitude change towards people with disabilities: how successful are they?. International Journal of Rehabilitation Research. Jun. 1996;19(2):171-4. [pmid: 8842831].
9 Pittman JOE, Noh S, Coleman D. Evaluating the effectiveness of a consumer delivered anti-stigma program: replication with graduate-level helping professionals. Psychiatric Rehabilitation Journal. 2010;33(3):236-8. [pmid: 20061261].

### Full Text—No Formal System/Health Promotion (20)

1 Baker-Ericzen MJ, Mueggenborg MG, Shea MM. Impact of trainings on child care providers' attitudes and perceived competence toward inclusion: What factors are associated with change?. Topics in Early Childhood Special Education. 2009;28(4):196-208.
2 Bombardier CH, Cunniffe M, Wadhwani R, et al. The efficacy of telephone counseling for health promotion in people with multiple sclerosis: a randomized controlled trial. Archives of Physical Medicine & Rehabilitation. Oct. 2008;89(10):1849-56. [pmid: 18929012].
3 Brief DJ, Rubin A, Enggasser JL, et al. Web-based intervention for returning veterans with symptoms of posttraumatic stress disorder and risky alcohol use. Journal of Contemporary Psychotherapy. 2011;41(4):237-246. [pmid: 25378713].
4 Brown SH, Lewis CA, McCarthy JM, et al. The effects of Internet-based home training on upper limb function in adults with cerebral palsy. Neurorehabilitation & Neural Repair. Jul-Aug. 2010;24(6):575-83. [pmid: 20581338].
5 Carraro A, Gobbi E. Effects of an exercise programme on anxiety in adults with intellectual disabilities. Research in Developmental Disabilities. Jul-Aug. 2012;33(4):1221-6. [pmid: 22502848].
6 Faulks D, Hennequin M. Evaluation of a long-term oral health program by carers of children and adults with intellectual disabilities. Special Care in Dentistry. Sep-Oct. 2000;20(5):199-208. [pmid: 11203899].
7 Flatt-Fultz E, Phillips LA. Empowerment training and direct support professionals' attitudes about individuals with intellectual disabilities. Journal of Intellectual Disabilities. Jun. 2012;16(2):119-25. [pmid: 22491507].
8 Gephart EF, Loman DG. Use of prevention and prevention plus weight management guidelines for youth with developmental disabilities living in group homes. Journal of Pediatric Health Care. Mar-Apr. 2013;27(2):98-108. [pmid: 23414975].
9 Heller T, McCubbin JA, Drum C, et al. Physical activity and nutrition health promotion interventions: what is working for people with intellectual disabilities?. Intellectual & Developmental Disabilities. Feb. 2011;49(1):26-36. [pmid: 21338310].
10 Horner-Johnson W, Drum CE, Abdullah N. A randomized trial of a health promotion intervention for adults with disabilities. Disability & Health Journal. Oct. 2011;4(4):254-61. [pmid: 22014673].
11 Naaldenberg J, Kuijken N, van Dooren K, et al. Topics, methods and challenges in health promotion for people with intellectual disabilities: a structured review of literature. Research in Developmental Disabilities. Dec. 2013;34(12):4534-45. [pmid: 24161461].
12 Perez-Cruzado D, Cuesta-Vargas AI. Improving Adherence Physical Activity with a Smartphone Application Based on Adults with Intellectual Disabilities (APPCOID). BMC Public Health. 2013;13:1173. [pmid: 24330604].
13 Robinson-Whelen S, Hughes RB, Powers LE, et al. Efficacy of a computerized abuse and safety assessment intervention for women with disabilities: a randomized controlled trial. Rehabilitation Psychology. May. 2010;55(2):97-107. [pmid: 20496965].
14 Robinson-Whelen S, Hughes RB, Taylor HB, et al. Improving the health and health behaviors of women aging with physical disabilities: A peer-led health promotion program. Womens Health Issues. Nov-Dec. 2006;16(6):334-45. [pmid: 17188216].
15 Stuifbergen AK, Becker H, Blozis S, et al. A randomized clinical trial of a wellness intervention for women with multiple sclerosis. Archives of Physical Medicine & Rehabilitation. Apr. 2003;84(4):467-76. [pmid: 12690582].
16 Stuifbergen AK, Morris M, Jung JH, et al. Benefits of wellness interventions for persons with chronic and disabling conditions: a review of the evidence. Disability & Health Journal. Jul. 2010;3(3):133-45. [pmid: 20628583].
17 Verschuren O, Ketelaar M, Gorter JW, et al. Exercise training program in children and adolescents with cerebral palsy: a randomized controlled trial. Archives of Pediatrics & Adolescent Medicine. Nov. 2007;161(11):1075-81. [pmid: 17984410].
18 Verschuren O, Ketelaar M, Takken T, et al. Exercise programs for children with cerebral palsy: a systematic review of the literature. American Journal of Physical Medicine & Rehabilitation. May. 2008;87(5):404-17. [pmid: 17993987].
19 Wilson JAB, Wells MG. Telehealth and the deaf: a comparison study. Journal of Deaf Studies & Deaf Education. 2009;14(3):386-402. [pmid: 19398534].
20 Wu C-L, Lin J-D, Hu J, et al. The effectiveness of healthy physical fitness programs on people with intellectual disabilities living in a disability institution: six-month short-term effect. Research in Developmental Disabilities. May-Jun. 2010;31(3):713-7. [pmid: 20172687].

### Full Text—Provider Education Only (4)

1 Catteau C, Faulks D, Mishellany-Dutour A, et al. Using e-learning to train dentists in the development of standardised oral health promotion interventions for persons with disability. European Journal of Dental Education. Aug. 2013;17(3):143-53. [pmid: 23815691].
2 Estes JP, Deyer CA, Hansen RA, et al. Influence of occupational therapy curricula on students' attitudes toward persons with disabilities. American Journal of Occupational Therapy. Feb. 1991;45(2):156-9. [pmid: 1827951].
3 Spaite DW, Conroy C, Karriker KJ, et al. Improving emergency medical services for children with special health care needs: does training make a difference?. American Journal of Emergency Medicine. Oct. 2001;19(6):474-8. [pmid: 11593465].
4 Spaite DW, Karriker KJ, Conroy C, et al. Emergency medical services assessment and treatment of children with special health care needs before and after specialized paramedic training. Prehospital & Disaster Medicine. Apr-Jun. 2001;16(2):96-101. [pmid: 11513288].

### Full Text—Virtual Care/Not Access Focused (10)

1 Boisvert M, Lang R, Andrianopoulos M, et al. Telepractice in the assessment and treatment of individuals with autism spectrum disorders: A systematic review. Developmental Neurorehabilitation. 2010;13(6):423-432. [pmid: 20887200].
2 Bombardier CH, Bell KR, Temkin NR, et al. The efficacy of a scheduled telephone intervention for ameliorating depressive symptoms during the first year after traumatic brain injury. Journal of Head Trauma Rehabilitation. Jul-Aug. 2009;24(4):230-8. [pmid: 19625862].
3 Carey B, O'Brian S, Onslow M, et al. Randomized controlled non-inferiority trial of a telehealth treatment for chronic stuttering: The camperdown program. International Journal of Language & Communication Disorders. 2010;45(1):108-120. [pmid: 19424889].
4 Fortney JC, Pyne JM, Kimbrell TA, et al. “Telemedicine-based collaborative care for posttraumatic stress disorder: A randomized clinical trial”: Correction. JAMA Psychiatry. 2015;72(1):96.
5 Fortney JC, Pyne JM, Kimbrell TA, et al. Telemedicine-based collaborative care for posttraumatic stress disorder: A randomized clinical trial. JAMA Psychiatry. 2015;72(1):58-67. [pmid: 25409287].
6 Langan J, Delave K, Phillips L, et al. Home-based telerehabilitation shows improved upper limb function in adults with chronic stroke: a pilot study. Journal of Rehabilitation Medicine. Feb. 2013;45(2):217-20. [pmid: 23319181].
7 Morland LA, Greene CJ, Rosen CS, et al. Telemedicine for anger management therapy in a rural population of combat veterans with posttraumatic stress disorder: A randomized non inferiority trial. Journal of Clinical Psychiatry. 2010;71(7):855-863. [pmid: 20122374].
8 Morland LA, Mackintosh M-A, Greene CJ, et al. Cognitive processing therapy for posttraumatic stress disorder delivered to rural veterans via telemental health: A randomized noninferiority clinical trial. Journal of Clinical Psychiatry. 2014;75(5):470-476. [pmid: 24922484].
9 van den Berg MH, Ronday HK, Peeters AJ, et al. Using internet technology to deliver a home-based physical activity intervention for patients with rheumatoid arthritis: A randomized controlled trial. Arthritis & Rheumatism. Dec. 15. 2006;55(6):935-45. [pmid: 17139640].
10 Yuen HK. Effect of a home telecare program on oral health among adults with tetraplegia: a pilot study. Spinal Cord. Jun. 2013;51(6):477-81. [pmid: 23318557].

## Lesbian, Gay, Bisexual, and Transgender Populations

### Full Text—Design/Descriptive (27)

1 Beverly A. Transforming the nursing curriculum: integrating concepts of gender, race, class, and ethnicity. Deans Notes. Mar. 1992;13(4):1-3. [pmid: 1563112].
2 Bonvicini KA, Perlin MJ. The same but different: clinician-patient communication with gay and lesbian patients. Patient Education & Counseling. Oct. 2003;51(2):115-22. [pmid: 14572940].
3 Brennan AMW, Barnsteiner J, Siantz MLdL, et al. Lesbian, gay, bisexual, transgendered, or intersexed content for nursing curricula. Journal of Professional Nursing. Mar-Apr. 2012;28(2):96-104. [pmid: 22459139].
4 Brondani MA, Paterson R. Teaching lesbian, gay, bisexual, and transgender issues in dental education: a multipurpose method. Journal of Dental Education. Oct. 2011;75(10):1354-61. [pmid: 22012779].
5 Celik H, Lagro-Janssen TALM, Widdershoven GGAM, et al. Bringing gender sensitivity into healthcare practice: a systematic review. Patient Education & Counseling. Aug. 2011;84(2):143-9. [pmid: 20719461].
6 Chervin M, Brotman S, Ryan B, et al. Transforming schools of social work into spaces of social action: a critical exploration of Project Interaction, The Gay, Lesbian, Bisexual and Two-Spirit Initiative of McGill University's School of Social Work. Canadian Journal of Community Mental Health. 2003;22(2):69-84. [pmid: 15868839].
7 Chu J, Floyd R, Diep H, et al. A tool for the culturally competent assessment of suicide: the Cultural Assessment of Risk for Suicide (CARS) measure. Psychological Assessment. Jun. 2013;25(2):424-34. [pmid: 23356681].
8 Corliss HL, Shankle MD, Moyer MB. Research, curricula, and resources related to lesbian, gay, bisexual, and transgender health in US schools of public health. American Journal of Public Health. Jun. 2007;97(6):1023-7. [pmid: 17463373].
9 Cramer EP. Effects of an educational unit about lesbian identity development and disclosure in a social work methods course. Journal of Social Work Education. 1997;33(3):461-472.
10 Diamond GM, Diamond GS, Levy S, et al. Attachment-based family therapy for suicidal lesbian, gay, and bisexual adolescents: A treatment development study and open trial with preliminary findings. Psychotherapy. Mar. 2012;49(1):62-71. [pmid: 22181026].
11 Diamond GM, Diamond GS, Levy S, et al. Attachment-based family therapy for suicidal lesbian, gay, and bisexual adolescents: A treatment development study and open trial with preliminary findings. Psychology of Sexual Orientation and Gender Diversity. Aug. 2013;1(S):91-100.
12 Dibble SL, Roberts SA. Improving cancer screening among lesbians over 50: results of a pilot study. Oncology Nursing Forum. Jul-Aug. 2003;30(4):E71-9. [pmid: 12861329].
13 Eliason MJ. Working with lesbian, gay, and bisexual people. Reducing negative stereotypes via inservice education. Journal of Nursing Staff Development. May-Jun. 1996;12(3):127-32. [pmid: 8716410].
14 Godfrey K, Haddock SA, Fisher A, et al. Essential components of curricula for preparing therapists to work effectively with lesbian, gay, and bisexual clients: a Delphi study. Journal of Marital & Family Therapy. Oct. 2006;32(4):491-504. [pmid: 17120521].
15 Katz KA, Furnish TJ. Dermatology-related epidemiologic and clinical concerns of men who have sex with men, women who have sex with women, and transgender individuals. Archives of Dermatology. Oct. 2005;141(10):1303-10. [pmid: 16230569].
16 Lim FA, Bernstein I. Promoting awareness of LGBT issues in aging in a baccalaureate nursing program. Nursing Education Perspectives. May-Jun. 2012;33(3):170-5. [pmid: 22860480].
17 Lombardi EL, van Servellen G. Building culturally sensitive substance use prevention and treatment programs for transgendered populations. Journal of Substance Abuse Treatment. Oct. 2000;19(3):291-6. [pmid: 11027900].
18 Long JK, Serovich JM. Incorporating sexual orientation into MFT training programs: infusion and inclusion. Journal of Marital & Family Therapy. Jan. 2003;29(1):59-67. [pmid: 12616799].
19 Mayer K, Appelbaum J, Rogers T, et al. The evolution of the Fenway Community Health model. American Journal of Public Health. Jun. 2001;91(6):892-4. [pmid: 11392929].
20 McNair R. Outing lesbian health in medical education. Women & Health. 2003;37(4):89-103. [pmid: 12956216].
21 Obedin-Maliver J, Goldsmith ES, Stewart L, et al. Lesbian, gay, bisexual, and transgender-related content in undergraduate medical education. JAMA. Sep. 7. 2011;306(9):971-7. [pmid: 21900137].
22 Robinson G, Cohen M. Gay, lesbian and bisexual health care issues and medical curricula. CMAJ Canadian Medical Association Journal. Sep. 15. 1996;155(6):709-11. [pmid: 8823216].
23 Sansone RA, Wiederman MW. Sexuality training for psychiatry residents: a national survey of training directors. Journal of Sex & Marital Therapy. Jul-Sep. 2000;26(3):249-56. [pmid: 10929573].
24 Shindel AW, Parish SJ. Sexuality education in North American medical schools: current status and future directions. Journal of Sexual Medicine. Jan. 2013;10(1):3-17. quiz 8. [pmid: 23343168].
25 Tamas RL, Miller KH, Martin LJ, et al. Addressing patient sexual orientation in the undergraduate medical education curriculum. Academic Psychiatry. Sep-Oct. 2010;34(5):342-5. [pmid: 20833902].
26 Townsend MH, Wallick MM, Pleak RR, et al. Gay and lesbian issues in child and adolescent psychiatry training as reported by training directors. Journal of the American Academy of Child & Adolescent Psychiatry. Jun. 1997;36(6):764-8. [pmid: 9183130].
27 Winston EJ, Piercy FP. Gender and diversity topics taught in Commission on Accreditation for Marriage and Family Therapy Education programs. Journal of Marital & Family Therapy. Oct. 2010;36(4):446-71. [pmid: 21039658].

### Full Text –Descriptive/No Intervention (12)

1 Austin SB, Pazaris MJ, Nichols LP, et al. An examination of sexual orientation group patterns in mammographic and colorectal screening in a cohort of U.S. women. Cancer Causes & Control. Mar. 2013;24(3):539-47. [pmid: 22729931].
2 Bailey JV, Kavanagh J, Owen C, et al. Lesbians and cervical screening. British Journal of General Practice. Jun. 2000;50(455):481-2. [pmid: 10962789].
3 Boehmer U, Miao X, Ozonoff A. Cancer survivorship and sexual orientation. Cancer. Aug. 15. 2011;117(16):3796-804. [pmid: 21557209].
4 Burnett CB, Steakley CS, Slack R, et al. Patterns of breast cancer screening among lesbians at increased risk for breast cancer. Women & Health. 1999;29(4):35-55. [pmid: 10608668].
5 Jin H, Earnshaw VA, Wickersham JA, et al. An assessment of health-care students' attitudes toward patients with or at high risk for HIV: implications for education and cultural competency. AIDS Care. 2014;26(10):1223-8. [pmid: 24625279].
6 McManus AJ, Hunter LP, Renn H. Lesbian experiences and needs during childbirth: guidance for health care providers. JOGNN - Journal of Obstetric, Gynecologic, & Neonatal Nursing. Jan-Feb. 2006;35(1):13-23. [pmid: 16466349].
7 Meads C, Moore D. Breast cancer in lesbians and bisexual women: systematic review of incidence, prevalence and risk studies. BMC Public Health. 2013;13:1127. [pmid: 24313963].
8 Moll J, Krieger P, Moreno-Walton L, et al. The prevalence of lesbian, gay, bisexual, and transgender health education and training in emergency medicine residency programs: what do we know?. Academic Emergency Medicine. May. 2014;21(5):608-11. [pmid: 24842513].
9 Mujawar I, Sabatino M, Ray Mitchell S, et al. A 12-year comparison of students' perspectives on diversity at a Jesuit Medical School. Medical Education Online. 2014;19:23401. [pmid: 24581334].
10 Roberts SJ. Health care recommendations for lesbian women. JOGNN - Journal of Obstetric, Gynecologic, & Neonatal Nursing. Sep-Oct. 2006;35(5):583-91. [pmid: 16958713].
11 Shields L, Zappia T, Blackwood D, et al. Lesbian, gay, bisexual, and transgender parents seeking health care for their children: a systematic review of the literature. Worldviews on Evidence-Based Nursing. Dec. 2012;9(4):200-9. [pmid: 22646981].
12 Simpson TL, Balsam KF, Cochran BN, et al. Veterans administration health care utilization among sexual minority veterans. Psychological Services. May. 2013;10(2):223-32. [pmid: 23730965].

### Full Text—HIV Focused (8)

1 Carrico AW, Nation A, Gomez W, et al. Pilot trial of an expressive writing intervention with HIV-positive methamphetamine-using men who have sex with men. Psychology of Addictive Behaviors. Jun. 2015;29(2):277-82. [pmid: 25437153].
2 Fals-Stewart W, O'Farrell TJ, Lam WKK. Behavioral couple therapy for gay and lesbian couples with alcohol use disorders. Journal of Substance Abuse Treatment. Dec. 2009;37(4):379-87. [pmid: 19553063].
3 Gayner B, Esplen MJ, DeRoche P, et al. A randomized controlled trial of mindfulness-based stress reduction to manage affective symptoms and improve quality of life in gay men living with HIV. Journal of Behavioral Medicine. Jun. 2012;35(3):272-85. [pmid: 21597980].
4 Grossman S, Wheeler K, Lippman D. Role-modeling experience improves nursing students' attitudes toward people living with AIDS. Nursingconnections. 1998;11(1):41-9. [pmid: 9644480].
5 Kemppainen JK, Dubbert PM, McWilliams P. Effects of group discussion and guided patient care experience on nurses' attitudes towards care of patients with AIDS. Journal of Advanced Nursing. Aug. 1996;24(2):296-302. [pmid: 8858433].
6 Mulder CL, Antoni MH, Emmelkamp PM, et al. Psychosocial group intervention and the rate of decline of immunological parameters in asymptomatic HIV-infected homosexual men. Psychotherapy & Psychosomatics. 1995;63(3-4):185-92. [pmid: 7624465].
7 Mulder CL, Emmelkamp PM, Antoni MH, et al. Cognitive-behavioral and experiential group psychotherapy for HIV-infected homosexual men: a comparative study. Psychosomatic Medicine. Sep-Oct. 1994;56(5):423-31. [pmid: 7809342].
8 Velasquez MM, von Sternberg K, Johnson DH, et al. Reducing sexual risk behaviors and alcohol use among HIV-positive men who have sex with men: A randomized clinical trial. Journal of Consulting and Clinical Psychology. Aug. 2009;77(4):657-67. [pmid: 19634959].

### Full Text—Individualized/Patient Centered Care (4)

1 Chesney MA, Koblin BA, Barresi PJ, et al. An individually tailored intervention for HIV prevention: baseline data from the EXPLORE Study. American Journal of Public Health. Jun. 2003;93(6):933-8. [pmid: 12773358].
2 Gore-Felton C, Rotheram-Borus MJ, Weinhardt LS, et al. The Healthy Living Project: an individually tailored, multidimensional intervention for HIV-infected persons. AIDS Education & Prevention. Feb. 2005;17(1 Suppl A):21-39. [pmid: 15843115].
3 Safren SA, O'Cleirigh CM, Skeer M, et al. Project enhance: a randomized controlled trial of an individualized HIV prevention intervention for HIV-infected men who have sex with men conducted in a primary care setting. Health Psychology. Feb. 2013;32(2):171-9. [pmid: 22746262].
4 Schwarcz SK, Chen Y-H, Murphy JL, et al. A randomized control trial of personalized cognitive counseling to reduce sexual risk among HIV-infected men who have sex with men. AIDS Care. 2013;25(1):1-10. [pmid: 22568569].

### Full Text—No Formal System (32)

1 Bowen AM, Horvath K, Williams ML. A randomized control trial of Internet-delivered HIV prevention targeting rural MSM. Health Education Research. Feb. 2007;22(1):120-7. [pmid: 16849391].
2 Bowen AM, Williams ML, Daniel CM, et al. Internet based HIV prevention research targeting rural MSM: feasibility, acceptability, and preliminary efficacy. Journal of Behavioral Medicine. Dec. 2008;31(6):463-77. [pmid: 18770021].
3 Carpenter KM, Stoner SA, Mikko AN, et al. Efficacy of a web-based intervention to reduce sexual risk in men who have sex with men. AIDS & Behavior. Jun. 2010;14(3):549-57. [pmid: 19499321].
4 Chesney MA, Chambers DB, Taylor JM, et al. Coping effectiveness training for men living with HIV: results from a randomized clinical trial testing a group-based intervention. Psychosomatic Medicine. Nov-Dec. 2003;65(6):1038-46. [pmid: 14645783].
5 Christensen JL, Miller LC, Appleby PR, et al. Reducing shame in a game that predicts HIV risk reduction for young adult MSM: a randomized trial delivered nationally over the Web. Journal of the International AIDS Society. 2013;16(3 Suppl 2):18716. [pmid: 24242264].
6 Dilley JW, Woods WJ, Loeb L, et al. Brief cognitive counseling with HIV testing to reduce sexual risk among men who have sex with men: results from a randomized controlled trial using paraprofessional counselors. Journal of Acquired Immune Deficiency Syndromes: JAIDS. Apr. 15. 2007;44(5):569-77. [pmid: 17310937].
7 Dilley JW, Woods WJ, Sabatino J, et al. Changing sexual behavior among gay male repeat testers for HIV: a randomized, controlled trial of a single-session intervention. Journal of Acquired Immune Deficiency Syndromes: JAIDS. Jun. 1. 2002;30(2):177-86. [pmid: 12045680].
8 Harawa NT, Williams JK, McCuller WJ, et al. Efficacy of a culturally congruent HIV risk-reduction intervention for behaviorally bisexual black men: results of a randomized trial. AIDS. Jul. 31. 2013;27(12):1979-88. [pmid: 24180003].
9 Hirshfield S, Chiasson MA, Joseph H, et al. An online randomized controlled trial evaluating HIV prevention digital media interventions for men who have sex with men. PLoS ONE. [Electronic Resource]. 2012;7(10):e46252. [pmid: 23071551].
10 Horvath KJ, Oakes JM, Rosser BRS, et al. Feasibility, acceptability and preliminary efficacy of an online peer-to-peer social support ART adherence intervention. AIDS & Behavior. Jul. 2013;17(6):2031-44. [pmid: 23553347].
11 Imrie J, Stephenson JM, Cowan FM, et al. A cognitive behavioural intervention to reduce sexually transmitted infections among gay men: randomised trial. BMJ. Jun. 16. 2001;322(7300):1451-6. [pmid: 11408300].
12 Kelly JA, Murphy DA, Sikkema KJ, et al. Randomised, controlled, community-level HIV-prevention intervention for sexual-risk behaviour among homosexual men in US cities. Community HIV Prevention Research Collaborative. Lancet. Nov. 22. 1997;350(9090):1500-5. [pmid: 9388397].
13 Koblin B, Chesney M, Coates T, et al. Effects of a behavioural intervention to reduce acquisition of HIV infection among men who have sex with men: the EXPLORE randomised controlled study. Lancet. Jul. 3-9. 2004;364(9428):41-50. [pmid: 15234855].
14 Koblin BA, Bonner S, Powell B, et al. A randomized trial of a behavioral intervention for black MSM: the DiSH study. AIDS. Feb. 20. 2012;26(4):483-8. [pmid: 22156967].
15 Kurtz SP, Stall RD, Buttram ME, et al. A randomized trial of a behavioral intervention for high risk substance-using MSM. AIDS & Behavior. Nov. 2013;17(9):2914-26. [pmid: 23732957].
16 Lau JTF, Lau M, Cheung A, et al. A randomized controlled study to evaluate the efficacy of an Internet-based intervention in reducing HIV risk behaviors among men who have sex with men in Hong Kong. AIDS Care. Aug. 2008;20(7):820-8. [pmid: 18608057].
17 Lau JTF, Tsui HY, Lau MMC. A pilot clustered randomized control trial evaluating the efficacy of a network-based HIV peer-education intervention targeting men who have sex with men in Hong Kong, China. AIDS Care. 2013;25(7):812-9. [pmid: 23244706].
18 Lin Y-J, Israel T. A computer-based intervention to reduce internalized heterosexism in men. Journal of Counseling Psychology. Jul. 2012;59(3):458-64. [pmid: 22545801].
19 Mausbach BT, Semple SJ, Strathdee SA, et al. Efficacy of a behavioral intervention for increasing safer sex behaviors in HIV-positive MSM methamphetamine users: results from the EDGE study. Drug & Alcohol Dependence. Mar. 16. 2007;87(2-3):249-57. [pmid: 17182196].
20 Mimiaga MJ, Reisner SL, Pantalone DW, et al. A pilot trial of integrated behavioral activation and sexual risk reduction counseling for HIV-uninfected men who have sex with men abusing crystal methamphetamine. AIDS Patient Care & Stds. Nov. 2012;26(11):681-93. [pmid: 23030605].
21 Rosser BRS, Bockting WO, Rugg DL, et al. A randomized controlled intervention trial of a sexual health approach to long-term HIV risk reduction for men who have sex with men: effects of the intervention on unsafe sexual behavior. AIDS Education & Prevention. Jun. 2002;14(3 Suppl A):59-71. [pmid: 12092938].
22 Rosser BRS, Hatfield LA, Miner MH, et al. Effects of a behavioral intervention to reduce serodiscordant unsafe sex among HIV positive men who have sex with men: the Positive Connections randomized controlled trial study. Journal of Behavioral Medicine. Apr. 2010;33(2):147-58. [pmid: 20101454].
23 Rosser BRS, Oakes JM, Konstan J, et al. Reducing HIV risk behavior of men who have sex with men through persuasive computing: results of the Men's INTernet Study-II. AIDS. Aug. 24. 2010;24(13):2099-107. [pmid: 20601853].
24 Sanchez JP, Guilliames C, Sanchez NF, et al. Video tool to promote knowledge of syphilis among black and Hispanic men recruited from clinical and non-clinical settings. Journal of Community Health. Jun. 2010;35(3):220-8. [pmid: 20151183].
25 Serovich JM, Reed S, Grafsky EL, et al. An intervention to assist men who have sex with men disclose their serostatus to casual sex partners: results from a pilot study. AIDS Education & Prevention. Jun. 2009;21(3):207-19. [pmid: 19519236].
26 Sullivan PS, White D, Rosenberg ES, et al. Safety and acceptability of couples HIV testing and counseling for US men who have sex with men: a randomized prevention study. Journal of the International Association of Providers of AIDS Care. Mar-Apr. 2014;13(2):135-44. [pmid: 23995295].
27 Tobin K, Kuramoto SJ, German D, et al. Unity in diversity: results of a randomized clinical culturally tailored pilot HIV prevention intervention trial in Baltimore, Maryland, for African American men who have sex with men. Health Education & Behavior. Jun. 2013;40(3):286-95. [pmid: 22984216].
28 Vega MY, Spieldenner AR, DeLeon D, et al. SOMOS: Evaluation of an HIV prevention intervention for Latino gay men. Health Education Research. 2011;26(3):407-418. [pmid: 21059799].
29 Weiss JJ, Mulder CL, Antoni MH, et al. Effects of a supportive-expressive group intervention on long-term psychosocial adjustment in HIV-infected gay men. Psychotherapy & Psychosomatics. May-Jun. 2003;72(3):132-40. [pmid: 12707480].
30 Wilton L, Herbst JH, Coury-Doniger P, et al. Efficacy of an HIV/STI prevention intervention for black men who have sex with men: findings from the Many Men, Many Voices (3MV) project. AIDS & Behavior. Jun. 2009;13(3):532-44. [pmid: 19267264].
31 Wolitski RJ, Gomez CA, Parsons JT. Effects of a peer-led behavioral intervention to reduce HIV transmission and promote serostatus disclosure among HIV-seropositive gay and bisexual men. AIDS. Apr. 2005;19(Suppl 1):S99-109. [pmid: 15838199].
32 Wolitski RJ, Parsons JT, Gomez CA, et al. Prevention with gay and bisexual men living with HIV: rationale and methods of the Seropositive Urban Men's Intervention Trial (SUMIT). AIDS. Apr. 2005;19(Suppl 1):S1-11. [pmid: 15838188].

## Racial/Ethnic Populations

### Design (124)

1 Affonso DD, Mayberry LJ, Graham K, et al. Prenatal and postpartum care in Hawaii: a community-based approach. JOGNN - Journal of Obstetric, Gynecologic, & Neonatal Nursing. Jul-Aug. 1993;22(4):320-5. [pmid: 8410431].
2 Ahluwalia JS, Okuyemi K, Nollen N, et al. The effects of nicotine gum and counseling among African American light smokers: a 2 × 2 factorial design. Addiction. Jun. 2006;101(6):883-91. [pmid: 16696632].
3 Alexander GK, Uz SW, Hinton I, et al. Culture brokerage strategies in diabetes education. Public Health Nursing. Sep-Oct. 2008;25(5):461-70. [pmid: 18816363].
4 Alvidrez J, Snowden LR, Rao SM, et al. Psychoeducation to address stigma in black adults referred for mental health treatment: a randomized pilot study. Community Mental Health Journal. Apr. 2009;45(2):127-36. [pmid: 18841473].
5 Ameling JM, Ephraim PL, Bone LR, et al. Adapting hypertension self-management interventions to enhance their sustained effectiveness among urban African Americans. Family & Community Health. Apr-Jun. 2014;37(2):119-33. [pmid: 24569158].
6 Amoako E, Skelly AH. Managing uncertainty in diabetes: an intervention for older African American women. Ethnicity & Disease. 2007;17(3):515-21. [pmid: 17985507].
7 Amoako E, Skelly AH, Rossen EK. Outcomes of an intervention to reduce uncertainty among African American women with diabetes. Western Journal of Nursing Research. Dec. 2008;30(8):928-42. [pmid: 18596303].
8 Ashing K, Rosales M. A telephonic-based trial to reduce depressive symptoms among Latina breast cancer survivors. Psycho-Oncology. May. 2014;23(5):507-15. [pmid: 24217994].
9 Babamoto KS, Sey KA, Camilleri AJ, et al. Improving diabetes care and health measures among hispanics using community health workers: results from a randomized controlled trial. Health Education & Behavior. Feb. 2009;36(1):113-26. [pmid: 19188371].
10 Bailey EJ, Erwin DO, Belin P. Using cultural beliefs and patterns to improve mammography utilization among African-American women: the Witness Project. Journal of the National Medical Association. Mar. 2000;92(3):136-42. [pmid: 10745644].
11 Barnato AE, Mohan D, Downs J, et al. A randomized trial of the effect of patient race on physicians' intensive care unit and life-sustaining treatment decisions for an acutely unstable elder with end-stage cancer. Critical Care Medicine. Jul. 2011;39(7):1663-9. [pmid: 21460710].
12 Barrera M Jr., Toobert D, Strycker L, et al. Effects of acculturation on a culturally adapted diabetes intervention for Latinas. Health Psychology. Jan. 2012;31(1):51-4. [pmid: 21859212].
13 Beeber LS, Lewis VS, Cooper C, et al. Meeting the “Now” Need: PMH-APRN-- Interpreter Teams Provide In-Home Mental Health Intervention for Depressed Latina Mothers With Limited English Proficiency. Journal of the American Psychiatric Nurses Association. Aug. 2009;15(4):249-59. [pmid: 21665811].
14 Blixen CE, Hammel JP, Murphy D, et al. Feasibility of a nurse-run asthma education program for urban African-Americans: a pilot study. Journal of Asthma. Feb. 2001;38(1):23-32. [pmid: 11256551].
15 Bolin JN, Ory MG, Wilson AD, et al. Diabetes education kiosks in a latino community. Diabetes Educator. Mar-Apr. 2013;39(2):204-12. [pmid: 23435404].
16 Brown SA, Garcia AA, Kouzekanani K, et al. Culturally competent diabetes self-management education for Mexican Americans: the Starr County border health initiative. Diabetes Care. Feb. 2002;25(2):259-68. [pmid: 11815493].
17 Brown SA, Hanis CL. A community-based, culturally sensitive education and group-support intervention for Mexican Americans with NIDDM: a pilot study of efficacy. Diabetes Educator. May-Jun. 1995;21(3):203-10. [pmid: 7758387].
18 Canino G, Vila D, Normand S-LT, et al. Reducing asthma health disparities in poor Puerto Rican children: the effectiveness of a culturally tailored family intervention. Journal of Allergy & Clinical Immunology. Mar. 2008;121(3):665-70. [pmid: 18061648].
19 Carter EL, Nunlee-Bland G, Callender C. A patient-centric, provider-assisted diabetes telehealth self-management intervention for urban minorities. Perspectives in Health Information Management. 2011;8:1b. [pmid: 21307985].
20 Castejon AM, Calderon JL, Perez A, et al. A community-based pilot study of a diabetes pharmacist intervention in Latinos: impact on weight and hemoglobin A1c. Journal of Health Care for the Poor & Underserved. Nov. 2013;24(4 Suppl):48-60. [pmid: 24241260].
21 Catley D, Ahluwalia JS, Resnicow K, et al. Depressive symptoms and smoking cessation among inner-city African Americans using the nicotine patch. Nicotine & Tobacco Research. Feb. 2003;5(1):61-8. [pmid: 12745507].
22 Champion JD, Collins JL. Comparison of a theory-based (AIDS Risk Reduction Model) cognitive behavioral intervention versus enhanced counseling for abused ethnic minority adolescent women on infection with sexually transmitted infection: Results of a randomized controlled trial. International Journal of Nursing Studies. 2012;49(2):138-150. [pmid: 21937041].
23 Clark F, Azen SP, Zemke R, et al. Occupational therapy for independent-living older adults. A randomized controlled trial. JAMA. Oct. 22-29. 1997;278(16):1321-6. [pmid: 9343462].
24 Collins-McNeil J, Edwards CL, Batch BC, et al. A culturally targeted self-management program for African Americans with type 2 diabetes mellitus. Canadian Journal of Nursing Research. Dec. 2012;44(4):126-41. [pmid: 23448079].
25 Cooper LA, Marsteller JA, Noronha GJ, et al. A multi-level system quality improvement intervention to reduce racial disparities in hypertension care and control: study protocol. Implementation Science. 2013;8:60. [pmid: 23734703].
26 Cousins JH, Rubovits DS, Dunn JK, et al. Family versus individually oriented intervention for weight loss in Mexican American women. Public Health Reports. Sep-Oct. 1992;107(5):549-55. [pmid: 1410236].
27 Cramer JS, Sibley RF, Bartlett DP, et al. An adaptation of the diabetes prevention program for use with high-risk, minority patients with type 2 diabetes. Diabetes Educator. May-Jun. 2007;33(3):503-8. [pmid: 17570881].
28 DeMarco RF, Chan K. The Sistah Powah structured writing intervention: a feasibility study for aging, low-income, HIV-positive Black women. American Journal of Health Promotion. Nov-Dec. 2013;28(2):108-18. [pmid: 23621624].
29 DePue JD, Rosen RK, Batts-Turner M, et al. Cultural translation of interventions: diabetes care in American Samoa. American Journal of Public Health. Nov. 2010;100(11):2085-93. [pmid: 20864729].
30 DePue JD, Rosen RK, Seiden A, et al. Implementation of a culturally tailored diabetes intervention with community health workers in American Samoa. Diabetes Educator. Nov-Dec. 2013;39(6):761-71. [pmid: 24052204].
31 Diabetes Prevention Program Research G. The Diabetes Prevention Program (DPP): description of lifestyle intervention. Diabetes Care. Dec. 2002;25(12):2165-71. [pmid: 12453955].
32 Drieling RL, Ma J, Stafford RS. Evaluating clinic and community-based lifestyle interventions for obesity reduction in a low-income Latino neighborhood: Vivamos Activos Fair Oaks Program. BMC Public Health. 2011;11:98. [pmid: 21320331].
33 Dushay RA, Singer M, Weeks MR, et al. Lowering HIV risk among ethnic minority drug users: comparing culturally targeted intervention to a standard intervention. American Journal of Drug & Alcohol Abuse. Aug. 2001;27(3):501-24. [pmid: 11506265].
34 Dwight-Johnson M, Aisenberg E, Golinelli D, et al. Telephone-based cognitive-behavioral therapy for Latino patients living in rural areas: a randomized pilot study. Psychiatric Services. Aug. 2011;62(8):936-42. [pmid: 21807834].
35 Ell K, Vourlekis B, Lee P-J, et al. Patient navigation and case management following an abnormal mammogram: a randomized clinical trial. Preventive Medicine. Jan. 2007;44(1):26-33. [pmid: 16962652].
36 Engelman KK, Cupertino AP, Daley CM, et al. Engaging diverse underserved communities to bridge the mammography divide. BMC Public Health. 2011;11:47. [pmid: 21255424].
37 Gary TL, Hill-Briggs F, Batts-Turner M, et al. Translational research principles of an effectiveness trial for diabetes care in an urban African American population. Diabetes Educator. Nov-Dec. 2005;31(6):880-9. [pmid: 16288095].
38 Gaston MH, Porter GK, Thomas VG. Prime Time Sister Circles: evaluating a gender-specific, culturally relevant health intervention to decrease major risk factors in mid-life African-American women. Journal of the National Medical Association. Apr. 2007;99(4):428-38. [pmid: 17444433].
39 Gilliland SS, Azen SP, Perez GE, et al. Strong in body and spirit: lifestyle intervention for Native American adults with diabetes in New Mexico. Diabetes Care. Jan. 2002;25(1):78-83. [pmid: 11772905].
40 Grote NK, Swartz HA, Geibel SL, et al. A randomized controlled trial of culturally relevant, brief interpersonal psychotherapy for perinatal depression. Psychiatric Services. Mar. 2009;60(3):313-21. [pmid: 19252043].
41 Harris KJ, Ahluwalia JS, Okuyemi KS, et al. Addressing cultural sensitivity in a smoking cessation intervention: Development of the Kick It At Swope Project. Journal of Community Psychology. 2001;29(4):447-458.
42 Hay JW, Katon WJ, Ell K, et al. Cost-effectiveness analysis of collaborative care management of major depression among low-income, predominantly Hispanics with diabetes. Value in Health. Mar-Apr. 2012;15(2):249-54. [pmid: 22433755].
43 Hayashi T, Farrell MA, Chaput LA, et al. Lifestyle intervention, behavioral changes, and improvement in cardiovascular risk profiles in the California WISEWOMAN project. Journal of Women's Health. Jun. 2010;19(6):1129-38. [pmid: 20509780].
44 Henderson JA, Chubak J, O'Connell J, et al. Design of a randomized controlled trial of a web-based intervention to reduce cardiovascular disease risk factors among remote reservation-dwelling American Indian adults with type 2 diabetes. Journal of Primary Prevention. Aug. 2012;33(4):209-22. [pmid: 23001642].
45 Hendren S, Griggs JJ, Epstein RM, et al. Study protocol: a randomized controlled trial of patient navigation-activation to reduce cancer health disparities. BMC Cancer. 2010;10:551. [pmid: 20939928].
46 Herbst JH, Painter TM, Tomlinson HL, et al. Evidence-based HIV/STD prevention intervention for black men who have sex with men. Morbidity & Mortality Weekly Report Surveillance Summaries. Apr. 18. Suppl 1. 2014;63:21-7. [pmid: 24743663].
47 Hill MN, Bone LR, Hilton SC, et al. A clinical trial to improve high blood pressure care in young urban black men: recruitment, follow-up, and outcomes. American Journal of Hypertension. Jun. 1999;12(6):548-54. [pmid: 10371363].
48 Hill-Briggs F, Batts-Turner M, Gary TL, et al. Training community health workers as diabetes educators for urban African Americans: value added using participatory methods. Progress in Community Health Partnerships. 2007;1(2):185-94. [pmid: 20208238].
49 Ikeda JP, Pham L, Nguyen K-P, et al. Culturally relevant nutrition education improves dietary quality among WIC-eligible Vietnamese immigrants. Journal of Nutrition Education & Behavior. May-Jun. 2002;34(3):151-8. [pmid: 12047839].
50 Jackson J, Kennedy BL, Mandel D, et al. Derivation and pilot assessment of a health promotion program for Mandarin-speaking Chinese older adults. International Journal of Aging & Human Development. 2000;50(2):127-49. [pmid: 10791612].
51 Janevic MR, Sanders GM, Thomas LJ, et al. Study protocol for Women of Color and Asthma Control: a randomized controlled trial of an asthma-management intervention for African American women. BMC Public Health. 2012;12:76. [pmid: 22272780].
52 Jobe JB, Adams AK, Henderson JA, et al. Community-responsive interventions to reduce cardiovascular risk in American Indians. Journal of Primary Prevention. Aug. 2012;33(4):153-9. [pmid: 22983753].
53 Kanter JW, Santiago-Rivera AL, Santos MM, et al. A randomized hybrid efficacy and effectiveness trial of behavioral activation for latinos with depression. Behavior Therapy. 2015;46(2):177-192. [pmid: 25645167].
54 Kaslow NJ, Leiner AS, Reviere S, et al. Suicidal, abused African American women's response to a culturally informed intervention. Journal of Consulting & Clinical Psychology. Aug. 2010;78(4):449-58. [pmid: 20658802].
55 Keyserling TC, Ammerman AS, Samuel-Hodge CD, et al. A diabetes management program for African American women with type 2 diabetes. Diabetes Educator. Sep-Oct. 2000;26(5):796-805. [pmid: 11140007].
56 Keyserling TC, Samuel-Hodge CD, Ammerman AS, et al. A randomized trial of an intervention to improve self-care behaviors of African-American women with type 2 diabetes: impact on physical activity. Diabetes Care. Sep. 2002;25(9):1576-83. [pmid: 12196430].
57 Kim KB, Han H-R, Huh B, et al. The effect of a community-based self-help multimodal behavioral intervention in Korean American seniors with high blood pressure. American Journal of Hypertension. Sep. 2014;27(9):1199-208. [pmid: 24671049].
58 Kim MT, Han H-R, Hedlin H, et al. Teletransmitted monitoring of blood pressure and bilingual nurse counseling-sustained improvements in blood pressure control during 12 months in hypertensive Korean Americans. Journal of Clinical Hypertension. Aug. 2011;13(8):605-12. [pmid: 21806771].
59 Kim MT, Han H-R, Song H-J, et al. A community-based, culturally tailored behavioral intervention for Korean Americans with type 2 diabetes. Diabetes Educator. Nov-Dec. 2009;35(6):986-94. [pmid: 19934458].
60 Kopelowicz A. Adapting social skills training for Latinos with schizophrenia. International Review of Psychiatry. 1998;10(1):47-50.
61 Kumanyika S, Fassbender J, Phipps E, et al. Design, recruitment and start up of a primary care weight loss trial targeting African American and Hispanic adults. Contemporary Clinical Trials. Mar. 2011;32(2):215-24. [pmid: 21062645].
62 Kumanyika SK, Fassbender JE, Sarwer DB, et al. One-year results of the Think Health! study of weight management in primary care practices. Obesity. Jun. 2012;20(6):1249-57. [pmid: 22051940].
63 Kumpfer KL, Alvarado R, Smith P, et al. Cultural sensitivity and adaptation in family-based prevention interventions. Prevention Science. Sep. 2002;3(3):241-6. [pmid: 12387558].
64 Kwong K, Chung H, Cheal K, et al. Depression care management for Chinese Americans in primary care: a feasibility pilot study. Community Mental Health Journal. Apr. 2013;49(2):157-65. [pmid: 22015960].
65 La Roche MJ, Batista C, D'Angelo E. A culturally competent relaxation intervention for Latino/as: assessing a culturally specific match model. American Journal of Orthopsychiatry. Oct. 2011;81(4):535-42. [pmid: 21977939].
66 Li P, Guttmann A. Recent innovations to improve asthma outcomes in vulnerable children. Current Opinion in Pediatrics. Dec. 2009;21(6):783-8. [pmid: 19745737].
67 Lujan J, Ostwald SK, Ortiz M. Promotora diabetes intervention for Mexican Americans. Diabetes Educator. Jul-Aug. 2007;33(4):660-70. [pmid: 17684167].
68 Malgady RG, Rogler LH, Costantino G. Culturally sensitive psychotherapy for Puerto Rican children and adolescents: a program of treatment outcome research. Journal of Consulting & Clinical Psychology. Dec. 1990;58(6):704-12. [pmid: 2292620].
69 McCoy HV, McCoy CB, Lai S. Effectiveness of HIV interventions among women drug users. Women & Health. 1998;27(1-2):49-66. [pmid: 9640634].
70 Mendel P, Ngo VK, Dixon E, et al. Partnered evaluation of a community engagement intervention: use of a kickoff conference in a randomized trial for depression care improvement in underserved communities. Ethnicity & Disease. 2011;21(3 Suppl 1):S1-78-88. [pmid: 22352084].
71 Mendelson SG, McNeese-Smith D, Koniak-Griffin D, et al. A community-based parish nurse intervention program for Mexican American women with gestational diabetes. JOGNN - Journal of Obstetric, Gynecologic, & Neonatal Nursing. Jul-Aug. 2008;37(4):415-25. [pmid: 18754979].
72 Mendenhall AN, Fristad MA, Early TJ. Factors influencing service utilization and mood symptom severity in children with mood disorders: effects of multifamily psychoeducation groups (MFPGs). Journal of Consulting & Clinical Psychology. Jun. 2009;77(3):463-73. [pmid: 19485588].
73 Menon U, Szalacha LA, Belue R, et al. Interactive, culturally sensitive education on colorectal cancer screening. Medical Care. Sep. 2008;46(9 Suppl 1):S44-50. [pmid: 18725832].
74 Merriam PA, Tellez TL, Rosal MC, et al. Methodology of a diabetes prevention translational research project utilizing a community-academic partnership for implementation in an underserved Latino community. BMC Medical Research Methodology. 2009;9:20. [pmid: 19284663].
75 Miles MS, Holditch-Davis D, Eron J, et al. An HIV self-care symptom management intervention for African American mothers. Nursing Research. Nov-Dec. 2003;52(6):350-60. [pmid: 14639081].
76 Miranda J, Duan N, Sherbourne C, et al. Improving care for minorities: can quality improvement interventions improve care and outcomes for depressed minorities? Results of a randomized, controlled trial. Health Services Research. Apr. 2003;38(2):613-30. [pmid: 12785564].
77 Mokuau N, Braun KL, Wong LK, et al. Development of a family intervention for Native Hawaiian women with cancer: a pilot study. Social Work. Jan. 2008;53(1):9-19. [pmid: 18610817].
78 Mutchler MG, Wagner G, Cowgill BO, et al. Improving HIV/AIDS care through treatment advocacy: going beyond client education to empowerment by facilitating client-provider relationships. AIDS Care. Jan. 2011;23(1):79-90. [pmid: 21218280].
79 Napholz L. Stress-reduction psychoeducational interventions for black working women. Nursing Clinics of North America. Jun. 2002;37(2):263-72. vi. [pmid: 12389267].
80 Nguyen AB, Belgrave FZ, Sholley BK. Development of a breast and cervical cancer screening intervention for Vietnamese American women: a community-based participatory approach. Health Promotion Practice. Nov. 2011;12(6):876-86. [pmid: 20530637].
81 Norr KF, Crittenden KS, Lehrer EL, et al. Maternal and infant outcomes at one year for a nurse-health advocate home visiting program serving African Americans and Mexican Americans. Public Health Nursing. May-Jun. 2003;20(3):190-203. [pmid: 12716399].
82 O'Brien MJ, Halbert CH, Bixby R, et al. Community health worker intervention to decrease cervical cancer disparities in Hispanic women. Journal of General Internal Medicine. Nov. 2010;25(11):1186-92. [pmid: 20607434].
83 Osborn CY, Amico KR, Cruz N, et al. A brief culturally tailored intervention for Puerto Ricans with type 2 diabetes. Health Education & Behavior. Dec. 2010;37(6):849-62. [pmid: 21076128].
84 Osuna D, Barrera M Jr., Strycker LA, et al. Methods for the cultural adaptation of a diabetes lifestyle intervention for Latinas: an illustrative project. Health Promotion Practice. May. 2011;12(3):341-8. [pmid: 19843703].
85 Penedo FJ, Traeger L, Dahn J, et al. Cognitive behavioral stress management intervention improves quality of life in Spanish monolingual hispanic men treated for localized prostate cancer: results of a randomized controlled trial. International Journal of Behavioral Medicine. 2007;14(3):164-72. [pmid: 18062059].
86 Peragallo N, Deforge B, O'Campo P, et al. A randomized clinical trial of an HIV-risk-reduction intervention among low-income Latina women. [Erratum appears in Nurs Res. 2005 Jul-Aug;54(4):264]. Nursing Research. Mar-Apr. 2005;54(2):108-18. [pmid: 15778652].
87 Philis-Tsimikas A, Fortmann A, Lleva-Ocana L, et al. Peer-led diabetes education programs in high-risk Mexican Americans improve glycemic control compared with standard approaches: a Project Dulce promotora randomized trial. Diabetes Care. Sep. 2011;34(9):1926-31. [pmid: 21775748].
88 Ramirez A, Perez-Stable E, Penedo F, et al. Reducing time-to-treatment in underserved Latinas with breast cancer: the Six Cities Study. Cancer. Mar. 1. 2014;120(5):752-60. [pmid: 24222098].
89 Ratzliff ADH, Ni K, Chan Y-F, et al. A collaborative care approach to depression treatment for Asian Americans. Psychiatric Services. May. 1. 2013;64(5):487-90. [pmid: 23632577].
90 Rodrigue JR, Cornell DL, Kaplan B, et al. A randomized trial of a home-based educational approach to increase live donor kidney transplantation: effects in blacks and whites. American Journal of Kidney Diseases. Apr. 2008;51(4):663-70. [pmid: 18371542].
91 Rosenzweig M, Brufsky A, Rastogi P, et al. The attitudes, communication, treatment, and support intervention to reduce breast cancer treatment disparity. Oncology Nursing Forum. Jan. 2011;38(1):85-9. [pmid: 21186164].
92 Rossiter JC. The effect of a culture-specific education program to promote breastfeeding among Vietnamese women in Sydney. International Journal of Nursing Studies. Aug. 1994;31(4):369-79. [pmid: 7928125].
93 Roye C, Perlmutter Silverman P, Krauss B. A brief, low-cost, theory-based intervention to promote dual method use by black and Latina female adolescents: a randomized clinical trial. Health Education & Behavior. Aug. 2007;34(4):608-21. [pmid: 16740522].
94 Ruggiero L, Moadsiri A, Butler P, et al. Supporting diabetes self-care in underserved populations: a randomized pilot study using medical assistant coaches. Diabetes Educator. Jan-Feb. 2010;36(1):127-31. [pmid: 20185612].
95 Saulsberry A, Corden ME, Taylor-Crawford K, et al. Chicago Urban Resiliency Building (CURB): An internet-based depression-prevention intervention for urban African-American and Latino adolescents. Journal of Child and Family Studies. 2013;22(1):150-160.
96 Shin S-K, Lukens EP. Effects of psychoeducation for Korean Americans with chronic mental illness. Psychiatric Services. Sep. 2002;53(9):1125-31. [pmid: 12221311].
97 Siegel C, Haugland G, Chambers ED. Performance measures and their benchmarks for assessing organizational cultural competency in behavioral health care service delivery. Administration & Policy in Mental Health. Nov. 2003;31(2):141-70. [pmid: 14756197].
98 Simoni JM, Wiebe JS, Sauceda JA, et al. A preliminary RCT of CBT-AD for adherence and depression among HIV-positive Latinos on the U.S.-Mexico border: The Nuevo Dia study. AIDS and Behavior. 2013;17(8):2816-2829. [pmid: 23812892].
99 Sinclair KiA, Makahi EK, Shea-Solatorio C, et al. Outcomes from a diabetes self-management intervention for Native Hawaiians and Pacific People: Partners in Care. Annals of Behavioral Medicine. Feb. 2013;45(1):24-32. [pmid: 23086589].
100 Sixta CS, Ostwald S. Texas-Mexico border intervention by promotores for patients with type 2 diabetes. Diabetes Educator. Mar-Apr. 2008;34(2):299-309. [pmid: 18375779].
101 Sly JR, Jandorf L, Dhulkifl R, et al. Challenges to replicating evidence-based research in real-world settings: training African-American peers as patient navigators for colon cancer screening. Journal of Cancer Education. Dec. 2012;27(4):680-6. [pmid: 22791543].
102 Spencer MS, Rosland A-M, Kieffer EC, et al. Effectiveness of a community health worker intervention among African American and Latino adults with type 2 diabetes: a randomized controlled trial. American Journal of Public Health. Dec. 2011;101(12):2253-60. [pmid: 21680932].
103 Taylor G, Jones A. Effects of a culturally sensitive breast self-examination intervention. Outcomes Management. Apr-Jun. 2002;6(2):73-8. quiz 9. [pmid: 11949517].
104 Thompson VLS, Kalesan B, Wells A, et al. Comparing the use of evidence and culture in targeted colorectal cancer communication for African Americans. Patient Education & Counseling. Dec. Suppl. 2010;81:S22-33. [pmid: 20702056].
105 Tondora J, O'Connell M, Miller R, et al. A clinical trial of peer-based culturally responsive person-centered care for psychosis for African Americans and Latinos. Clinical Trials. Aug. 2010;7(4):368-79. [pmid: 20571133].
106 Toobert DJ, Strycker LA, Barrera M Jr., et al. Outcomes from a multiple risk factor diabetes self-management trial for Latinas: Viva Bien!. Annals of Behavioral Medicine. Jun. 2011;41(3):310-23. [pmid: 21213091].
107 Trinh N-HT, Bedoya CA, Chang TE, et al. A study of a culturally focused psychiatric consultation service for Asian American and Latino American primary care patients with depression. BMC Psychiatry. 2011;11:166. [pmid: 21995514].
108 Tsosie U, Nannauck S, Buchwald D, et al. Staying connected: A feasibility study linking American Indian and Alaska Native trauma survivors to their tribal communities. Psychiatry: Interpersonal and Biological Processes. 2011;74(4):349-361. [pmid: 22168295].
109 van Servellen G, Nyamathi A, Carpio F, et al. Effects of a treatment adherence enhancement program on health literacy, patient-provider relationships, and adherence to HAART among low-income HIV-positive Spanish-speaking Latinos. AIDS Patient Care & Stds. Nov. 2005;19(11):745-59. [pmid: 16283835].
110 Vazquez IM, Millen B, Bissett L, et al. Buena Alimentacion, Buena Salud: a preventive nutrition intervention in Caribbean Latinos with type 2 diabetes. American Journal of Health Promotion. Nov-Dec. 1998;13(2):116-9. [pmid: 10346658].
111 Vincent D. Culturally tailored education to promote lifestyle change in Mexican Americans with type 2 diabetes. Journal of the American Academy of Nurse Practitioners. Sep. 2009;21(9):520-7. [pmid: 19845810].
112 Vincent D, Pasvogel A, Barrera L. A feasibility study of a culturally tailored diabetes intervention for Mexican Americans. Biological Research for Nursing. Oct. 2007;9(2):130-41. [pmid: 17909165].
113 Walters KL, LaMarr J, Levy RL, et al. Project hli?dx(w)/Healthy Hearts Across Generations: development and evaluation design of a tribally based cardiovascular disease prevention intervention for American Indian families. Journal of Primary Prevention. Aug. 2012;33(4):197-207. [pmid: 22965622].
114 Welch G, Allen NA, Zagarins SE, et al. Comprehensive diabetes management program for poorly controlled Hispanic type 2 patients at a community health center. Diabetes Educator. Sep-Oct. 2011;37(5):680-8. [pmid: 21918206].
115 Wells KB, Jones L, Chung B, et al. Community-partnered cluster-randomized comparative effectiveness trial of community engagement and planning or resources for services to address depression disparities. [Erratum appears in J Gen Intern Med. 2013 Nov;28(11):1534]. Journal of General Internal Medicine. Oct. 2013;28(10):1268-78. [pmid: 23649787].
116 Wells KJ, Meade CD, Calcano E, et al. Innovative approaches to reducing cancer health disparities: the Moffitt Cancer Center Patient Navigator Research Program. Journal of Cancer Education. Dec. 2011;26(4):649-57. [pmid: 21573740].
117 Wilson K, Durantini MR, Albarracin J, et al. Reducing cultural and psychological barriers to Latino enrollment in HIV-prevention counseling: initial data on an enrollment meta-intervention. AIDS Care. 2013;25(7):881-7. [pmid: 23398305].
118 Wingood GM, DiClemente RJ, Villamizar K, et al. Efficacy of a health educator-delivered HIV prevention intervention for Latina women: a randomized controlled trial. American Journal of Public Health. Dec. 2011;101(12):2245-52. [pmid: 22021297].
119 Wise M, Han JY, Shaw B, et al. Effects of using online narrative and didactic information on healthcare participation for breast cancer patients. Patient Education & Counseling. Mar. 2008;70(3):348-56. [pmid: 18201859].
120 Witmer JM, Hensel MR, Holck PS, et al. Heart disease prevention for Alaska Native women: a review of pilot study findings. Journal of Women's Health. Jun. 2004;13(5):569-78. [pmid: 15257848].
121 Yeung A, Hails K, Chang T, et al. A study of the effectiveness of telepsychiatry-based culturally sensitive collaborative treatment of depressed Chinese Americans. BMC Psychiatry. 2011;11:154. [pmid: 21943315].
122 Yeung A, Shyu I, Fisher L, et al. Culturally sensitive collaborative treatment for depressed chinese americans in primary care. American Journal of Public Health. Dec. 2010;100(12):2397-402. [pmid: 20966373].
123 Yi JK, Luong KN-T. Apartment-Based Breast Cancer Education Program for Low Income Vietnamese American Women. Journal of Community Health: The Publication for Health Promotion and Disease Prevention. 2005;30(5):345-353. [pmid: 16175957].
124 Zhang H, Neelarambam K, Schwenke TJ, et al. Mediators of a culturally-sensitive intervention for suicidal African American women. Journal of Clinical Psychology in Medical Settings. Dec. 2013;20(4):401-14. [pmid: 23864403].

### Excluded Systematic Literature Review (27)

1 Benish SG. Culturally adapted psychotherapy and the legitimacy of Myth: A multilevel model, direct comparison meta-analysis. Benish, Steven G. U Wisconsin - Madison, US. 2011.
2 Chowdhary N, Jotheeswaran AT, Nadkarni A, et al. The methods and outcomes of cultural adaptations of psychological treatments for depressive disorders: a systematic review. Psychological Medicine. Apr. 2014;44(6):1131-46. [pmid: 23866176].
3 Clarke AR, Goddu AP, Nocon RS, et al. Thirty years of disparities intervention research: what are we doing to close racial and ethnic gaps in health care?. Medical Care. Nov. 2013;51(11):1020-6. [pmid: 24128746].
4 Dauvrin M, Lorant V. Culturally competent interventions in Type 2 diabetes mellitus management: An equity-oriented literature review. Ethnicity & Health. 2014;19(6):579-600. [pmid: 24266662].
5 Davidson PM, Gholizadeh L, Haghshenas A, et al. A review of the cultural competence view of cardiac rehabilitation. Journal of Clinical Nursing. May. 2010;19(9-10):1335-42. [pmid: 20500343].
6 Griner D, Smith TB. Culturally adapted mental health intervention: A meta-analytic review. Psychotherapy: Theory, Research, Practice, Training. 2006;43(4):531-48. [pmid: 22122142].
7 Hawthorne K, Robles Y, Cannings-John R, et al. Culturally appropriate health education for type 2 diabetes mellitus in ethnic minority groups. Cochrane Database of Systematic Reviews. 2008;(3). CD006424. [pmid: 18646153].
8 Hawthorne K, Robles Y, Cannings-John R, et al. Culturally appropriate health education for Type 2 diabetes in ethnic minority groups: a systematic and narrative review of randomized controlled trials. Diabetic Medicine. Jun. 2010;27(6):613-23. [pmid: 20546277].
9 Heo H-H, Braun KL. Culturally tailored interventions of chronic disease targeting Korean Americans: A systematic review. Ethnicity & Health. 2014;19(1):64-85. [pmid: 24261698].
10 Hodge DR, Jackson KF, Vaughn MG. Culturally sensitive interventions for health related behaviors among Latino youth: A meta-analytic review. Children and Youth Services Review. 2010;32(10):1331-1337.
11 Hodge DR, Jackson KF, Vaughn MG. Culturally sensitive interventions and substance use: A meta-analytic review of outcomes among minority youths. Social Work Research. 2012;36(1):1-9.
12 Jackson KF, Hodge DR. Native American youth and culturally sensitive interventions: A systematic review. Research on Social Work Practice. 2010;20(3):260-270.
13 Jackson KF, Hodge DR, Vaughn MG. A meta-analysis of culturally sensitive interventions designed to reduce high-risk behaviors among African American youth. Journal of Social Service Research. 2010;36(3):163-173.
14 Joo JY. Effectiveness of culturally tailored diabetes interventions for asian immigrants to the United States: a systematic review. Diabetes Educator. Sep. 2014;40(5):605-15. [pmid: 24829268].
15 Kalibatseva Z, Leong FTL. A critical review of culturally sensitive treatments for depression: Recommendations for intervention and research. Psychological Services. 2014;11(4):433-450. [pmid: 25383996].
16 Kong G, Singh N, Krishnan-Sarin S. A review of culturally targeted/tailored tobacco prevention and cessation interventions for minority adolescents. Nicotine & Tobacco Research. Dec. 2012;14(12):1394-406. [pmid: 22614548].
17 Liu JJ, Wabnitz C, Davidson E, et al. Smoking cessation interventions for ethnic minority groups-A systematic review of adapted interventions. Preventive Medicine: An International Journal Devoted to Practice and Theory. 2013;57(6):765-775. [pmid: 24076130].
18 McMahon T, Ward PR. HIV among immigrants living in high-income countries: a realist review of evidence to guide targeted approaches to behavioural HIV prevention. Systems Review. 2012;1:56. [pmid: 23168134].
19 Metzger I, Cooper SM, Zarrett N, et al. Culturally sensitive risk behavior prevention programs for African American adolescents: a systematic analysis. Clinical Child & Family Psychology Review. Jun. 2013;16(2):187-212. [pmid: 23660972].
20 Mier N, Ory MG, Medina AA. Anatomy of culturally sensitive interventions promoting nutrition and exercise in hispanics: a critical examination of existing literature. Health Promotion Practice. Jul. 2010;11(4):541-54. [pmid: 19193933].
21 Nierkens V, Hartman MA, Nicolaou M, et al. Effectiveness of cultural adaptations of interventions aimed at smoking cessation, diet, and/or physical activity in ethnic minorities. a systematic review. PLoS ONE. [Electronic Resource]. 2013;8(10):e73373. [pmid: 24116000].
22 Renzaho AMN, Romios P, Crock C, et al. The effectiveness of cultural competence programs in ethnic minority patient centered health care-A systematic review of the literature. International Journal for Quality in Health Care. 2013;25(3):261-269. [pmid: 23343990].
23 Saxena S, Misra T, Car J, et al. Systematic review of primary healthcare interventions to improve diabetes outcomes in minority ethnic groups. Journal of Ambulatory Care Management. Jul-Sep. 2007;30(3):218-30. [pmid: 17581434].
24 van Loon A, van Schaik A, Dekker J, et al. Bridging the gap for ethnic minority adult outpatients with depression and anxiety disorders by culturally adapted treatments. Journal of Affective Disorders. May. 2013;147(1-3):9-16. [pmid: 23351566].
25 Whittemore R. Culturally competent interventions for Hispanic adults with type 2 diabetes: a systematic review. Journal of Transcultural Nursing. Apr. 2007;18(2):157-66. [pmid: 17416718].
26 Williamson M, Harrison L. Providing culturally appropriate care: a literature review. International Journal of Nursing Studies. Jun. 2010;47(6):761-9. [pmid: 20138275].
27 Zeh P, Sandhu HK, Cannaby AM, et al. The impact of culturally competent diabetes care interventions for improving diabetes-related outcomes in ethnic minority groups: a systematic review. Diabetic Medicine. Oct. 2012;29(10):1237-52. [pmid: 22553954].

### Not Cultural Competence Intervention (25)

1 Allen JK, Dennison Himmelfarb CR, Szanton SL, et al. Cost-effectiveness of nurse practitioner/community health worker care to reduce cardiovascular health disparities. Journal of Cardiovascular Nursing. Jul. 2014;29(4):308-14. [pmid: 23635809].
2 Bao Y, Alexopoulos GS, Casalino LP, et al. Collaborative depression care management and disparities in depression treatment and outcomes. Archives of General Psychiatry. Jun. 2011;68(6):627-36. [pmid: 21646579].
3 Bosworth HB, Olsen MK, Neary A, et al. Take Control of Your Blood Pressure (TCYB) study: a multifactorial tailored behavioral and educational intervention for achieving blood pressure control. Patient Education & Counseling. Mar. 2008;70(3):338-47. [pmid: 18164894].
4 Christie J, Itzkowitz S, Lihau-Nkanza I, et al. A randomized controlled trial using patient navigation to increase colonoscopy screening among low-income minorities. Journal of the National Medical Association. Mar. 2008;100(3):278-84. [pmid: 18390020].
5 DiClemente RJ, Wingood GM, Harrington KF, et al. Efficacy of an HIV prevention intervention for African American adolescent girls: a randomized controlled trial. JAMA. Jul. 14. 2004;292(2):171-9. [pmid: 15249566].
6 Dutton GR, Davis Martin P, Welsch MA, et al. Promoting physical activity for low-income minority women in primary care. American Journal of Health Behavior. Nov-Dec. 2007;31(6):622-31. [pmid: 17691875].
7 Fisher EB, Strunk RC, Highstein GR, et al. A randomized controlled evaluation of the effect of community health workers on hospitalization for asthma: the asthma coach. [Erratum appears in Arch Pediatr Adolesc Med. 2009 May;163(5):493]. Archives of Pediatrics & Adolescent Medicine. Mar. 2009;163(3):225-32. [pmid: 19255389].
8 Freund KM, Battaglia TA, Calhoun E, et al. Impact of patient navigation on timely cancer care: the Patient Navigation Research Program. Journal of the National Cancer Institute. Jun. 2014;106(6):dju115. [pmid: 24938303].
9 Jerant A, Kravitz RL, Sohler N, et al. Sociopsychological tailoring to address colorectal cancer screening disparities: a randomized controlled trial. Annals of Family Medicine. May-Jun. 2014;12(3):204-14. [pmid: 24821891].
10 Kalauokalani D, Franks P, Oliver JW, et al. Can patient coaching reduce racial/ethnic disparities in cancer pain control? Secondary analysis of a randomized controlled trial. Pain Medicine. Jan-Feb. 2007;8(1):17-24. [pmid: 17244100].
11 Katz ML, Fisher JL, Fleming K, et al. Patient activation increases colorectal cancer screening rates: a randomized trial among low-income minority patients. Cancer Epidemiology, Biomarkers & Prevention. Jan. 2012;21(1):45-52. [pmid: 22068288].
12 Lepore SJ, Wolf RL, Basch CE, et al. Informed decision making about prostate cancer testing in predominantly immigrant black men: a randomized controlled trial. Annals of Behavioral Medicine. Dec. 2012;44(3):320-30. [pmid: 22825933].
13 Lesley ML, Oermann MH, Vander Wal JS. Internet education of African American consumers on quality of care. Journal of Community Health Nursing. 2004;21(1):1-14. [pmid: 14979842].
14 Levine DM, Bone LR, Hill MN, et al. The effectiveness of a community/academic health center partnership in decreasing the level of blood pressure in an urban African-American population. Ethnicity & Disease. 2003;13(3):354-61. [pmid: 12894960].
15 Peragallo N, DeForge B, O'Campo P, et al. A Randomized Clinical Trial of an HIV-Risk-Reduction Intervention Among Low-Income Latina Women. Nursing Research. 2005;54(2):108-118. [pmid: 15778652].
16 Podorefsky DL, McDonald-Dowdell M, Beardslee WR. Adaptation of preventive interventions for a low-income, culturally diverse community. Journal of the American Academy of Child & Adolescent Psychiatry. Aug. 2001;40(8):879-86. [pmid: 11501686].
17 Powers BJ, King JL, Ali R, et al. The Cholesterol, Hypertension, and Glucose Education (CHANGE) study for African Americans with diabetes: study design and methodology. American Heart Journal. Sep. 2009;158(3):342-8. [pmid: 19699855].
18 Sisk JE, Hebert PL, Horowitz CR, et al. Effects of nurse management on the quality of heart failure care in minority communities: a randomized trial. [Summary for patients in Ann Intern Med. 2006 Aug 15;145(4):I28; PMID: 16908913]. Annals of Internal Medicine. Aug. 15. 2006;145(4):273-83. [pmid: 16908918].
19 Sterk CE, Theall KP, Elifson KW. Effectiveness of a risk reduction intervention among African American women who use crack cocaine. AIDS Education & Prevention. Feb. 2003;15(1):15-32. [pmid: 12627741].
20 Ukoli FA, Patel K, Hargreaves M, et al. A tailored prostate cancer education intervention for low-income African Americans: impact on knowledge and screening. Journal of Health Care for the Poor & Underserved. Feb. 2013;24(1):311-31. [pmid: 23377736].
21 Wagner H, Pizzimenti JJ, Daniel K, et al. Eye on diabetes: a multidisciplinary patient education intervention. Diabetes Educator. Jan-Feb. 2008;34(1):84-9. [pmid: 18267994].
22 Weng HH, Kaplan RM, Boscardin WJ, et al. Development of a decision aid to address racial disparities in utilization of knee replacement surgery. Arthritis & Rheumatism. May. 15. 2007;57(4):568-75. [pmid: 17471558].
23 West DS, Greene P, Pulley L, et al. Stepped-care, community clinic interventions to promote mammography use among low-income rural African American women. Health Education & Behavior. Aug. 2004;31(4 Suppl):29S-44S. [pmid: 15296690].
24 Wingood GM, DiClemente RJ, Harrington KF, et al. Efficacy of an HIV prevention program among female adolescents experiencing gender-based violence. American Journal of Public Health. Jun. 2006;96(6):1085-90. [pmid: 16670238].
25 Zayas LH, McKee MD, Jankowski KRB. Adapting psychosocial intervention research to urban primary care environments: a case example. Annals of Family Medicine. Sep-Oct. 2004;2(5):504-8. [pmid: 15506589].

### Not Health Care (15)

1 Barlow A, Mullany B, Neault N, et al. Paraprofessional-delivered home-visiting intervention for American Indian teen mothers and children: 3-year outcomes from a randomized controlled trial. American Journal of Psychiatry. Feb. 1. 2015;172(2):154-62. [pmid: 25321149].
2 Bertens MGBC, Eiling EM, van den Borne B, et al. Uma Tori! Evaluation of an STI/HIV-prevention intervention for Afro-Caribbean women in the Netherlands. Patient Education & Counseling. Apr. 2009;75(1):77-83. [pmid: 18950977].
3 Brown B, Noonan C, Harris KJ, et al. Developing and piloting the Journey to Native Youth Health program in Northern Plains Indian communities. Diabetes Educator. Jan-Feb. 2013;39(1):109-18. [pmid: 23150531].
4 Chiang C-Y, Sun FK. The effects of a walking program on older Chinese American immigrants with hypertension: a pretest and posttest quasi-experimental design. Public Health Nursing. May-Jun. 2009;26(3):240-8. [pmid: 19386059].
5 Eakin EG, Bull SS, Riley KM, et al. Resources for health: a primary-care-based diet and physical activity intervention targeting urban Latinos with multiple chronic conditions. Health Psychology. Jul. 2007;26(4):392-400. [pmid: 17605558].
6 Koniak-Griffin D, Brecht M-L, Takayanagi S, et al. A community health worker-led lifestyle behavior intervention for Latina (Hispanic) women: Feasibility and outcomes of a randomized controlled trial. International Journal of Nursing Studies. 2015;52(1):75-87. [pmid: 25307195].
7 Leeman-Castillo B, Beaty B, Raghunath S, et al. LUCHAR: using computer technology to battle heart disease among Latinos. American Journal of Public Health. Feb. 2010;100(2):272-5. [pmid: 20019305].
8 Ma GX, Shive S, Tan Y, et al. Community-based colorectal cancer intervention in underserved Korean Americans. Cancer Epidemiology. Nov. 2009;33(5):381-6. [pmid: 19914880].
9 Ma GX, Shive SE, Tan Y, et al. Development of a culturally appropriate smoking cessation program for Chinese-American youth. Journal of Adolescent Health. Sep. 2004;35(3):206-16. [pmid: 15313502].
10 Matthews AK, Sanchez-Johnsen L, King A. Development of a culturally targeted smoking cessation intervention for African American smokers. Journal of Community Health. Dec. 2009;34(6):480-92. [pmid: 19728056].
11 Newton RL Jr., Perri MG. A randomized pilot trial of exercise promotion in sedentary African-American adults. Ethnicity & Disease. 2004;14(4):548-57. [pmid: 15724775].
12 Shepherd JL, Fandel J, Esposito R, et al. Multidimensionality matters: An effective HIV, hepatitis C, and substance-use prevention program for minority parolees. Journal of Offender Rehabilitation. 2012;51(4):199-221.
13 Sparks SN, Tisch R, Gardner M. Family-centered interventions for substance abuse in Hispanic communities. Journal of Ethnicity in Substance Abuse. 2013;12(1):68-81. [pmid: 23480212].
14 Walkup JT, Barlow A, Mullany BC, et al. Randomized controlled trial of a paraprofessional-delivered in-home intervention for young reservation-based American Indian mothers. Journal of the American Academy of Child & Adolescent Psychiatry. Jun. 2009;48(6):591-601. [pmid: 19454915].
15 Weeks MR, Himmelgreen DA, Singer M, et al. Community-based AIDS prevention: Preliminary outcomes of a program for African American and Latino injection drug users. Journal of Drug Issues. 1996;26(3):561-590.

### Not Population (7)

1 Braithwaite RL, Stephens TT, Treadwell HM, et al. Short-term impact of an HIV risk reduction intervention for soon-to-be released inmates in Georgia. Journal of Health Care for the Poor & Underserved. Nov. 2005;16(4 Suppl B):130-9. [pmid: 16327112].
2 Cotton B, Smith A, Hansen I, et al. Physician-directed primary care intervention to reduce risk factors for type 2 diabetes in high-risk youth. American Journal of the Medical Sciences. Sep. 2006;332(3):108-11. [pmid: 16969138].
3 Kelly JA, McAuliffe TL, Sikkema KJ, et al. Reduction in risk behavior among adults with severe mental illness who learned to advocate for HIV prevention. Psychiatric Services. Oct. 1997;48(10):1283-8. [pmid: 9323747].
4 McKay MM, Stoewe J, McCadam K, et al. Increasing access to child mental health services for urban children and their caregivers. Health & Social Work. Feb. 1998;23(1):9-15. [pmid: 9522199].
5 Rawlings MK, Thompson MA, Farthing CF, et al. Impact of an educational program on efficacy and adherence with a twice-daily lamivudine/zidovudine/abacavir regimen in underrepresented HIV-infected patients. Journal of Acquired Immune Deficiency Syndromes: JAIDS. Oct. 1. 2003;34(2):174-83. [pmid: 14526206].
6 Simmons D, Gamble GD, Foote S, et al. The New Zealand Diabetes Passport Study: a randomized controlled trial of the impact of a diabetes passport on risk factors for diabetes-related complications. Diabetic Medicine. Mar. 2004;21(3):214-7. [pmid: 15008829].
7 Wise M, Pulvermacher A, Shanovich KK, et al. Using action research to implement an integrated pediatric asthma case management and eHealth intervention for low-income families. Health Promotion Practice. Nov. 2010;11(6):798-806. [pmid: 19515862].