# Search Strings

## Disability Search String

# | Searches
1 | meta analysis as topic/
2 | meta-analy$.tw.
3 | metaanaly$.tw.
4 | meta-analysis/
5 | (systematic adj (review$1 or overview$1)).tw.
6 | exp Review Literature as Topic/
7 | or/1-6
8 | cochrane.ab.
9 | embase.ab.
10 | (psychlit or psyclit).ab.
11 | (psychinfo or psycinfo).ab.
12 | or/8-11
13 | reference list$.ab.
14 | bibliograph$.ab.
15 | hand search.ab.
16 | relevant journals.ab.
17 | manual search$.ab.
18 | or/13-17
19 | selection criteria.ab.
20 | (data adj2 (extract* or abstract*)).ab.
21 | 19 or 20
22 | review/
23 | 21 and 22
24 | Comment/
25 | Letter/
26 | editorial/
27 | animal/
28 | human/
29 | 27 not (28 and 27)
30 | or/24-26,29
31 | 7 or 12 or 18 or 23
32 | 31 not 30
33 | randomized controlled trials as topic/
34 | randomized controlled trial/
35 | random allocation/
36 | double blind method/
37 | single blind method/
38 | clinical trial/
39 | clinical trial, phase i.pt.
40 | clinical trial, phase ii.pt.
41 | clinical trial, phase iii.pt.
42 | clinical trial, phase iv.pt.
43 | controlled clinical trial.pt.
44 | randomized controlled trial.pt.
45 | multicenter study.pt.
46 | clinical trial.pt.
47 | exp clinical trials as topic/
48 | or/33-47
49 | (clinical adj trial$).tw.
50 | ((singl$ or doubl$ or treb$ or tripl$) adj (blind$3 or mask$3)).tw.
51 | placebos/
52 | placebo$.tw.
53 | randomly allocated.tw.
54 | (allocated adj2 random$).tw.
55 | or/49-54
56 | 48 or 55
57 | case report.tw.
58 | letter/
59 | historical article/
60 | or/57-59
61 | 56 not 60
62 | exp cohort studies/ or comparative study/ or follow-up studies/ or prospective studies/ or cohort.mp. or compared.mp. or groups.mp. or multivariate.mp.
63 | cohort$.tw.
64 | controlled clinical trial.pt.
65 | epidemiological methods/
66 | limit 65 to yr=1971-1983
67 | or/62-64,66
68 | exp disabled person/ or (amputee$ or disabled person$ or disabled child$ or disab$ or disabled people or mentally disabled person$ or mentally disabled people or mentally ill person$ or mentally ill people or visually impaired person$ or visually impaired people or hearing impaired person$ or hearing impaired people).mp.
69 | exp mental disorders diagnosed in childhood/ or (Asperger Syndrome or Aperger$ or Autism or Autistic or Autistic Disorde$ or learning disabil$ or learning disorder$ or developmental disability$ or Attention Deficit Disorder$ or Attention Deficit Disorder with Hyperactivity or behavior$ disorder$ or conduct disorder$ or dyslexia or affective Disorder$ or mood disorder$ or depress$ or depress$ disorder$ or personality disorder$).mp.
70 | exp cognition disorders/ or (cognit$ disord$ or cognit$ disabil$ or Mild Cognitive Impairment$ or Huntington$ or cognitive$ impair$).mp.
71 | exp intellectual disability/ or (intellectual disab$ or Down Syndrome or mental$ retard$ or Fragile X or Rett Syndrome or Prader-Willi Syndrome or Williams Syndrome).mp.
72 | exp “Activities of Daily Living”/ or (activit$ of daily living or functional limitation$ or activity limitation$ or participation limitation$).mp.
73 | Mobility limitation/ or (mobility limitation$ or mobility impairment$).mp.
74 | Dependent ambulation/ or dependent ambulation.mp.
75 | Paraplegia/ or paraplegia.mp.
76 | Quadriplegia/ or quadriplegia.mp.
77 | Hearing loss/ or (hearing loss or hearing impair$ or deaf$).mp.
78 | Vision disorders/ or (blind$ or vis$ impair$).mp.
79 | exp self-help devices/ or (assist$ techn$ or Commun$ Aid$ or commun$ device$ or Wheelchair$).mp.
80 | Mental disorders/ or (mental disorder$ or psychiatric disabilit$ or mental health disabilit$ or mental health impairment$).mp.
81 | or/68-80
82 | minority groups/ or minority Health/
83 | exp health personnel/ed
84 | health services accessibility/ or healthcare disparities/
85 | “Attitude of Health Personnel”/
86 | Health Communication/
87 | (divers* adj3 (competenc* or understanding or knowledg* or expertise or skill* or sensitiv* or aware* or appropriate* or acceptab* or safe* or humility or service* or communicat* or barrier* or divers* or comparison* or identity or specific or background* or value* or belief*)).tw.
88 | stigma.tw.
89 | Comprehensive Health Care/mt [Methods]
90 | “Delivery of Health Care”/mt [Methods]
91 | Health Promotion/mt [Methods]
92 | or/82-91
93 | 61 and 81 and 92
94 | limit 93 to yr=“1990-Current”
95 | 32 and 81 and 92
96 | 95 not 94
97 | limit 96 to yr=“1990-Current”
98 | 67 and 81 and 92
99 | intervention*.ti,ab.
100 | program*.ti,ab.
101 | 99 or 100
102 | 98 and 101
103 | 102 not (94 or 97)
104 | limit 103 to yr=“1990-Current”

## Gender and Sexual Minority Search String

# | Searches
1 | meta analysis as topic/
2 | meta-analy$.tw.
3 | metaanaly$.tw.
4 | meta-analysis/
5 | (systematic adj (review$1 or overview$1)).tw.
6 | exp Review Literature as Topic/
7 | or/1-6
8 | cochrane.ab.
9 | embase.ab.
10 | (psychlit or psyclit).ab.
11 | (psychinfo or psycinfo).ab.
12 | or/8-11
13 | reference list$.ab.
14 | bibliograph$.ab.
15 | hand search.ab.
16 | relevant journals.ab.
17 | manual search$.ab.
18 | or/13-17
19 | selection criteria.ab.
20 | (data adj2 (extract* or abstract*)).ab.
21 | 19 or 20
22 | review/
23 | 21 and 22
24 | Comment/
25 | Letter/
26 | editorial/
27 | animal/
28 | human/
29 | 27 not (28 and 27)
30 | or/24-26,29
31 | 7 or 12 or 18 or 23
32 | 31 not 30
33 | randomized controlled trials as topic/
34 | randomized controlled trial/
35 | random allocation/
36 | double blind method/
37 | single blind method/
38 | clinical trial/
39 | clinical trial, phase i.pt.
40 | clinical trial, phase ii.pt.
41 | clinical trial, phase iii.pt.
42 | clinical trial, phase iv.pt.
43 | controlled clinical trial.pt.
44 | randomized controlled trial.pt.
45 | multicenter study.pt.
46 | clinical trial.pt.
47 | exp clinical trials as topic/
48 | or/33-47
49 | (clinical adj trial$).tw.
50 | ((singl$ or doubl$ or treb$ or tripl$) adj (blind$3 or mask$3)).tw.
51 | placebos/
52 | placebo$.tw.
53 | randomly allocated.tw.
54 | (allocated adj2 random$).tw.
55 | or/49-54
56 | 48 or 55
57 | case report.tw.
58 | letter/
59 | historical article/
60 | or/57-59
61 | 56 not 60
62 | exp cohort studies/ or comparative study/ or follow-up studies/ or prospective studies/ or cohort.mp. or compared.mp. or groups.mp. or multivariate.mp.
63 | cohort$.tw.
64 | controlled clinical trial.pt.
65 | exp teaching/
66 | exp health personnel/ed
67 | exp teaching materials/
68 | exp education/
69 | ((education* or teaching or learning or elearning or instruction* or training or skills or didactic or pedagogic* or online or online or web* or internet or cd-rom* or dvd or multimedia or multi-media or computer*) adj2 (intervention* or session* or course* or program* or activit* or presentation* or round* or material* or package* or module* or demonstration* or method* or process*)).tw.
70 | (inservice or in service or workshop* or (discussion adj1 group*) or lectur* or seminar* or (short adj2 course*) or role play* or immersion or mentor* or lifelong learning or life long learning).tw.
71 | ((staff or professional or workforce or work force) adj (development or training)).tw.
72 | ((medical or continuing or residency or distance) adj2 education).tw.
73 | ((cultural* or transcultural* or multicultural* or intercultural* or bicultural*) adj2 (education or train* or teach* or learn* or instruct* or coach* or skills or content*)).tw.
74 | (curriculum or curricul* intervent*).tw.
75 | or/62-74
76 | exp Bisexuality/ or bisexual*.mp.
77 | exp Transsexualism/ or transsexual*.mp.
78 | exp Homosexuality/ or homosexual*.mp.
79 | exp Transgendered Persons/ or transgender*.mp.
80 | (lgbt* or glbt*).mp.
81 | (gay or lesbian).mp.
82 | (“men who have sex with men” or msm or “women who have sex with women” or wsw).mp.
83 | (WSMW or WSWM or MSWM or MSMW).mp.
84 | sexual minority.mp.
85 | gender minority.mp.
86 | gender expression.mp.
87 | (gender identit* or sexual orientation or sexual identit*).mp.
88 | or/76-87
89 | 32 and 88
90 | 61 and 88
91 | 75 and 88
92 | limit 89 to yr=“1990-Current”
93 | limit 90 to yr=“1990-Current”
94 | limit 91 to yr=“1990-Current”
95 | intervention*.ti,ab.
96 | program*.ti,ab.
97 | curriculum.ti,ab.
98 | or/95-97
99 | 94 and 98
100 | 93
101 | 92 not 93
102 | 99 not (93 or 92)

## Racial/Ethnic Populations Search String

# | Searches
1 | meta analysis as topic/
2 | meta-analy$.tw.
3 | metaanaly$.tw.
4 | meta-analysis/
5 | (systematic adj (review$1 or overview$1)).tw.
6 | exp Review Literature as Topic/
7 | or/1-6
8 | cochrane.ab.
9 | embase.ab.
10 | (psychlit or psyclit).ab.
11 | (psychinfo or psycinfo).ab.
12 | or/8-11
13 | reference list$.ab.
14 | bibliograph$.ab.
15 | hand search.ab.
16 | relevant journals.ab.
17 | manual search$.ab.
18 | or/13-17
19 | selection criteria.ab.
20 | (data adj2 (extract* or abstract*)).ab.
21 | 19 or 20
22 | review/
23 | 21 and 22
24 | Comment/
25 | Letter/
26 | editorial/
27 | animal/
28 | human/
29 | 27 not (28 and 27)
30 | or/24-26,29
31 | 7 or 12 or 18 or 23
32 | 31 not 30
33 | randomized controlled trials as topic/
34 | randomized controlled trial/
35 | random allocation/
36 | double blind method/
37 | single blind method/
38 | clinical trial/
39 | clinical trial, phase i.pt.
40 | clinical trial, phase ii.pt.
41 | clinical trial, phase iii.pt.
42 | clinical trial, phase iv.pt.
43 | controlled clinical trial.pt.
44 | randomized controlled trial.pt.
45 | multicenter study.pt.
46 | clinical trial.pt.
47 | exp clinical trials as topic/
48 | or/33-47
49 | (clinical adj trial$).tw.
50 | ((singl$ or doubl$ or treb$ or tripl$) adj (blind$3 or mask$3)).tw.
51 | placebos/
52 | placebo$.tw.
53 | randomly allocated.tw.
54 | (allocated adj2 random$).tw.
55 | or/49-54
56 | 48 or 55
57 | case report.tw.
58 | letter/
59 | historical article/
60 | or/57-59
61 | 56 not 60
62 | exp cohort studies/ or comparative study/ or follow-up studies/ or prospective studies/ or cohort.mp. or compared.mp. or groups.mp. or multivariate.mp.
63 | cohort$.tw.
64 | controlled clinical trial.pt.
65 | epidemiological methods/
66 | limit 65 to yr=1971-1983
67 | or/62-64,66
68 | population groups/ or african continental ancestry group/ or african americans/ or indians, north american/ or inuits/ or asian americans/ or oceanic ancestry group/ or ethnic groups/ or arabs/ or hispanic americans/ or mexican americans/
69 | “Emigration and Immigration”/ or “Emigrants and Immigrants”/ or “Transients and Migrants”/ or refugees/
70 | race relations/ or racism/
71 | (immigrant* or migrant* or refugee* or (displaced and (people or person*)) or (“foreign born” or “non us born” or “non-us born”) or undocumented or second language* or ((language or english) and proficien*) or interpreter* or “minority group*” or “ethnic group*” or “urban health” or “urban population” or “inner city” or ethnic* or race or racial or minorit* or urban or inner-city or multiethnic).tw.
72 | (non-english or hispanic* or latin* or ((african or black or asian or native or mexican) adj american*) or inuit* or islander*).tw.
73 | or/68-72
74 | culture/ or cross-cultural comparison/ or cultural characteristics/ or cultural competency/ or cultural diversity/
75 | multilingualism/ or language/
76 | ((cultur* or linguistic* or language*) adj3 (competenc* or understanding or knowledg* or expertise or skill* or sensitiv* or aware* or appropriate* or acceptab* or safe* or humility or service* or communicat* or barrier* or divers* or comparison* or identity or specific or background* or value* or belief*)).tw.
77 | (intercultural* or inter-cultural or transcultural* or trans-cultural or cross-cultural or crosscultural or multicultural* or multicultural* or bicultural or bi-cultural or multilingual* or multi-lingual* or bilingual or bi-lingual).tw.
78 | transcultural nursing/
79 | minority groups/ or minority Health/
80 | ((cultural* or transcultural* or multicultural* or intercultural* or bicultural*) adj2 (education or train* or teach* or learn* or instruct* or coach* or skills or content*)).tw.
81 | Healthcare Disparities/
82 | stigma.mp.
83 | or/74-82
84 | 61 and 73 and 83
85 | limit 84 to yr=“1990-Current”
86 | 32 and 83
87 | 86 not 85
88 | limit 87 to yr=“1990-Current”
89 | 67 and 73 and 83
90 | intervention*.ti,ab.
91 | program*.ti,ab.
92 | 90 or 91
93 | 89 and 92
94 | 93 not (85 or 88)
95 | limit 94 to yr=“1990-Current”

## Cultural Competence Model Search String

# | Searches
1 | Culture/
2 | Cultural Competency/
3 | Anthropology, Cultural/
4 | Cultural Characteristics/
5 | Cultural Diversity/
6 | Cross-Cultural Comparison/
7 | (cultur* adj3 competenc*).tw.
8 | (cultur* adj3 understanding).tw.
9 | (cultur* adj3 knowledg*).tw.
10 | (cultur* adj3 skill*).tw.
11 | (cultur* adj3 sensitiv*).tw.
12 | (cultur* adj3 aware*).tw.
13 | (cultur* adj3 appropriate*).tw.
14 | (cultur* adj3 acceptab*).tw.
15 | (cultur* adj3 safe*).tw.
16 | (cultur* adj3 service*).tw.
17 | (cultur* adj3 communicat*).tw.
18 | (cultur* adj3 barrier*).tw.
19 | (cultur* adj3 divers*).tw.
20 | (cultur* adj3 comparison*).tw.
21 | (cultur* adj3 identity*).tw.
22 | (cultur* adj3 specific*).tw.
23 | (cultur* adj3 background*).tw.
24 | (cultur* adj3 value*).tw.
25 | (cultur* adj3 belief*).tw.
26 | Transcultural Nursing/
27 | (intercultural* or inter-cultural or transcultural* or trans-cultural or cross-cultural or crosscultural or multicultural* or multi-cultural* or multiethnic or bicultural or bi-cultural or multilingual* or multi-lingual* or bilingual or bi-lingual).tw.
28 | “Emigration and Immigration”/
29 | “Emigrants and Immigrants”/
30 | “Transients and Migrants”/
31 | Refugees/
32 | exp Population Groups/
33 | Minority Groups/
34 | Minority Health/
35 | (immigrant* or migrant* or refugee* or ethnic* or racial or indigenous or aborigin*).tw.
36 | (non-english or hispanic* or latino* or ((african or black or asian or native or mexican) adj american*) or inuit* or maori or islander*).tw.
37 | exp Bisexuality/ or exp Transsexualism/ or exp Homosexuality/ or exp Homosexuality, Female/ or lgbt.mp. or exp Homosexuality, Male/ or exp Sexual Behavior/
38 | exp child development disorders/
39 | exp child development disorders, pervasive/
40 | exp communication disorders/
41 | exp developmental disabilities/
42 | exp learning disorders/
43 | exp intellectual disability/
44 | exp psychomotor disorders/
45 | exp Disabled Persons/
46 | exp Disabled Children/
47 | exp Models, Nursing/
48 | exp Models, Theoretical/
49 | model*.mp. or framework*.tw. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier]
50 | exp Models, Organizational/
51 | delivery of health care/
52 | patient-centered care/
53 | health knowledge attitudes practice/
54 | exp Clinical Competence/ or exp Professional Competence/
55 | or/1-27
56 | or/28-46
57 | or/47-50
58 | or/51-54
59 | 55 and 56 and 57
60 | 55 and 56 and 57 and 58

This section briefly summarizes the methods used to search for the conceptual models. We searched Ovid MEDLINE® from 1990, when the concept of cultural competence gained traction, to February 2014. We used natural language key words and MeSH terms to capture the concepts of cultural competence, models, and the three included priority populations.

Two independent reviewers screened the references for articles that described the development of a cultural competence model, reviewed models of cultural competence, or appeared to have likely used a cultural competence model as the basis for research in order to identify likely models. Full texts of articles that might be a source for a model were then pulled and examined for likely descriptions of or references to cultural competence models. This process necessarily required backward citation searching to locate original source material for models. Identified models were included if they were intended for use by the formal healthcare system, were designed for or applicable to at least one of the three priority populations, and suggested possible point of interventions to improve cultural competence of providers or the healthcare system. Mid-level models that examined only one facet or factor of cultural competence, or only one type of patient behavior (such as help-seeking) were not included. Models were then collated and presented as unique models with one citation for the source from which it was eventually drawn. Each model was abstracted directly into an evidence table for whether the model focused primarily on the inner experience of the provider, externally on the person(s) the provider would be interacting with, or both; a brief description of the model; and the model characteristics. One investigator abstracted the model and a second investigator quality checked the abstraction.