# Analytic Framework

Figure A1 Analytic framework for improving cultural competence to reduce disparities in priority populations

Figure A1 displays the flow diagram illustrating thel path for patients from the priority populations presenting to their providers and the health system for care. Interventions that are intended to improve the cultural competence of the system in order to provide culturally appropriate care lead to intermediate outcomes for providers such as improved provider motivation, behaviors, attitudes, beliefs, cognitions toward the priority populations, and organizational adaptation. Interventions may also generate patient intermediate outcomes such as patient knowledge and behaviors, beliefs and cognitions, satisfaction, and improved access to care. The intermediate outcomes eventually lead to final health outcomes that reduce the gaps in health disparities for patient medical and mental health outcomes. However, there is also the possibility of the interventions generating negative unintended consequences.