# Abbreviations

AAMC: American Association of Medical Colleges
A-CBT: Accommodated version of cognitive-behavioral treatment
ACS: American Community Survey
AHRQ: Agency for Healthcare Research and Quality
AI/AN: American Indian and Alaska Native
AIMS2: Arthritis Self-Efficacy Scale
AQ-9: Attribution Questionnaire
ASES: Arthritis Self-Efficacy Scale
ASO: AIDS service organization
AwQ: Awareness Questionnaire
BV: Bacterial vaginosis
CALD: Culturally and linguistically diverse
CAMI: Community Attitudes towards the Mentally Ill
CBT: Cognitive behavioral therapy
CC: Cultural competency
CES-D: Center for Epidemiological Studies Depression Scale
CHAP: Comprehensive Health Assessment Program
CLAS: Culturally and linguistically appropriate services
CM: Contingency management
CMPPQ: Comorbidity Problems Perceptions Questionnaire
CVD: Cardiovascular disease
DSMT: Diabetes self-management training
ERMIS: Emotional Reactions to Mental Illness Scale
ESL: English as a second language
FIS: Fatigue Impact Scale
FSS: Fatigue Severity Scale
GBM: Gay and bisexual men
HAART: Highly active antiretroviral treatment
HAN-D: Hamilton Depression Rating Scale
HIV: Human immunodeficiency virus
ICF: International Classification of Functioning, Disability, and Health
IDs: Intellectual disabilities
IES-Revised: Impact of Event Scale-Revised
KQ: Key Question
LGBT: Lesbian, gay, bisexual, and transgender
MAKS: Mental Health Knowledge Schedule
MHFA: Mental Health First Aid
MICA: Mental Illness: Clinicians Attitudes Scale
MSM: Men who have sex with men
MSMW: Men who have sex with men and women
OMS-HC: Opening Minds Scale for Health Care Providers
PASHIN: Providers Advocating for Sexual Health Initiative
PHP: Personal health profile
PICOTS: Population, Interventions, Comparators, Outcomes, Timing, Settings
PTSD: Post-traumatic stress disorder
QLS: Quality of Life Scale
RA: Rheumatoid arthritis
RAPID: Rapid Assessment of Disease Activity in Rheumatology
RCT: Randomized controlled trial
REMAS-CA: Real Men Are Safe—culturally adapted version
RIBS: Reported and Intended Behaviour Scale
S-CBT: Standard cognitive-behavioral substance abuse treatment
SDS: Self-Determination Scale
SMW: Sexual minority women
SPS: Social Provisions Scale
STI: Sexually transmitted infection
SUN: Study to Understand the Natural History of HIV/AIDS in the Era of Effective Therapy
WAI: Working Alliance Inventory
WSW: Women who have sex with women
WSWM: Women who have sex with women and men