# Summary and Discussion

## EPC GRADE

Results for major clinical outcomes are summarized in an EPC GRADE table of evidence (Table 12). Major clinical outcomes are those explicitly stated in key questions 1 and 2; identified as important outcomes by members of the Technical Expert Panel because they are most relevant to patients, clinicians, and policymakers; and have adequate data from studies meeting eligibility criteria for the comparative effectiveness review. Outcomes included in the GRADE table are invasive breast cancer, estrogen receptor positive breast cancer, estrogen receptor negative breast cancer, noninvasive breast cancer, all-cause death, vertebral fractures, nonvertebral fractures, thromboembolic events, coronary heart disease events, stroke, endometrial cancer, and cataracts.

Table 12 GRADE table of evidence for major health outcomes

Number of studies; number of subjects | Domains Pertaining to Strength of Evidence | | | | Strength of Evidence and Magnitude of Effect
| Risk of Bias | Consistency | Directness | Precision | Risk Ratio (95% CI; number of trials)Number of events reduced or increased per 1000 women years assuming 5 years of use (95% CI)
Invasive breast cancer | | | | | High for tamoxifen and raloxifene; moderate for tibolone
Head to head RCT 1 raloxifene vs tamoxifen; 19,747 | Low | Unknown (single study) | Direct | Precise | 1.02 (0.82, 1.28; 1 trial)
4 tamoxifen vs placebo RCTs; 28,421 | Low | No inconsistency | Indirect | Precise | 0.70 (0.59, 0.82; 4 trials) 7 (4, 12) fewer than placebo
2 raloxifene vs placebo RCTs; 17,806 | Low | No inconsistency | Indirect | Precise | 0.44 (0.27, 0.71; 2 trials) 9 (4, 14) fewer than placebo
1 tibolone vs placebo RCT; 4,506 | Low | Unknown (single study) | Indirect | Precise | 0.32 (0.13, 0.80; 1 trial) 10 (3, 17) fewer than placebo
Estrogen receptor positive breast cancer | | | | | High for tamoxifen and raloxifene; insufficient for tibolone
Head to head RCT 1 raloxifene vs tamoxifen; 19,747 | Low | Unknown (single study) | Direct | Precise | 0.93 (0.72, 1.24; 1 trial)
4 tamoxifen vs placebo RCTs; 28,421 | Low | No inconsistency | Indirect | Precise | 0.58 (0.42, 0.79; 4 trials) 8 (3, 13) fewer than placebo
2 raloxifene vs placebo RCTs; 17,806 | Low | No inconsistency | Indirect | Precise | 0.33 (0.18, 0.61; 2 trials) 8 (4, 12) fewer than placebo
Estrogen receptor negative breast cancer | | | | | Moderate for tamoxifen and raloxifene; insufficient for tibolone
Head to head RCT 1 raloxifene vs tamoxifen; 19,747 | Low | Unknown (single study) | Direct | Imprecise^*^ | 1.15 (0.75, 1.77; 1 trial)
4 tamoxifen vs placebo RCTs; 28,421 | Low | No inconsistency | Indirect | Imprecise^*^ | 1.19 (0.92, 1.55; 4 trials)
2 raloxifene vs placebo RCTs; 17,806 | Low | No inconsistency | Indirect | Imprecise^*^ | 1.25 (0.67, 2.31; 2 trials)
Noninvasive breast cancer | | | | | Moderate for raloxifene; low for tamoxifen; insufficient for tibolone
Head to head RCT 1 raloxifene vs tamoxifen; 19,747 | Low | Unknown (single study) | Direct | Imprecise^*^ | 1.40 (0.98, 2.00; 1 trial)
4 tamoxifen vs placebo RCTs; 28,421 | Low | Inconsistent^†^ | Indirect | Imprecise^*^ | 0.85 (0.54, 1.35; 4 trials)
2 raloxifene vs placebo RCTs; 17,806 | Low | No inconsistency | Indirect | Imprecise^*^ | 1.47 (0.75, 2.91; 2 trials)
All-cause death (short-term) | | | | | High for raloxifene and tamoxifen; insufficient for tibolone
Head to head RCT 1 raloxifene vs tamoxifen; 19,747 | Low | Unknown (single study) | Direct | Precise | 0.94 (0.71, 1.26; 1 trial)
4 tamoxifen vs placebo RCTs; 28,421 | Low | No inconsistency | Indirect | Precise | 1.07 (0.90, 1.27; 4 trials)
2 raloxifene vs placebo RCTs; 14,112 | Low | No inconsistency | Indirect | Precise | 0.91 (0.81, 1.02; 2 trials)
1 tibolone vs placebo RCT; 4,506 | Low | Unknown (single study) | Indirect | Not estimable^‡^ | 26 deaths tibolone vs. 28 placebo; p=0.89 in LIFT trial
Vertebral fractures | | | | | High for raloxifene; moderate for tibolone; low for tamoxifen
Head to head RCT 1 raloxifene vs tamoxifen; 19,747 | Low | Unknown (single study) | Direct | Imprecise^*^ | 0.98 (0.65, 1.46; 1 trial)
1 tamoxifen vs placebo RCT; 13,388 | Low | Unknown (single study) | Indirect | Imprecise^*^ | 0.75 (0.48, 1.15; 1 trial)
2 raloxifene vs placebo RCTs; 16,929 | Low | No inconsistency | Indirect | Precise | 0.61 (0.54, 0.69; 2 trials) 7 (5, 9) fewer than placebo
1 tibolone vs placebo RCT; 4,146 | Low | Unknown (single study) | Indirect | Precise | 0.55 (0.41, 0.74; 1 trial) 44 (25, 61) fewer than placebo
Nonvertebral fractures | | | | | High for raloxifene; moderate for tamoxifen and tibolone
1 tamoxifen vs placebo RCT; 13,388 | Low | Unknown (single study) | Indirect | Precise | 0.66 (0.45, 0.98; 1 trial) 3 (0.2, 5) fewer than placebo
2 raloxifene vs placebo RCTs; 14,112 | Low | No inconsistency | Indirect | Precise | 0.97 (0.87, 1.09; 2 trials)
1 tibolone vs placebo RCT; 4,506 | Low | Unknown (single study) | Indirect | Precise | 0.74 (0.58, 0.93; 1 trial) 34 (8, 56) fewer than placebo
Thromboembolic events | | | | | High for raloxifene and tamoxifen; low for tibolone
Head to head RCT 1 raloxifene vs tamoxifen; 19,747 | Low | Unknown (single study) | Direct | Precise | 0.70 (0.54, 0.91; 1 trial) 6 (2, 10) more with tamoxifen
4 tamoxifen vs placebo RCTs; 28,421 | Low | No Inconsistency | Indirect | Precise | 1.93 (1.41, 2.64; 4 trials) 4 (2, 9) more than placebo
8 raloxifene vs placebo RCTs; 19,774 | Low | No inconsistency | Indirect | Precise | 1.60 (1.15, 2.23; 2 trials) 7 (2, 15) more than placebo
3 tibolone vs placebo RCT; 6,051 | Low | Unknown (single study) | Indirect | Imprecise^*^ | 0.57 (0.19, 1.69; 1 trial)
Coronary Heart Disease Events | | | | | High for raloxifene and tamoxifen; low for tibolone
Head to head RCT 1 raloxifene vs tamoxifen; 19,747 | Low | Unknown (single study) | Direct | Precise | 1.10 (0.85, 1.43; 1 trial))
4 tamoxifen vs placebo RCTs; 28,421 | Low | No inconsistency | Indirect | Precise | 1.00 (0.79, 1.27; 4 trials)
2 raloxifene vs placebo RCTs; 17,806 | Low | No inconsistency | Indirect | Precise | 0.95 (0.84, 1.06; 2 trials)
2 tibolone vs. placebo RCTs; 4,902 | Low | Unknown | Indirect | Imprecise^*^ | 1.37 (0.77, 2.45; 1 trial)
Stroke | | | | | Moderate for tamoxifen, raloxifene, and tibolone
Head to head RCT 1 raloxifene vs tamoxifen; 19,747 | Low | Unknown (single study) | Direct | Imprecise^*^ | 0.96 (0.64, 1.43; 1 trial)
4 tamoxifen vs placebo RCTs; 28,421 | Low | No inconsistency | Indirect | Imprecise^*^ | 1.36 (0.89, 2.08; 4 trials)
2 raloxifene vs placebo RCTs; 15,314 | Low | Inconsistent^§^ | Indirect | Precise | 0.96 (0.67, 1.38; 2 trials)
1 tibolone vs placebo RCT; 4,506 | Low | Unknown (single study) | Indirect | Precise | 2.19 (1.14, 4.23; 1 trial) 11 (1, 36) more with tibolone
Endometrial cancer | | | | | High for tamoxifen; moderate for raloxifene; insufficient for tibolone
Head to head RCT 1 raloxifene vs tamoxifen; 19,747 | Low | Unknown (single study) | Direct | Imprecise^*^ | 0.62 (0.35, 1.08; 1 trial)
3 tamoxifen vs placebo RCTs;15,401 | Low | No inconsistency | Indirect | Precise | 2.13 (1.3, 3.32; 3 trials) 4 (1, 10) more with tamoxifen
2 raloxifene vs placebo RCTs; 13,741 | Low | No inconsistency | Indirect | Imprecise^*^ | 1.14 (0.65, 1.98; 2 trials)
2 tibolone vs placebo RCTs; 4,385 | Low | Unknown | Indirect | Not estimable^‡^ | 0 cases tibolone vs. 4 placebo; p=0.06 in LIFT trial
1 tibolone observational study; 28,028 | High\|\| | Unknown | Indirect | Precise | 1.79 (1.43, 2.25; 1 study)
Cataracts | | | | | High for raloxifene; low fo tamoxifen; insufficient for tibolone r
Head to head RCT 1 raloxifene vs tamoxifen; 19,747 | Low | Unknown (single study) | Direct | Precise | 0.79 (0.68, 0.92; 1 trial) 13 (5, 21) more with tamoxifen
3 tamoxifen vs placebo RCTs; 21,857 | Low | Inconsistent^†^ | Indirect | Imprecise^*^ | 1.25 (0.93, 1.67; 3 trials)
2 raloxifene vs placebo RCTs; 17,717 | Low | No inconsistency | Indirect | Precise | 0.93 (0.84, 1.04; 2 trials)

* Estimates indicating no statistically significant differences between comparators with confidence intervals wider than 0.67 to 1.50 are considered imprecise because they could be compatible with different clinical conclusions.

† Results of the NSABP P-1 trial differ from results of the meta-analysis.

‡ Low number of events and short duration of treatment and follow-up (2.8 years) limit this outcome measure from the LIFT trial.

§ Point estimates are inconsistent and may reflect population heterogeneity between the MORE and RUTH trials for this outcome.

|| Tibolone users in this study are highly selected introducing bias for this outcome.

See appendix and text for definitions of terms used in this table.

The EPC GRADE table includes the four required domains–risk of bias, consistency, directness, and precision (terms defined in Appendix C-2).15 Additional optional domains were not included in the table because they are not relevant to this review (Appendix C-4). The table summarizes the strength of evidence; estimates of effect using risk ratios from trials and meta-analyses detailed in the report; and estimates of magnitude of effect expressed as the number of events reduced or increased per 1000 women years assuming 5 years of use of tamoxifen, raloxifene, or tibolone.

### Risk of Bias

Risk of bias incorporates both study design and study conduct.15 In general, we ranked risk of bias low because results for all major outcomes were derived from randomized controlled trials with good aggregate quality. These included eight large randomized controlled trials that each met criteria for fair or good quality based on their use of appropriate clinical trial methodology and analysis (Appendix C-5). Additional smaller trials provided data on harms. Although these studies are included in the review and GRADE table, they rarely reported the major clinical outcomes addressed by the table. No nonrandomized effectiveness studies of medications to reduce risk for primary breast cancer have been published. No relevant observational studies of tamoxifen, and only one of raloxifene were identified in our searches or by our technical experts. Observational studies of tibolone, such as the Million Women Study, are likely biased for some of the major outcomes in the GRADE table because they focus on women using tibolone to treat menopausal symptoms.98,103 This design introduces multiple uncontrolled confounders compromising results.

### Consistency

Consistency refers to the degree of similarity in the effect sizes of different studies within an evidence base.15 In most cases, we ranked this domain as consistent for tamoxifen and raloxifene because the effect sizes of randomized controlled trials for the major clinical outcomes were generally in the same direction of effect, they usually had narrow ranges of effect sizes, and results of placebo-controlled trials were generally consistent with results of the STAR head-to-head trial. We also considered measures of heterogeneity from our meta-analyses in evaluating consistency (Figures 3 to 19). We ranked this domain inconsistent for noninvasive breast cancer and cataracts for tamoxifen because the results of the placebo-controlled NSABP P-1 trial differed from the meta-analysis of tamoxifen trials. The NSABP P-1 trial is particularly relevant because it is based in the United States, is the largest trial, and meets criteria for good quality and applicability. Results for tibolone were based on a single trial and consistency could not be evaluated.

### Directness

Directness has two meanings: (1) evidence links the interventions directly to health outcomes, and (2) evidence compares two or more interventions in head-to-head trials.15 All trials included in this review linked the evidence directly to health outcomes. The EPC GRADE table focuses on the second meaning for directness, whether evidence came from direct (head-to-head) or indirect (placebo-controlled) trials. Direct evidence comparing tamoxifen and raloxifene resolved important discrepancies arising from the placebo-controlled trials, such as magnitudes of effect. Women enrolled in the raloxifene placebo-controlled trials were 15 to 20 years older than women in the tamoxifen placebo-controlled trials. This age difference accounts for the higher incidence rates of most of the clinical outcomes in the raloxifene trials. Older women have higher risks for breast cancer, thromboembolic events, and other outcomes than younger women and would likely demonstrate larger medication effects for benefits as well as harms. The STAR trial allows direct comparisons between similar groups of women providing a better assessment of advantages and disadvantages of one medication over the other. Women in STAR were more similar to women in the tamoxifen than the raloxifene trials because they were closer in age and inclusion criteria were based on breast cancer risk as determined by the Gail model. No head-to-head trials including tibolone are available.

### Precision

Precision is the degree of certainty surrounding an estimate of effect for specific outcomes.15 The methodology for determining precision for EPC GRADE tables emphasizes the need to include both clinical and statistical considerations (Appendix C-2). For this comparative effectiveness review, we considered estimates precise if they provided statistically significant differences between medications, or between medications and placebo, for major clinical outcomes that would support clinical decisions (conceptual confidence). Estimates were also considered precise if they showed no statistically significant differences between comparators, and confidence intervals did not range beyond 0.67 to 1.50 (statistical precision of effect estimation). Estimates indicating no statistically significant differences between comparators with wider confidence intervals were considered imprecise because they could be compatible with different clinical conclusions.

Most comparisons in the EPC GRADE table met criteria for precise estimates (Table 12). Estimates are imprecise for some comparisons with placebo including estrogen receptor negative breast cancer (tamoxifen, raloxifene), noninvasive breast cancer (tamoxifen, raloxifene), vertebral fractures (tamoxifen), thromboembolic events (tibolone), coronary heart disease events (tibolone), stroke (tamoxifen), endometrial cancer (raloxifene), and cataracts (tamoxifen). For head-to-head comparisons of raloxifene and tamoxifen, estimates are imprecise for estrogen receptor negative breast cancer, noninvasive breast cancer, vertebral fractures, stroke, and endometrial cancer.

### Strength of Evidence

We qualitatively rated the overall strength of evidence as high, moderate, low, or insufficient for each outcome based on the required domains and other relevant factors (Appendix C-3). Strength of evidence is high for outcomes with low risk of bias, consistency, and adequate precision. Outcomes with results from placebo-controlled trials that were consistent with results from the head-to-head STAR trial provided additional support for the high strength of evidence grade. Outcomes with high strength of evidence include invasive breast cancer (tamoxifen, raloxifene), estrogen receptor positive breast cancer (tamoxifen, raloxifene), all-cause death (short-term) (tamoxifen, raloxifene), vertebral fractures (raloxifene), nonvertebral fractures (raloxifene), thromboembolic events (tamoxifen, raloxifene), coronary heart disease events (tamoxifen, raloxifene), endometrial cancer (tamoxifen), and cataracts (raloxifene) (Table 12).

The strength of evidence for outcomes with imprecise estimates, inconsistency between trials, or based on only one trial was downgraded to moderate. These include invasive breast cancer (tibolone), estrogen receptor negative breast cancer (tamoxifen, raloxifene), noninvasive breast cancer (raloxifene), vertebral fractures (tibolone), nonvertebral fractures (tamoxifen, tibolone), stroke (tamoxifen, raloxifene, tibolone), and endometrial cancer (raloxifene).

Strength of evidence was ranked low if multiple deficiencies existed. Strength of evidence for tamoxifen was low for noninvasive breast cancer and cataracts because placebo-controlled trials were both inconsistent and imprecise; also, results of placebo-controlled trials were inconsistent with STAR for cataracts. Strength of evidence for tamoxifen was ranked low for vertebral fractures because the one placebo-controlled trial reporting this outcome was imprecise and was not designed to detect vertebral fractures as rigorously as trials of the other medications. We graded the strength of evidence for tibolone low for thromboembolic events and coronary heart disease events because estimates were based on only one trial and were imprecise. Strength of evidence for tibolone was insufficient for estrogen receptor positive breast cancer, estrogen receptor negative breast cancer, noninvasive breast cancer, all-cause death, endometrial cancer, and cataracts because these outcomes were either not reported, or the numbers of events were too low and duration of treatment and follow-up too short to provide useful estimates.

## Applicability

All primary prevention trials except the Italian trial met criteria for good applicability. The Italian trial exclusively enrolled women who had undergone prior hysterectomy for reasons other than cancer28 as described in Results (Appendix C-5). For each trial, interventions, comparators, outcomes, and timing of outcome measures were appropriate. All trials were multicenter and relevant to primary care. In addition, trials were conducted in settings appropriate to clinical practice, enrolled subjects selected with broad eligibility criteria, assessed health outcomes, and had follow-up periods of several years. For these reasons, the trials provided information about effectiveness as well as efficacy of the medications.

Although inclusion criteria differed between the primary prevention trials, results for breast cancer outcomes were similar. These findings support good aggregate applicability to the target population of women without pre-existing breast cancer. Most older women with osteoporosis enrolled in the MORE and LIFT trials, and those with cardiovascular disease or risk factors enrolled in the RUTH trial, would have met risk factor eligibility criteria for the STAR and NSABP P-1 tamoxifen trials based on age. Women not well represented in the trials are those who are younger (<55 years old), have Gail scores <1.66% or considered low risk by other criteria used by some of the trials, are nonwhite, or are from outside North America, the UK, and Europe. Also, premenopausal women were excluded from the raloxifene and tibolone trials.

Clinicians can consider the results of trials to be most applicable to patients with similar characteristics as the study populations. Specifically, tamoxifen results apply to younger pre and postmenopausal women meeting breast cancer risk criteria; tibolone results apply to older postmenopausal women with osteoporosis; and raloxifene results apply to postmenopausal women meeting breast cancer risk criteria, and older postmenopausal women with osteoporosis or cardiovascular disease and/or risk factors for cardiovascular disease.

Applicability may be more limited for other outcomes. Fracture reduction is better for women with osteoporosis than for those without it.134 It would be expected that fracture reduction would be greater in the MORE trial of raloxifene and LIFT trial of tibolone that enrolled women with known osteoporosis. However, osteoporosis is common and often undiagnosed in the target population, as well as among women enrolled in the other primary prevention trials. Fractures were reduced in most trials, including those that did not specifically enroll women with osteoporosis, supporting the applicability of this effect.

The applicability of trials for adverse effect outcomes is more difficult to determine. Trials varied in how these outcomes were measured and reported, it is not known how risk factors for adverse effect outcomes varied among subjects, and results were not reported for specific sub-groups. Most studies were small and included highly selected participants from outside the United States. Several studies of tibolone enrolled women seeking treatment of menopausal vasomotor symptoms.

## Summary of Results

### Benefits (Key Questions 1 and 3)

All three medications, tamoxifen, raloxifene, and tibolone, reduced the incidence of invasive breast cancer in midlife and older women without pre-existing breast cancer by 30% to 68%. The direct comparison trial, STAR, indicated similar effects for tamoxifen and raloxifene. Indirect comparison analysis indicated that results of a placebo-controlled trial of tibolone were not significantly different than results of placebo-controlled trials of raloxifene. Reduction of invasive breast cancer continued after discontinuation of tamoxifen in trials providing follow-up data. Tamoxifen and raloxifene reduced estrogen receptor positive but not estrogen receptor negative breast cancer, and had similar effects on these subtypes when directly compared. Tamoxifen reduced noninvasive breast cancer, including ductal carcinoma in situ (DCIS), in the NSABP P-1 trial, but not in the other tamoxifen trials. Raloxifene did not decrease noninvasive cancer, and the STAR trial suggested that more women using raloxifene had noninvasive breast cancer than those using tamoxifen.

Tamoxifen and raloxifene reduced invasive breast cancer for all population subgroups evaluated. They had similar effects regardless of age and family history of breast cancer in the STAR trial. Tamoxifen reduced breast cancer outcomes in subgroups evaluated in placebo-controlled primary prevention trials based on age, menopausal status, estrogen use, family history of breast cancer, and history of lobular carcinoma in situ (LCIS) or atypical hyperplasia. In the NSABP P-1 trial, cancer rates were highest and risk reduction greatest among women in the highest Gail model risk category and among women with prior atypical hyperplasia. Raloxifene reduced breast cancer outcomes in subgroups based on age, age at menarche, parity, age at first live birth, and body mass index. Estimates from subgroups based on prior estrogen use, family history of breast cancer, and prior hysterectomy or oophorectomy were limited by small numbers of subjects. Population subgroups have not been evaluated for tibolone.

All-cause mortality was similar for women using raloxifene compared to tamoxifen, or tamoxifen, raloxifene, or tibolone compared to placebo. Tamoxifen did not reduce breast cancer mortality compared to placebo. Tamoxifen and raloxifene had similar effects on fractures at multiple sites in the STAR trial. In placebo-controlled trials, raloxifene and tibolone reduced vertebral fractures, tamoxifen and tibolone reduced nonvertebral fractures, and tibolone reduced wrist but not hip fractures.

### Harms (Key Question 2 and 3)

Tamoxifen and raloxifene increased risk for thromboembolic events compared to placebo. Raloxifene caused fewer thromboembolic events than tamoxifen in the STAR trial. Tamoxifen caused more thromboembolic events for older (>50 or 60 years) than younger women. Risk returned to normal after discontinuation of tamoxifen in the trials providing post treatment data. Tibolone did not increase risk for thromboembolic events. None of these medications increased risk for coronary heart disease events. Tibolone caused more strokes than placebo resulting in early discontinuation of the LIFT trial. Subgroup analysis indicated that risk for stroke was higher for older (>70 years) than younger women. Tamoxifen and raloxifene did not increase risk for stroke.

Raloxifene caused fewer cases of endometrial hyperplasia and was associated with fewer hysterectomies than tamoxifen in the STAR trial; differences for endometrial cancer were not significantly different. In placebo-controlled trials, tamoxifen caused more cases of endometrial cancer, and risk was higher in older than younger women. Raloxifene did not increase risk for endometrial cancer or uterine bleeding compared to placebo. Tibolone did not increase risk for endometrial cancer in clinical trials, but was associated with more cases of endometrial cancer in a large cohort study.

Raloxifene caused fewer cataracts and cataract surgeries than tamoxifen in the STAR trial and did not increase risk for cataracts or cataract surgery in placebo-controlled trials. Tamoxifen was associated with more cataract surgeries than placebo in one trial.

Medications caused several additional symptoms. In direct comparisons, women using raloxifene reported more musculoskeletal problems, dyspareunia, and weight gain, while those using tamoxifen had more gynecological problems, vasomotor symptoms, leg cramps, and bladder control symptoms. Some of the most common side effects for tamoxifen were hot flashes and other vasomotor symptoms, vaginal discharge, and other vaginal symptoms such as itching or dryness. For raloxifene, common side effects were vasomotor symptoms and leg cramps. Tibolone increased vaginal bleeding, but in contrast to the SERMs, it reduced the number and severity of hot flashes and reduced risk for colon cancer.

### Patient Choice, Concordance, Adherence, and Persistence (Key Question 4)

Evidence about patient treatment choice, concordance, adherence, and persistence to treatment was lacking. Comparisons of adherence and persistence rates across medications in primary prevention trials were limited because few trials reported treatment duration, completion rates, or other measures of adherence and persistence. Also, trials were designed for different treatment purposes. From the few trials reporting data about discontinuation, rates for tamoxifen or raloxifene were generally higher than placebo, but differences between treatment and placebo groups were low (≤2% for adverse events and ≤4% for nonprotocol specified events). No data were available for tibolone.

Regarding treatment choice, small descriptive studies indicate that women make decisions to use tamoxifen to reduce breast cancer risk based on their concern for adverse effects as well as their risk for breast cancer. They weigh their physicians’ recommendations highly when deciding whether to take tamoxifen. Similar data for raloxifene and tibolone are lacking. No studies about how women choose among multiple risk reducing medications have been published.

### Risk Assessment (Key Question 5)

Research on risk assessment to identify women who could benefit from medications to reduce breast cancer risk focuses on nine risk stratification models evaluated for use in clinical settings. Models consider multiple risk factors for breast cancer, and some are derived from the original Gail model. Risk stratification models demonstrate high calibration, with the expected number of breast cancer cases in a study population closely matching the number of breast cancer cases observed. All models have low discriminatory accuracy in predicting the probability of breast cancer in an individual. Most models perform only slightly better than age alone as a risk predictor. Models that include breast density, postmenopausal hormone use, and a more extensive family history show promise in improving the predictive risk. A Gail score of ≥ 1.66% has been used as a risk threshold in primary prevention trials and in U.S. Food and Drug Administration approval of tamoxifen and raloxifene for reducing risk for primary breast cancer. However, this threshold has low discriminatory accuracy in predicting the probability of breast cancer in an individual. Most women age 60 and older without other risk factors would meet this threshold by age alone.

### Clinical Implications and Limitations

Based on our meta-analysis of placebo-controlled primary prevention trials, the calculated number needed to treat (NNT) to prevent one case of invasive breast cancer assuming 5 years of use is similar for all three medications: 142 (95% CI 84, 280) for tamoxifen, 112 (71, 236) for raloxifene, and 105 (58, 302) for tibolone (Tables 13, 14, 15). The STAR trial indicates similar results for tamoxifen and raloxifene (Table 16). Women and clinicians may interpret these findings as beneficial and consider use of these medications as a promising approach to reducing risk for breast cancer. In the United States, the current choices are raloxifene and tamoxifen, both also capable of reducing risk for fractures.

Table 13 Estimates of number needed to treat or harm for tamoxifen

Outcomes | RR (95% CI) | Trials | Placebo Rate (SE)^*^ | Number of Events Reduced/Increased (95% CI)^†^ | Number Needed to Treat/Harm (95% CI)^‡^
Breast cancer reduced
All breast cancer^§^ | 0.72 (0.61, 0.86) | 4 | 5.54 (1.32) | 8 (3, 15) | 129 (72, 286)
Invasive | 0.70 (0.59, 0.82) | 4 | 4.70 (1.02) | 7 (4, 12) | 142 (84, 280)
Estrogen receptor + | 0.58 (0.42, 0.79) | 4 | 3.67 (0.78) | 8 (3, 13) | 130 (76, 294)
Fractures reduced
Vertebral | 0.75 (0.48, 1.15) | 1
Nonvertebral | 0.66 (0.45, 0.98) | 1 | 1.55 (0.20) | 3 (0.2, 5) | 380 (196, 1798)
Thromboembolic events increased\|\| | 1.93 (1.41, 2.64) | 4 | 0.91 (0.19) | 4 (2, 9) | 236 (117, 578)
Deep vein thrombosis | 1.45 (0.89, 2.37) | 2
Pulmonary embolus | 2.69 (1.12, 6.47) | 2 | 0.19 (0.07) | 2 (0.1, 6) | 623 (127, 5405)
Stroke | 1.36 (0.89, 2.08) | 4
Endometrial cancer increased | 2.13 (1.36, 3.32) | 3 | 0.75 (0.15)^¶^ | 4 (1, 10) | 236 (104, 771)
Cataracts^**^ | 1.25 (0.93, 1.67) | 3

* Per 1000 women-years. Estimated from a meta-analysis of rates from the placebo groups from the same trials included in the combined RR.

† Numbers of events reduced/increased are calculated by assuming 1000 women take tamoxifen for 5 years.

‡ Numbers needed to treat/harm are calculated by assuming each woman takes tamoxifen for 5 years.

§ RR for noninvasive breast cancer was significantly reduced in the NSABP P-1 trial (60 vs 93 events; RR=0.63; 0.45, 0.89).

|| Includes deep vein thrombosis and pulmonary embolus.

¶ Estimated from two trials that reported rates from the placebo groups (Fisher, 1998 and Cuzik, 2007).

** RR for cataracts was significantly increased in the NSABP P-1 trial (574 vs 507 events; RR=1.14; 1.01, 1.29).

Table 14 Estimates of number needed to treat or harm for raloxifene

Outcomes | RR (95% CI) | Trials | Placebo Rate (SE)^*^ | Number of Events Reduced/Increased (95% CI)^†^ | Number Needed to Treat/Harm (95% CI)^‡^
Breast cancer reduced
All breast cancer | 0.53 (0.34, 0.84) | 2 | 3.53 (0.69) | 8 (3, 14) | 121 (70, 340)
Invasive | 0.44 (0.27, 0.71) | 2 | 3.19 (0.59) | 9 (4, 14) | 112 (71, 236)
Estrogen receptor + | 0.33 (0.18, 0.61) | 2 | 2.45 (0.42) | 8 (4, 12) | 122 (81, 226)
Fractures reduced
Vertebral | 0.61 (0.54, 0.69) | 2 | 3.45 (0.35)^§^ | 7 (5, 9) | 149 (115, 201)
Nonvertebral | 0.97 (0.87, 1.09) | 2
Thromboembolic events increased\|\| | 1.60 (1.15, 2.23) | 2 | 2.34 (0.25) | 7 (2, 15) | 142 (66, 553)
Deep vein thrombosis | 1.91 (0.87, 4.23) | 2
Pulmonary embolus | 2.19 (0.97, 4.97) | 2
Stroke | 0.96 (0.67, 1.38) | 2
Endometrial cancer | 1.14 (0.65, 1.98) | 2
Cataracts | 0.93 (0.84, 1.04) | 2

* Per 1000 women-years. Estimated from a meta-analysis of rates from the placebo groups from the same trials included in the combined RR.

† Numbers of events reduced/increased are calculated by assuming 1000 women take raloxifene for 5 years.

‡ Numbers needed to treat/harm are calculated by assuming each woman takes raloxifene for 5 years.

§ Estimated from the placebo group of RUTH (Barrett-Connor, 2006).

|| includes deep vein thrombosis and pulmonary embolus.

Table 15 Estimates of number needed to treat or harm for tibolone from the LIFT trial

Outcomes | RR (95% CI) | Trials | Placebo Rate (SE)^*^ | Number of Events Reduced/Increased (95% CI)^†^ | Number Needed to Treat/Harm (95% CI)^‡^
Breast cancer reduced
All breast cancer
Invasive | 0.32 (0.13, 0.80) | 1 | 2.80 (0.66) | 10 (3, 17) | 105 (58, 302)
Estrogen receptor +
Fractures reduced
Vertebral | 0.55 (0.41, 0.74) | 1 | 19.60 (1.75) | 44 (25, 61) | 23 (16, 40)
Nonvertebral | 0.74 (0.58, 0.93) | 1 | 26.30 (2.04) | 34 (8, 56) | 29 (17, 104)
Thromboembolic events increased^§^ | 0.57 (0.19, 1.69) | 1
Deep vein thrombosis
Pulmonary embolus
Stroke increased | 2.19 (1.14, 4.23) | 1 | 1.90 (0.53) | 11 (1, 36) | 88 (25, 584)
Endometrial cancer
Cataracts

* Per 1000 women-years.

† Numbers of events reduced/increased are calculated by assuming 1000 women take tibolone for 5 years.

‡ Numbers needed to treat/harm are calculated by assuming each woman takes tibolone for 5 years.

§ Includes deep vein thrombosis and pulmonary embolus.

Table 16 Results of STAR

Outcomes | RR (95% CI) | Raloxifene Rate^*^ | Tamoxifen Rate^*^ | Number of Events Reduced/Increased (95% CI)^†^
Breast cancer reduced
Invasive | 1.02 (0.82, 1.28) | 4.41 | 4.30
Estrogen receptor + | 0.93 (0.72, 1.24) | 2.86 | 3.04
Noninvasive | 1.40 (0.98, 2.00) | 2.11 | 1.51
Fractures reduced
Vertebral | 0.98 (0.65, 1.60) | 1.35 | 1.39
Hip | 0.88 (0.48, 1.60) | 0.60 | 0.68
Wrist | 0.85 (0.46, 1.53) | 0.60 | 0.71
Thromboembolic events increased | 0.70 (0.54, 0.91) | 2.61 | 3.71 | 5.5 more with tamoxifen
Deep vein thrombosis | 0.74 (0.53, 1.03) | 1.69 | 2.29
Pulmonary embolus | 0.64 (0.41, 1.00) | 0.91 | 1.41
Stroke | 0.96 (0.64, 1.43) | 1.33 | 1.39
Endometrial cancer^‡^ | 0.62 (0.35, 1.08) | 1.25 | 2.00
Cataracts increased | 0.79 (0.68, 0.92) | 9.72 | 12.30 | 13 more with tamoxifen

* Per 1000 women-years.

† Numbers of events reduced/increased are calculated by assuming 1000 women take the medication for 5 years.

‡ Hyperplasia and hysterectomy rates are higher with tamoxifen among those not diagnosed with uterine cancer.

Although raloxifene and tamoxifen demonstrate these potential benefits, they are also capable of increasing risks for serious and potentially life threatening adverse events. Thromboembolic events are the most common serious complication of both medications, more so with tamoxifen than raloxifene (Table 16). Risk was increased by 60% to 90% in the placebo-controlled primary prevention trials that enrolled women with no prior history of thromboembolic events. Clinicians considering these medications will need to be vigilant in assessing prior history and risk factors for thromboembolic events in treatment candidates. Tamoxifen’s effects on endometrial cancer, endometrial hyperplasia, and hysterectomy are also significant. These problems could be avoided if its use were limited to women with prior hysterectomies. However, since tamoxifen is the only medication approved for use in premenopausal women with or without hysterectomies, close monitoring of adverse uterine effects would be required for some users. Raloxifene and tamoxifen are also capable of causing adverse effects that could impact quality of life such as hot flashes, vaginal symptoms, and musculoskeletal symptoms.

Women need to understand their own risks of death as a result of breast cancer and the unwanted effects of risk reducing medications before using them. The decision to use these medications would ideally occur after an accurate assessment of a woman’s individual risks for breast cancer and adverse effects. Those at highest risk for breast cancer would be most likely to benefit. However, methods to identify candidates for risk reducing medications have low discriminatory accuracy. Average risk women age 60 and older meet the Gail model eligibility threshold of 1.66% 5-year risk for breast cancer. Women and clinicians have few clinical tools to work with when making decisions about using these medications.

This review is limited by potential biases. These include publication bias and biases resulting from our selection criteria, such as using English-only publications. Trials may not have been truly blinded because side effects of active medications may have lead to differential ascertainment of outcomes. Active surveillance ended with completion of therapy in most trials and important long-term outcomes may have been underreported. For some tamoxifen trials, participants randomized to placebo switched to active medications following closure of the trial, compromising long-term tracking of outcomes. All efficacy trials were powered to detect statistical differences in breast cancer incidence not adverse outcomes. Risks for some adverse outcomes may be underestimated because of lack of statistical power. Underestimation of adverse outcomes may also relate to inadequate ascertainment. For example, rates of cataracts and cataract surgery in the NSABP P-1 trial are substantially higher than rates in the other trials most likely because the trial enlisted a more aggressive detection method.

These issues highlight the limitations of the comparative effectiveness review as well as limitations of research in this area. Although many factors influence the decision to use medications to reduce risk of breast cancer, they are outside the scope of this comparative effectiveness review. However, these need to be considered when applying the results of this review to health policy, insurance coverage, or patient decisions. Research is lacking in many essential areas including optimal doses, duration of use, persistence of effects after treatment, and outcomes in population subgroups. Data are lacking for nonwhite women, premenopausal women, and women with co-morbidities or taking additional medications for other indications.