# References

1 American Cancer Society. Cancer Facts and Figures 2007 [updated 2007]. Available at: http://www.cancer.org/docroot/stt/stt_0.asp.
2 American Cancer Society. 2008. Statistics [updated 2008]. Available at: http://www.cancer.org/docroot/stt/stt_0.asp.
3 Ries LAG, Melbert D, Krapcho M, et al. SEER Cancer Statistics Review, 1975–2004–2007 [updated 2007]. Available at: http://seer.cancer.gov/csr/1975_2004/.
4 Simpson JF, Wilkinson EJ. Malignant Neoplasia of the Breast: Infiltrating Carcinomas. Bland KI, Copeland EM, editors. Breast: Comprehensive Management of Benign and Malignant Disorders. 3rd Ed. St Louis. Saunders. 2004.
5 Schwartz GF. Biology and Management of Lobular Carcinoma In Situ of the Breast. Bland KI, Copeland EM, editors. The Breast: Comprehensive Management of Benign and Malignant Disorders. 3rd Ed. St Louis. Saunders. 2004.
6 Nelson HD, Huffman LH, Fu R, et al. Genetic risk assessment and BRCA mutation testing for breast and ovarian cancer susceptibility: Systematic evidence review for the U.S. Preventive Services Task Force. Ann Intern Med. 2005;143(5):362-79. [pmid: 16144895].
7 Martin AM, Weber BL. Genetic and hormonal risk factors in breast cancer. J Natl Cancer Inst. 2000;92:1126-35. [pmid: 10904085].
8 Cummings SR, Tice JA, Bauer S, et al. Prevention of breast cancer in postmenopausal women: approaches to estimating and reducing risk. J Natl Cancer Inst. 2009;101(6):384-98. [pmid: 19276457].
9 Boyd NF, Guo H, Martin LJ, et al. Mammographic density and the risk and detection of breast cancer. N Engl J Med. 2007;356(3):227-36. [pmid: 17229950].
10 Cummings SR, Ettinger B, Delmas PD, et al. The effects of tibolone in older postmenopausal women. N Engl J Med. 2008;359(7):697-708. [pmid: 18703472].
11 Medicines and Healthcare Products Regulatory Agency. UK Public Assessment Report Tibolone (Livial): benefit-risk evaluation. Available at: http://www.mhra.gov.uk/home/groups/plp/documents/websiteresources/con2032229.pdf.
12 Vogel VG, Costantino JP, Wickerham DL, et al. Effects of tamoxifen vs raloxifene on the risk of developing invasive breast cancer and other disease outcomes: the NSABP Study of Tamoxifen and Raloxifene (STAR) P-2 trial. JAMA. 2006;295(23):2727-41. [pmid: 16754727].
13 Harris RP, Helfand M, Woolf SH, et al. Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. 2001;20(3 Suppl):21-35. [pmid: 11306229].
14 Methods Reference Guide for Effectiveness and Comparative Effectiveness Reviews, Version 1.0. Rockville, MD. Draft posted Oct. 2007. Available at: http://effectivehealthcare.ahrq.gov/repFiles/2007_10DraftMethodsGuide.pdf.
15 Lohr KN, Helfand M, Owens DK, et al. Grading the strength of a body of evidence. J Clin Epidemiol. [in press].
16 Higgins JP, Thompson SG. Quantifying heterogeneity in a meta-analysis. Stat Med. 2002;21(11):1539-58. [pmid: 12111919].
17 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. 1986;7(3):177-88. [pmid: 3802833].
18 Land SR, Wickerham DL, Costantino JP, et al. Patient-reported symptoms and quality of life during treatment with tamoxifen or raloxifene for breast cancer prevention: the NSABP Study of Tamoxifen and Raloxifene (STAR) P-2 trial [erratum appears in JAMA 2007;298(9):973]. JAMA. 2006;295(23):2742-51. [pmid: 16754728].
19 Cuzick J, Forbes J, Edwards R, et al. First results from the International Breast Cancer Intervention Study (IBIS-I): a randomised prevention trial. Lancet. 2002;360(9336):817-24. [pmid: 12243915].
20 Cuzick J, Forbes JF, Sestak I, et al. Long-term results of tamoxifen prophylaxis for breast cancer—96-month follow-up of the randomized IBIS-I trial. J Natl Cancer Inst. 2007;99(4):272-82. [pmid: 17312304].
21 Day R, Ganz PA, Costantino JP. Tamoxifen and depression: more evidence from the National Surgical Adjuvant Breast and Bowel Project’s Breast Cancer Prevention (P-1) Randomized Study. J Natl Cancer Inst. 2001;93(21):1615-23. [pmid: 11698565].
22 Day R. Quality of life and tamoxifen in a breast cancer prevention trial: a summary of findings from the NSABP P-1 study. National Surgical Adjuvant Breast and Bowel Project. Ann N Y Acad Sci. 2001;949:143-50. [pmid: 11795346].
23 Fisher B, Costantino JP, Wickerham DL, et al. Tamoxifen for the prevention of breast cancer: current status of the National Surgical Adjuvant Breast and Bowel Project P-1 study. J Natl Cancer Inst. 2005;97(22):1652-62. [pmid: 16288118].
24 Fisher B, Costantino JP, Wickerham DL, et al. Tamoxifen for prevention of breast cancer: report of the National Surgical Adjuvant Breast and Bowel Project P-1 Study. J Natl Cancer Inst. 1998;90(18):1371-88. [pmid: 9747868].
25 Powles T, Eeles R, Ashley S, et al. Interim analysis of the incidence of breast cancer in the Royal Marsden Hospital tamoxifen randomised chemoprevention trial. Lancet. 1998;352(9122):98-101. [pmid: 9672274].
26 Powles TJ, Ashley S, Tidy A, et al. Twenty-year follow-up of the Royal Marsden randomized, double-blinded tamoxifen breast cancer prevention trial. J Natl Cancer Inst. 2007;99(4):283-90. [pmid: 17312305].
27 Decensi A, Maisonneuve P, Rotmensz N, et al. Effect of tamoxifen on venous thromboembolic events in a breast cancer prevention trial. Circulation. 2005;111(5):650-6. [pmid: 15699284].
28 Veronesi A, Pizzichetta MA, Ferlante MA, et al. Tamoxifen as adjuvant after surgery for breast cancer and tamoxifen or placebo as chemoprevention in healthy women: different compliance with treatment. Tumori. 1998;84(3):372-5. [pmid: 9678620].
29 Veronesi U, Maisonneuve P, Rotmensz N, et al. Tamoxifen for the prevention of breast cancer: late results of the Italian Randomized Tamoxifen Prevention Trial among women with hysterectomy [see comment]. J Natl Cancer Inst. 2007;99(9):727-37. [pmid: 17470740].
30 Veronesi U, Maisonneuve P, Rotmensz N, et al. Italian randomized trial among women with hysterectomy: tamoxifen and hormone-dependent breast cancer in high-risk women. J Natl Cancer Inst. 2003;95(2):160-5. [pmid: 12529349].
31 Barrett-Connor E, Cauley JA, Kulkarni PM, et al. Risk-benefit profile for raloxifene: 4-year data From the Multiple Outcomes of Raloxifene Evaluation (MORE) randomized trial. J Bone Miner Res. 2004;19(8):1270-5. [pmid: 15231013].
32 Barrett-Connor E, Grady D, Sashegyi A, et al. Raloxifene and cardiovascular events in osteoporotic postmenopausal women: four-year results from the MORE (Multiple Outcomes of Raloxifene Evaluation) randomized trial. JAMA. 2002;287(7):847-57. [pmid: 11851576].
33 Cauley JA, Norton L, Lippman ME, et al. Continued breast cancer risk reduction in postmenopausal women treated with raloxifene: 4-year results from the MORE trial. Breast Cancer Res Treat. 2001;65(2):125-34. [pmid: 11261828].
34 Cummings SR, Eckert S, Krueger KA, et al. The effect of raloxifene on risk of breast cancer in postmenopausal women: results from the MORE randomized trial. Multiple Outcomes of Raloxifene Evaluation. JAMA. 1999;281(23):2189-97. [pmid: 10376571].
35 Delmas PD, Ensrud KE, Adachi JD, et al. Efficacy of raloxifene on vertebral fracture risk reduction in postmenopausal women with osteoporosis: four-year results from a randomized clinical trial. J Clin Endocrinol Metab. 2002;87(8):3609-17. [pmid: 12161484].
36 Delmas PD, Genant HK, Crans GG, et al. Severity of prevalent vertebral fractures and the risk of subsequent vertebral and nonvertebral fractures: results from the MORE trial. Bone. 2003;33(4):522-32. [pmid: 14555255].
37 Duvernoy CS, Kulkarni PM, Dowsett SA, et al. Vascular events in the Multiple Outcomes of Raloxifene Evaluation (MORE) trial: incidence, patient characteristics, and effect of raloxifene. Menopause. 2005;12(4):444-52. [pmid: 16037760].
38 Ettinger B, Black DM, Mitlak BH, et al. Reduction of vertebral fracture risk in postmenopausal women with osteoporosis treated with raloxifene: results from a 3-year randomized clinical trial. JAMA. 1999;282(7):637-45. [pmid: 10517716].
39 Grady D, Ettinger B, Moscarelli E, et al. Safety and adverse effects associated with raloxifene: multiple outcomes of raloxifene evaluation. Obstet Gynecol. 2004;104(4):837-44. [pmid: 15458908].
40 Johnell O, Cauley JA, Kulkarni PM, et al. Raloxifene reduces risk of vertebral fractures and breast cancer in postmenopausal women regardless of prior hormone therapy. J Fam Pract. 2004;53(10):789-96. [pmid: 15469774].
41 Keech CA, Sashegyi A, Barrett-Connor E. Year-by-year analysis of cardiovascular events in the Multiple Outcomes of Raloxifene Evaluation (MORE) trial. Curr Med Res Opin. 2005;21(1):135-40. [pmid: 15881485].
42 Lippman ME, Cummings SR, Disch DP, et al. Effect of raloxifene on the incidence of invasive breast cancer in postmenopausal women with osteoporosis categorized by breast cancer risk [see comment]. Clin Cancer Res. 2006;12(17):5242-7. [pmid: 16951244].
43 Martino S, Disch D, Dowsett SA, et al. Safety assessment of raloxifene over eight years in a clinical trial setting. Curr Med Res Opin. 2005;21(9):1441-52. [pmid: 16197663].
44 Silverman SL, Delmas PD, Kulkarni PM, et al. Comparison of fracture, cardiovascular event, and breast cancer rates at 3 years in postmenopausal women with osteoporosis. J Am Geriatr Soc. 2004;52(9):1543-8. [pmid: 15341559].
45 Siris ES, Harris ST, Eastell R, et al. Skeletal effects of raloxifene after 8 years: results from the continuing outcomes relevant to Evista (CORE) study. J Bone Miner Res. 2005;20(9):1514-24. [pmid: 16059623].
46 Barrett-Connor E, Mosca L, Collins P, et al. Effects of raloxifene on cardiovascular events and breast cancer in postmenopausal women. N Engl J Med. 2006;355(2):125-37. [pmid: 16837676].
47 Grady D, Cauley JA, Geiger MJ, et al. Reduced incidence of invasive breast cancer with raloxifene among women at increased coronary risk. J Natl Cancer Inst. 2008;100(12):854-61. [pmid: 18544744].
48 Gail MH. The estimation and use of absolute risk for weighing the risks and benefits of selective estrogen receptor modulators for preventing breast cancer. Ann N Y Acad Sci. 2001;949:286-91. [pmid: 11795364].
49 Gail MH, Brinton LA, Byar DP, et al. Projecting individualized probabilities of developing breast cancer for white females who are being examined annually. J Natl Cancer Inst. 1989;81(24):1879-86. [pmid: 2593165].
50 Veronesi U, Maisonneuve P, Costa A, et al. Prevention of breast cancer with tamoxifen: preliminary findings from the Italian randomised trial among hysterectomised women. Italian Tamoxifen Prevention Study. Lancet. 1998;352(9122):93-7. [pmid: 9672273].
51 Martino S, Cauley JA, Barrett-Connor E, et al. Continuing outcomes relevant to Evista: breast cancer incidence in postmenopausal osteoporotic women in a randomized trial of raloxifene. J Natl Cancer Inst. 2004;96(23):1751-61. [pmid: 15572757].
52 Vogel VG. Recent results from clinical trials using SERMs to reduce the risk of breast cancer. Ann N Y Acad Sci. 2006;1089:127-42. [pmid: 17261762].
53 Martino S, Costantino J, McNabb M, et al. The role of selective estrogen receptor modulators in the prevention of breast cancer: comparison of the clinical trials. Oncologist. 2004;9(2):116-25. [pmid: 15047916].
54 Ensrud K, Genazzani AR, Geiger MJ, et al. Effect of raloxifene on cardiovascular adverse events in postmenopausal women with osteoporosis. Am J Cardiol. 2006;97(4):520-7. [pmid: 16461049].
55 Brisson J, Brisson B, Cote G, et al. Tamoxifen and mammographic breast densities. Cancer Epidemiol Biomarkers Prev. 2000;9(9):911-5. [pmid: 11008908].
56 Bruno S, Maisonneuve P, Castellana P, et al. Incidence and risk factors for non-alcoholic steatohepatitis: prospective study of 5408 women enrolled in Italian tamoxifen chemoprevention trial. BMJ. 2005;330(7497):932. [pmid: 15746106].
57 Chalas E, Costantino JP, Wickerham DL, et al. Benign gynecologic conditions among participants in the Breast Cancer Prevention Trial. Am J Obstet Gynecol. 2005;192(4):1230-7. [pmid: 15846210].
58 Cuzick J, Warwick J, Pinney E, et al. Tamoxifen and breast density in women at increased risk of breast cancer. J Natl Cancer Inst. 2004;96(8):621-8. [pmid: 15100340].
59 Day R, Ganz PA, Costantino JP, et al. Health-related quality of life and tamoxifen in breast cancer prevention: a report from the National Surgical Adjuvant Breast and Bowel Project P-1 Study. J Clin Oncol. 1999;17(9):2659-69. [pmid: 10561339].
60 Powles TJ, Hardy JR, Ashley SE, et al. Chemoprevention of breast cancer. Breast Cancer Res Treat. 1989;14(1):23-31. [pmid: 2690969].
61 Powles TJ, Hardy JR, Ashley SE, et al. A pilot trial to evaluate the acute toxicity and feasibility of tamoxifen for prevention of breast cancer. Br J Cancer. 1989;60(1):126-31. [pmid: 2679843].
62 Powles TJ, Jones AL, Ashley SE, et al. The Royal Marsden Hospital pilot tamoxifen chemoprevention trial. Breast Cancer Res Treat. 1994;31(1):73-82. [pmid: 7981459].
63 Powles TJ, Tillyer CR, Jones AL, et al. Prevention of breast cancer with tamoxifen—an update on the Royal Marsden Hospital pilot programme. Eur J Cancer. 1990;26(6):680-4. [pmid: 2144154].
64 Reis SE, Costantino JP, Wickerham DL, et al. Cardiovascular effects of tamoxifen in women with and without heart disease: breast cancer prevention trial. J Natl Cancer Inst. 2001;93(1):16-21. [pmid: 11136837].
65 Tan-Chiu E, Wang J, Costantino JP, et al. Effects of tamoxifen on benign breast disease in women at high risk for breast cancer. J Natl Cancer Inst. 2003;95(4):302-7. [pmid: 12591986].
66 Veronesi U, Costa A. Prevention of breast cancer with tamoxifen: The Italian study in hysterectomized women. Breast. 1995;4(4):267-72.
67 Veronesi U, Maisonneuve P, Sacchini V, et al. Tamoxifen for breast cancer among hysterectomised women. Lancet. 2002;359(9312):1122-4. [pmid: 11943263].
68 Vogel VG. Follow-up of the breast cancer prevention trial and the future of breast cancer prevention efforts. Clin Cancer Res. 2001;7(12 Suppl):4413s-8s. [pmid: 11916233].
69 Vogel VG, Costantino JP, Wickerham DL, et al. National surgical adjuvant breast and bowel project update: prevention trials and endocrine therapy of ductal carcinoma in situ. Clin Cancer Res. 2003;9(1 Pt 2):495S-501S. [pmid: 12538506].
70 Vogel VG, Costantino JP, Wickerham DL, et al. The study of Tamoxifen and Raloxifene: preliminary enrollment data from a randomized breast cancer risk reduction trial. Breast Cancer Res Treat. 2001;69(3):225.
71 Vogel VG, Costantino JP, Wickerham DL, et al. The study of tamoxifen and raloxifene: preliminary enrollment data from a randomized breast cancer risk reduction trial. Clin Breast Cancer. 2002;3(2):153-9. [pmid: 12123540].
72 Ensrud KE, Stock JL, Barrett-Connor E, et al. Effects of raloxifene on fracture risk in postmenopausal women: the Raloxifene Use for the Heart Trial. J Bone Miner Res. 2008;23(1):112-20. [pmid: 17892376].
73 Cohen FJ, Watts S, Shah A, et al. Uterine effects of 3-year raloxifene therapy in postmenopausal women younger than age 60. Obstet Gynecol. 2000;95(1):104-10. [pmid: 10636511].
74 Delmas PD, Bjarnason NH, Mitlak BH, et al. Effects of raloxifene on bone mineral density, serum cholesterol concentrations, and uterine endometrium in postmenopausal women. N Engl J Med. 1997;337(23):1641-7. [pmid: 9385122].
75 Freedman M, San Martin J, O’Gorman J, et al. Digitized mammography: a clinical trial of postmenopausal women randomly assigned to receive raloxifene, estrogen, or placebo. J Natl Cancer Inst. 2001;93(1):51-6. [pmid: 11136842].
76 Goldstein SR, Johnson S, Watts NB, et al. Incidence of urinary incontinence in postmenopausal women treated with raloxifene or estrogen. Menopause. 2005;12(2):160-4. [pmid: 15772563].
77 Johnston CC Jr, Bjarnason NH, Cohen FJ, et al. Long-term effects of raloxifene on bone mineral density, bone turnover, and serum lipid levels in early postmenopausal women: three-year data from 2 double-blind, randomized, placebo-controlled trials. Arch Intern Med. 2000;160(22):3444-50. [pmid: 11112238].
78 Jolly EE, Bjarnason NH, Neven P, et al. Prevention of osteoporosis and uterine effects in postmenopausal women taking raloxifene for 5 years. Menopause. 2003;10(4):337-44. [pmid: 12851517].
79 Lufkin EG, Whitaker MD, Nickelsen T, et al. Treatment of established postmenopausal osteoporosis with raloxifene: a randomized trial. J Bone Miner Res. 1998;13(11):1747-54. [pmid: 9797484].
80 McClung MR, Siris E, Cummings S, et al. Prevention of bone loss in postmenopausal women treated with lasofoxifene compared with raloxifene. Menopause. 2006;13(3):377-86. [pmid: 16735934].
81 Meunier PJ, Vignot E, Garnero P, et al. Treatment of postmenopausal women with osteoporosis or low bone density with raloxifene. Raloxifene Study Group [erratum appears in Osteoporos Int 1999;10(5):433]. Osteoporos Int. 1999;10(4):330-6. [pmid: 10692984].
82 Morii H, Ohashi Y, Taketani Y, et al. Effect of raloxifene on bone mineral density and biochemical markers of bone turnover in Japanese postmenopausal women with osteoporosis: results from a randomized placebo-controlled trial. Osteoporos Int. 2003;14(10):793-800. [pmid: 12955333].
83 Nickelsen T, Lufkin EG, Riggs BL, et al. Raloxifene hydrochloride, a selective estrogen receptor modulator: safety assessment of effects on cognitive function and mood in postmenopausal women. Psychoneuroendocrinology. 1999;24(1):115-28. [pmid: 10098223].
84 Palacios S, Farias ML, Luebbert H, et al. Raloxifene is not associated with biologically relevant changes in hot flushes in postmenopausal women for whom therapy is appropriate. Am J Obstet Gynecol. 2004;191(1):121-31. [pmid: 15295352].
85 Walsh BW, Kuller LH, Wild RA, et al. Effects of raloxifene on serum lipids and coagulation factors in healthy postmenopausal women. JAMA. 1998;279(18):1445-51. [pmid: 9600478].
86 Christodoulakos GE, Botsis DS, Lambrinoudaki IV, et al. A 5-year study on the effect of hormone therapy, tibolone and raloxifene on vaginal bleeding and endometrial thickness. Maturitas. 2006;53(4):413-23. [pmid: 16140483].
87 Ettinger B, Kenemans P, Johnson SR, et al. Endometrial effects of tibolone in elderly, osteoporotic women. Obstet Gynecol. 2008;112(3):653-9. [pmid: 18757665].
88 Bots ML, Evans GW, Riley W, et al. The Osteoporosis Prevention and Arterial effects of tiboLone (OPAL) study: design and baseline characteristics. Control Clin Trials. 2003;24(6):752-75. [pmid: 14662281].
89 Bots ML, Evans G, Riley W, et al. The osteoporosis prevention and arterial effects of tibolone (OPAL) study: study design and baseline characteristics. Control Clin Trials. 2001;22.
90 Langer RD, Landgren BM, Rymer J, et al. Effects of tibolone and continuous combined conjugated equine estrogen/medroxyprogesterone acetate on the endometrium and vaginal bleeding: results of the OPAL study. Am J Obstet Gynecol. 2006;195(5):1320-7. [pmid: 16875644].
91 Landgren MB, Bennink HJ, Helmond FA, et al. Dose-response analysis of effects of tibolone on climacteric symptoms. BJOG. 2002;109(10):1109-14. [pmid: 12387462].
92 Gallagher JC, Baylink DJ, Freeman R, et al. Prevention of bone loss with tibolone in postmenopausal women: results of two randomized, double-blind, placebo-controlled, dose-finding studies. J Clin Endocrinol Metab. 2001;86(10):4717-26. [pmid: 11600531].
93 Swanson SG, Drosman S, Helmond FA, et al. Tibolone for the treatment of moderate to severe vasomotor symptoms and genital atrophy in postmenopausal women: a multicenter, randomized, double-blind, placebo-controlled study. Menopause. 2006;13(6):917-25. [pmid: 17006377].
94 Hudita D, Posea C, Ceausu I, et al. Efficacy and safety of oral tibolone 1.25 or 2.5 mg/day vs. placebo in postmenopausal women. Eur Rev Med Pharmacol Sci. 2003;7(5):117-25. [pmid: 15214586].
95 Lundstrom E, Christow A, Kersemaekers W, et al. Effects of tibolone and continuous combined hormone replacement therapy on mammographic breast density. Am J Obstet Gynecol. 2002;186(4):717-22. [pmid: 11967497].
96 Onalan G, Onalan R, Selam B, et al. Mood scores in relation to hormone replacement therapies during menopause: a prospective randomized trial. Tohoku J Exp Med. 2005;207(3):223-31. [pmid: 16210834].
97 Beral V, Bull D, Reeves G, et al. Endometrial cancer and hormone-replacement therapy in the Million Women Study. Lancet. 2005;365(9470):1543-51. [pmid: 15866308].
98 Beral V. Million Women Study Collaborators. Breast cancer and hormone-replacement therapy in the Million Women Study [erratum appears in Lancet. 2003 Oct 4;362(9390):1160]. Lancet. 2003;362(9382):419-27. [pmid: 12927427].
99 Archer DF, Hendrix S, Gallagher JC, et al. Endometrial effects of tibolone. J Clin Endocrinol Metab. 2007;92(3):911-8. [pmid: 17192288].
100 Kenemans P, Bundred NJ, Foidart JM, et al. Safety and efficacy of tibolone in breast-cancer patients with vasomotor symptoms: a double-blind, randomised, non-inferiority trial. Lancet Oncol. 2009;10(2):135-46. [pmid: 19167925].
101 Beral V, Green J, Reeves G, et al. Fatal stroke in postmenopausal users of tibolone and hormonal therapy. 2006. Available at: http://www.bmj.com/cgi/eletters/332/7542/667#143473.
102 de Vries CS, Bromley SE, Thomas H, et al. Tibolone and endometrial cancer: a cohort and nested case-control study in the UK. Drug Saf. 2005;28(3):241-9. [pmid: 15733028].
103 Opatrny L, Dell’Aniello S, Assouline S, et al. Hormone replacement therapy use and variations in the risk of breast cancer. BJOG. 2008;115(2):169-75. [pmid: 18081598].
104 Stahlberg C, Pedersen AT, Lynge E, et al. Increased risk of breast cancer following different regimens of hormone replacement therapy frequently used in Europe. Int J Cancer. 2004;109(5):721-7. [pmid: 14999781].
105 Velthuis-Te Wierik EJM, Hendricks PT, Martinez C. Preferential prescribing of tibolone and combined estrogen plus progestogen therapy in postmenopausal women. Menopause. 2007;14(3 Pt 1):518-27. [pmid: 17224856].
106 Abramson N, Costantino JP, Garber JE, et al. Effect of Factor V Leiden and prothrombin G20210-->A mutations on thromboembolic risk in the national surgical adjuvant breast and bowel project breast cancer prevention trial. J Natl Cancer Inst. 2006;98(13):904-10. [pmid: 16818854].
107 Armstrong K, Quistberg DA, Micco E, et al. Prescription of tamoxifen for breast cancer prevention by primary care physicians. Arch Intern Med. 2006;166(20):2260-5. [pmid: 17101945].
108 Bastian LA, Lipkus IM, Kuchibhatla MN, et al. Women’s interest in chemoprevention for breast cancer. Arch Intern Med. 2001;161(13):1639-44. [pmid: 11434796].
109 Berning B, van Kuijk C, Bennink HJ, et al. Absent correlation between vaginal bleeding and oestradiol levels or endometrial morphology during tibolone use in early postmenopausal women. Maturitas. 2000;35(1):81-8. [pmid: 10802404].
110 Bober SL, Hoke LA, Duda RB, et al. Decision-making about tamoxifen in women at high risk for breast cancer: clinical and psychological factors. J Clin Oncol. 2004;22(24):4951-7. [pmid: 15598980].
111 McKay A, Martin W, Latosinsky S. How should we inform women at higher risk of breast cancer about tamoxifen? An approach with a decision guide. Breast Cancer Res Treat. 2005;94(2):153-9. [pmid: 16261414].
112 Melnikow J, Paterniti D, Azari R, et al. Preferences of Women Evaluating Risks of Tamoxifen (POWER) study of preferences for tamoxifen for breast cancer risk reduction. Cancer. 2005;103(10):1996-2005. [pmid: 15825209].
113 Port ER, Montgomery LL, Heerdt AS, et al. Patient reluctance toward tamoxifen use for breast cancer primary prevention. Ann Surg Oncol. 2001;8(7):580-5. [pmid: 11508619].
114 Taylor R, Taguchi K. Tamoxifen for breast cancer chemoprevention: low uptake by high-risk women after evaluation of a breast lump. Ann Fam Med. 2005;3(3):242-7. [pmid: 15928228].
115 Yeomans Kinney A, Vernon SW, Shui W, et al. Validation of a model predicting enrollment status in a chemoprevention trial for breast cancer. Cancer Epidemiol Biomarkers Prev. 1998;7(7):591-5. [pmid: 9681527].
116 Cramer JA, Roy A, Burrell A, et al. Medication compliance and persistence: terminology and definitions. Value Health. 2008;11(1):44-7. [pmid: 18237359].
117 Blenkinsopp B, Britten, Feely, et al. Achieving shared goals in medicine taking A working party report. London. Royal Pharmaceutical Society of Great Britain and Merck Sharp and Dohme. 1997.
118 Boyle P, Mezzetti M, La Vecchia C, et al. Contribution of three components to individual cancer risk predicting breast cancer risk in Italy. Eur J Cancer Prev. 2004;13(3):183-91. [pmid: 15167217].
119 Colditz GA, Rosner B. Cumulative risk of breast cancer to age 70 years according to risk factor status: data from the Nurses’ Health Study. Am J Epidemiol. 2000;152(10):950-64. [pmid: 11092437].
120 Colditz GA, Rosner BA, Chen WY, et al. Risk factors for breast cancer according to estrogen and progesterone receptor status. J Natl Cancer Inst. 2004;96(3):218-28. [pmid: 14759989].
121 Decarli A, Calza S, Masala G, et al. Gail model for prediction of absolute risk of invasive breast cancer: independent evaluation in the Florence-European Prospective Investigation Into Cancer and Nutrition cohort. J Natl Cancer Inst. 2006;98(23):1686-93. [pmid: 17148770].
122 Rockhill B, Spiegelman D, Byrne C, et al. Validation of the Gail et al. model of breast cancer risk prediction and implications for chemoprevention. J Natl Cancer Inst. 2001;93(5):358-66. [pmid: 11238697].
123 Tyrer J, Duffy SW, Cuzick J, et al. A breast cancer prediction model incorporating familial and personal risk factors [erratum appears in Stat Med 2005;24(1):156]. Stat Med. 2004;23(7):1111-30. [pmid: 15057881].
124 Costantino JP, Gail MH, Pee D, et al. Validation studies for models projecting the risk of invasive and total breast cancer incidence. J Natl Cancer Inst. 1999;91(18):1541-8. [pmid: 10491430].
125 Chlebowski RT, Anderson GL, Lane DS, et al. Predicting risk of breast cancer in postmenopausal women by hormone receptor status [see comment]. J Natl Cancer Inst. 2007;99(22):1695-705. [pmid: 18000216].
126 Gail MH, Costantino JP, Pee D, et al. Projecting individualized absolute invasive breast cancer risk in African American women [erratum appears in J Natl Cancer Inst 2008;100(5):373]. J Natl Cancer Inst. 2007;99(23):1782-92. [pmid: 18042936].
127 Adams-Campbell LL, Makambi KH, Palmer JR, et al. Diagnostic accuracy of the Gail model in the Black Women’s Health Study. Breast J. 2007;13(4):332-6. [pmid: 17593036].
128 Chen J, Pee D, Ayyagari R, et al. Projecting absolute invasive breast cancer risk in white women with a model that includes mammographic density. J Natl Cancer Inst. 2006;98(17):1215-26. [pmid: 16954474].
129 Barlow WE, White E, Ballard-Barbash R, et al. Prospective breast cancer risk prediction model for women undergoing screening mammography. J Natl Cancer Inst. 2006;98(17):1204-14. [pmid: 16954473].
130 Tice JA, Cummings SR, Smith-Bindman R, et al. Using clinical factors and mammographic breast density to estimate breast cancer risk: development and validation of a new predictive model. Ann Intern Med. 2008;148(5):337-47. [pmid: 18316752].
131 Rockhill B, Byrne C, Rosner B, et al. Breast cancer risk prediction with a log-incidence model: evaluation of accuracy. J Clin Epidemiol. 2003;56(9):856-61. [pmid: 14505770].
132 Amir E, Evans DG, Shenton A, et al. Evaluation of breast cancer risk assessment packages in the family history evaluation and screening programme. J Med Genet. 2003;40(11):807-14. [pmid: 14627668].
133 Hosmer D, Lemeshow S. Applied Logistic Regression. New York. John Wiley & Sons. 2000.
134 Nelson H, Haney B, Chou R, et al. Screening for Osteoporosis: Systematic Review to Update the 2002. US Preventive Services Task Force Recommendation (Prepared by the Oregon Health & Science University Evidence-based Practice Center under Contract No 290-97-0018). Rockville, MD. Agency for Healthcare Research and Quality. in press.
135 Kenemans P, Kubista E, Foidart JM, et al. Safety of tibolone in the treatment of vasomotor symptoms in breast cancer patients—design and baseline data ‘LIBERATE’ trial [erratum appears in Breast 2008;17(2):214–5 Note: Egberts J [added]; van Os S [added]; Planellas J [added]]. Breast. 2007;16(Suppl 2):S182-9. [pmid: 17983942].
136 Chlebowski RT, Kuller LH, Prentice RL, et al. Breast cancer after use of estrogen plus progestin in postmenopausal women. N Engl J Med. 2009;360(6):573-87. [pmid: 19196674].
137 Kurz-Milcke E, Gigerenzer G, Martignon L. Transparency in risk communication: graphical and analog tools. Ann N Y Acad Sci. 2008;1128:18-28. [pmid: 18469211].
138 Wolff T, Miller T, Ko S. Aspirin for the primary prevention of cardivascular events: An update of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. 2009;150(6):405-10. [pmid: 19293073].
139 U.S. Preventive Services Task Force. Aspirin for the prevention of cardiovascular disease: recommendation statement. Ann Intern Med. 2009;150(6):396-404. [pmid: 19293072].
140 Gierach GL, Lacey JV Jr, Schatzkin A, et al. Nonsteroidal anti-inflammatory drugs and breast cancer risk in the National Institutes of Health-AARP Diet and Health Study. Breast Cancer Res. 2008;10(2):R38. [pmid: 18447943].
141 Shen Y, Costantino JP, Qin J. Tamoxifen chemoprevention treatment and time to first diagnosis of estrogen receptor-negative breast cancer. J Natl Cancer Inst. 2008;100(20):1448-53. [pmid: 18840821].
142 U.S. Preventive Services Task Force. Chemoprevention of breast cancer: recommendations and rationale. Ann Intern Med. 2002;137(1):56-8. [pmid: 12093249].
143 RXList.com. Top 200 Drugs by Prescriptions Dispensed. Available at: http://www.rxlist.com/script/main/hp.asp. Accessed March 30, 2009.