# Acknowledgments

The authors thank Andrew Hamilton, M.L.S, M.S., and Rose Campbell, M.L.I.S., M.S., for literature searches, and Jennifer Nguyen for administrative assistance at the Oregon Evidence-based Practice Center at the Oregon Health & Science University. We also acknowledge the contributions of AHRQ Officers Shilpa Amin, M.D., M.B.Sc., and Kenneth Lin, M.D., and members of the Technical Expert Panel and Peer Reviewers listed below.

## Technical Expert Panel

Katrina Armstrong, M.D., University of Pennsylvania, Philadelphia, Pennsylvania

Elizabeth Barrett-Connor, M.D., University of California at San Diego, San Diego, California

William Gradishar, M.D., Northwestern University, Evanston, Illinois

Linda Kinsinger, M.D., Veterans Health Administration, Durham, North Carolina

Diana Petitti, M.D., University of Arizona, Phoenix, Arizona

George Sawaya, M.D., University of California San Francisco, San Francisco, California

Victor Vogel, M.D., Magee Women’s Hospital, Pittsburgh, Pennsylvania

## Peer Reviewers

Nananda Col, M.D., M.P.P., M.P.H., FACP

Brian E. Henderson, M.D.

Linda S. Kinsinger, M.D.

Joy Simha

## AHRQ Contacts

- Beth A. Collins-Sharp, Ph.D., R.N.
- Director
- Evidence-based Practice Center Program
- Agency for Healthcare Research and Quality
- Rockville, MD

- Shilpa H. Amin, M.D., M.B.Sc, FAAFP
- Task Order Officer
- Evidence-based Practice Center Program
- Agency for Healthcare Research and Quality
- Rockville, MD

- Kenneth W. Lin, M.D.
- Medical Officer
- U.S. Preventive Services Task Force Program
- Center for Primary Care, Prevention, and Clinical Partnerships
- Agency for Healthcare Research and Quality
- Rockville, MD