# Appendixes

Appendix A Searches

Appendix B List of Excluded Studies

Appendix C Quality and Strength of Evidence Criteria and Rating

Appendix D Evidence Tables