# Evidence Tables

## Appendix D-1. Evidence Table for Studies of Harms

Study^*^ | Study Design | N (drug/placebo or nonuser) | Participants | Dose (mg);Duration | Harms Outcomes
Tamoxifen vs Raloxifene
Study of Tamoxifen and Raloxifene (STAR)12,18 | RCT | 9872 tamoxifen/9875 raloxifene | Postmenopausal women with a 5-year predicted breast cancer risk of ≥1.66% based on the modified Gail model.^†^ Age ≥35 years, mean age 58.5 years; 94% white; 52% post hysterectomy; none using estrogen. United States based with nearly 200 clinical sites in North America. | Tamoxifen: 20 mg/day raloxifene: 60 mg/day Mean follow-up 3.9 years with mean exposure 3.1 to 3.2 years. | Thromboembolic events combined, pulmonary embolism, deep vein thrombosis, ischemic coronary heart disease, myocardial infarction, severe angina, acute ischemic syndrome, stroke, transient ischemic attack, endometrial cancer, hysterectomy, genitourinary cancers, cataracts, cataract surgery, quality of life indicators, sexual function, musculoskeletal problems, dyspareunia, weight gain, gynecological problems, vasomotor symptoms, leg cramps, bladder control symptoms.
Tamoxifen Studies
National Surgical Adjuvant Breast and Bowel Project P-1 Study (NSABP-1) 21–24 | RCT | 6576/6599 | Women age ≥60 years or age 35 to 59 years with a 5-year predicted risk of breast cancer ≥1.66% based on the modified Gail model,^†^ or a history of lobular carcinoma in situ. 39% of women were <50 years old; 97% white; 38% post hysterectomy; none using estrogen. United States based with multiple clinical sites in North America. | 20 mg/day Median follow-up 4.6 years, median exposure 4.0 years for initial results. Median follow-up 7.0 years for long-term results. | Pulmonary embolism, deep vein thrombosis, composite measures of coronary heart disease, myocardial infarction, acute coronary syndrome, severe angina, stroke, transient ischemic attack, endometrial cancer, gynecologic conditions, hysterectomy, vaginal symptoms (dryness, discharge), breast density, cataracts, cataract surgery, vasomotor symptoms, hot flashes, depression, quality of life indicators, sexual side effects.
International Breast Cancer Intervention Study (IBIS-I)19, 20 | RCT | 3573/3566 | Women with increased breast cancer risk based on family history and other factors.^‡^ Age 35 to 70 years, mean age 50.8 years; 35% post hysterectomy; 40% using estrogen. United Kingdom, Australia, New Zealand, Europe. | 20 mg/day Median follow-up 4.2 years for initial results. 8.0 years follow-up for long-term results. | Pulmonary embolus, deep vein thrombosis, superficial thrombophlebitis, retinal vein thrombosis, composite cardiac outcomes, myocardial infarction, angina, stroke, transient ischemic attack, endometrial cancer, gynecologic conditions, gynecologic procedures, vaginal symptoms, breast density, breast symptoms, cataracts, vasomotor symptoms, headaches.
Royal Marsden Hospital Trial25, 26 | RCT | 1238/1233 | Women with family history of breast cancer.^§^ Age 30 to 70 years; median age 47 years; 15% of tamoxifen and 27% of placebo group using estrogen at the beginning of trial. United Kingdom. | 20 mg/day Median follow-up 5.8 years for initial results. 13.2 years follow-up for long-term results. | Composite thromboembolic events, pulmonary embolism, deep venous thrombosis, cardiovascular outcomes, stroke, endometrial thickness, cystitis, incontinence, breast symptoms, cataracts, gastrointestinal symptoms, hot flashes, weight gain, headaches.
Italian Tamoxifen Prevention Study29, 30, 50 | RCT | 2700/2708 | Women with hysterectomy for reasons other than cancer. Age 35 to 70 years; median age 51 years; 14% using estrogen. Italy based with 55 clinical centers in Europe and South America. | 20 mg/day Median follow-up 3.8 years for initial results. 11.2 years follow-up and 4.0 years exposure for long-term results. | Pulmonary embolism, deep venous thrombosis, visceral, retinal and superficial thrombophlebitis, myocardial infarction, atrial fibrillation, stroke, cystitis, incontinence, gastrointestinal symptoms, vasomotor symptoms, hot flashes, weight gain.
Raloxifene Studies
Multiple Outcomes of Raloxifene Evaluation (MORE) and Continuing Outcomes Relevant to Evista (CORE) 31–37, 39–45, 87 | RCT | MORE: 5129/2576 CORE: 2725/1286 | Postmenopausal women with osteoporosis.║ Age 31 to 80 years; median age 66.9 years; 96% white; 23% post hysterectomy; none using systemic estrogen. United States based with 180 clinical centers in 25 countries. CORE is comprised of a subset of MORE participants to further examine raloxifene’s effect on breast cancer incidence. | MORE: 60 or 120 mg/day CORE: 60 mg/day Follow-up time varies; MORE results reported at 3 and 4 years and CORE at 4 and 8 years (combines the MORE and CORE data). | Thromboembolic events, pulmonary embolism, deep vein thrombosis, composite coronary heart disease measures, myocardial infarction, coronary death, silent myocardial infarction, sudden death, unstable angina, acute coronary syndrome, coronary ischemia, stroke, uterine pathology, endometrial cancer, uterine bleeding, urinary symptoms, breast density, cataracts, gastrointestinal symptoms, vasomotor symptoms, peripheral edema, leg cramps.
Raloxifene Use for the Heart (RUTH) 46, 47 | RCT | 5044/5057 | Postmenopausal women with coronary heart disease or multiple risk factors for heart disease.^¶^ Age ≥55 years; median age 67.5 years; 84% white; 23% post hysterectomy; none on estrogen. United States based with 177 clinical sites in 26 countries. | 60 mg/day Median duration 5.6 years; median exposure 5.1 years. | Pulmonary embolism, deep venous thrombosis, stroke, coronary events (death from coronary causes, nonfatal myocardial infarction, acute coronary syndrome), endometrial cancer, ovarian cancer, cataracts, cholelithiasis, dyspepsia, cholecystectomy, vasomotor symptoms, peripheral edema.
Cohen, 2000^**,73^ | RCT | 234 (30 mg); 245 (60 mg); 243 (150 mg)/247 (placebo) | Healthy women, 2–8 years postmenopausal; none with hysterectomy. Age 45–60 years. Multi-center with US sites. | 30, 60, or 150 mg/day; 3 years. | Uterine bleeding.
Delmas, 1997^74^ | RCT | 152 (30 mg); 152 (60 mg); 147 (150 mg)/150 (placebo) | Postmenopausal women with osteoporosis; none with hysterectomy. Mean age 55 years; 99% white. Multi-center no US sites. | 30, 60, or 150 mg/day; 2 years. | Uterine bleeding, vasomotor effects including hot flashes, other gynecologic symptoms, breast symptoms.
Goldstein, 2005^76^ | RCT | 152 (60 mg); 157 (150 mg)/152 (placebo) | Postmenopausal women; all with hysterectomy. Mean age 53 years; 96% white. Multi-center with US sites. | 60 or 150 mg/day; 3 years. | Urinary outcomes, breast symptoms.
Johnston, 2000^**,77^ | RCT | 288 (30 mg); 286 (60 mg); 285 (150 mg)/286 (placebo) | Healthy, postmenopausal women. Mean age 54.5 years. Multi-center with US sites. | 30, 60, or 150 mg/day 3 years. | Thromboembolic events, uterine bleeding, other gynecologic symptoms, breast symptoms, gastrointestinal symptoms, hot flashes, leg cramps, peripheral edema.
Jolly, 2003^**,78^ | RCT | 163/125 | Healthy, postmenopausal women remaining on therapy from Johnston, 2000 study. Mean age 55 years; 96% white. Multi-center with US sites. | 60 mg/day; 5 years. | Thromboembolic events, uterine bleeding, hot flashes, leg cramps.
Lufkin, 1998^††,79^ | RCT | 48 (60 mg); 47 (120 mg)/48 (placebo) | Healthy postmenopausal women with osteoporosis; 15% with hysterectomy. Mean age 68.4 years. United States. | 60 or 120 mg/day; 1 year. | Thromboembolic events, uterine bleeding, other gynecologic symptoms, breast symptoms, joint pain, dizziness, hot flashes.
McClung, 2006^80^ | RCT | 163/83 | Postmenopausal women with osteoporosis; up to 30% with hysterectomy. Mean age 58 years. Multi-center with US sites. | 60 mg/day; 2 years. | Uterine bleeding, hot flashes, leg cramps, breast symptoms, thromboembolic events.
Meuneir, 1999^81^ | RCT | 45 (60 mg); 42 (150 mg)/42 (placebo) | Postmenopausal women with osteoporosis; approximately 10% with hysterectomy. Mean age 60 years. France. | 60 or 150 mg/day; 2 years. | Thromboembolic events, vasomotor effects.
Morii, 2003^82^ | RCT | 92 (60 mg); 95 (120 mg)/97 (placebo) | Postmenopausal women with osteoporosis; hysterectomy status not reported. Mean age 65 years. Japan. | 60 or 120 mg/day; 1 year. | Thromboembolic events, uterine bleeding, vasomotor effects, leg cramps, breast symptoms, gastrointestinal symptoms, malaise/lethargy.
Nickelson, 1999^††,83^ | RCT | 48 (60 mg); 47 (120 mg)/48 (placebo) | Postmenopausal women with osteoporosis; 15% with hysterectomy. Mean age 69 years. United States. | 60 or 120 mg/day; 1 year. | Vasomotor effects, mood, depression, cognition, anxiety symptoms.
Palacios, 2004^84^ | RCT | 167/159 | Postmenopausal women; 25% with hysterectomy; Mean age 58 years. Multi-center with no US sites. | 60 mg/day; 8 months. | Thromboembolic events, uterine bleeding, vasomotor effects, breast symptoms, influenza syndrome, joint pain, mood, depression, anxiety symptoms, weight gain, malaise/lethargy.
Walsh, 1998^85^ | RCT | 95 (60 mg); 101 (120 mg)/98 (placebo) | Healthy postmenopausal women; 19–31% post hysterectomy. Mean age 59 years; 90% white. Multi-center with US sites. | 60 or 120 mg/day; 6 months. | Vaginal bleeding, breast symptoms, weight gain, hot flashes.
Christodoulakos, 2006^86^ | Prospe ctive cohort | 137 raloxifene/204 tibolone/189 nonuser | Postmenopausal women with menopausal symptoms or osteoporosis; none with hysterectomy. Age 42–66. Menopause clinic in Greece. | 60 mg/day | Uterine bleeding.
Tibolone Studies
Long-Term Intervention on Fractures with Tibolone (LIFT)10, 87 | RCT | 2267/2267 | Women with bone mineral density T-score ≤-2.5 at the hip or spine or T-score ≤-2.0 and radiologic evidence of a vertebral fracture. Age 60 to 85 years; mean 68 years. 22% post hysterectomy; none on estrogen. United States based with 80 clinical sites in 22 countries. | 1.25 mg/day; median exposure 2.8 years. | Death, coronary heart disease, bradycardia, stroke, transient ischemic attack, venous thromboembolism, cervical cancer, colon cancer, endometrial cancer, pelvic pain, vaginal infection, vaginal discharge, vaginal bleeding, breast discomfort, weight gain, gastroenteritis.
Osteoporosis Prevention and Arterial effects of tiboLone(OPAL)88–90 | RCT | 290/288 | Healthy postmenopausal women; 18% post hysterectomy (0% in US, 30% in Europe). Mean age 58.7 years (range 45–79 years); 96% Caucasian; 1% Black; 2% Asian; 1% Other. United States and Europe. | 2.5 mg/day; 36 months. | Endometrial cancer, uterine cancer, vaginal bleeding/spotting, musculoskeletal disorders.
Landgren, 2002^91^ | RCT | 149 (0.625 mg); 143 (1.25 mg); 154 (2.5 mg); 151 (5 mg)/143 (placebo) | Healthy postmenopausal women with vasomotor symptoms; none with hysterectomy. Mean age 52 years (range 40–60). Sweden, Netherlands, Norway, and Finland. | 0.625, 1.25, 2.5, or 5 mg/day; 36 months. | Deep venous thrombosis, pulmonary embolism, concussion, headache, vertigo, abdominal pain, vaginal bleeding and spotting, retinal detachment, cholecystitis, hot flashes, sweating.
Gallagher, 2001^92^ | RCT | 153 (0.3 mg); 158 (0.625 mg); 154 (1.25 mg); 155 (2.5 mg)/150 (placebo) | Healthy postmenopausal women; 3% post hysterectomy. Mean age 52.4 years. United States. | 0.3, 0.635, 1.25, or 2.5 mg/day; 24 months. | Deep venous thrombosis, pulmonary embolism, vaginal bleeding, moniliasis, allergy, anxiety, nervousness, herpes simplex infection, back pain, rhinitis, headache, weight gain, respiratory tract infection, hot flashes, arthralgia, accidental injury, influenza-like symptoms, sinusitis, pain, abdominal pain.
Swanson, 2006^93^ | RCT | 136 (1.25 mg); 126 (2.5 mg)/134 (placebo) | Postmenopausal women with vasomotor symptoms; none with hysterectomy. Mean age 51–53 years; 90–93% Caucasian, 5–7% Black, 2–3% Other. United States. | 1.25 or 2.5 mg/day; 3 months. | Coronary heart failure, hot flashes, genital atrophy, nocturia, urinary urgency, kidney stone, headache, upper respiratory symptoms, nausea, breast pain, uterine spasm, enlarged abdomen, genital pruritus, weight gain, vaginal bleeding.
Hudita, 2003^94^ | RCT | 45 (1.25 mg); 41 (2.5 mg)/34 (placebo) | Healthy postmenopausal women with vasomotor symptoms; none with hysterectomy. Mean age 54–56 years. Romania. | 1.25 or 2.5 mg/day; 6 months. | Hot flashes, sweating, vaginal dryness, sexual function, breast density, breast discomfort, vaginal bleeding/spotting, headache, nausea, fluid retention.
Onalan, 2005^96^ | RCT | 76/54 | Postmenopausal women; none with hysterectomy. Mean age 52.4 years. Menopause clinic in Turkey. | 2.5 mg/day; 12 months. | Depression.
Lundstrom, 2002^95^ | RCT | 51/55 | Healthy postmenopausal women; hysterectomy status not reported. Age range 50–70 years. Sweden. | 2.5 mg/day; 6 months. | Breast density, breast pain.
Million Women’s Study Beral, 2003^98^ | Prospe ctive cohort | 18,186/392,757 | Women invited for breast cancer screening who were using tibolone for menopausal symptoms; hysterectomy status not reported. Mean age 55.9 years (range 50–64 years). United Kingdom. | Dose varied; 2.6 years. | Vaginal bleeding.
Million Women’s Study Beral, 2005^97^ | Prospective cohort | 28,028/395,785 | Postmenopausal women with no previous cancer or hysterectomy using tibolone for menopausal symptoms. Mean age 58 years. United Kingdom. | Dose varied; 3.1 years. | Endometrial cancer.

* Quality and applicability ratings described in Appendix C-5.

† STAR & NSABP-1: The Gail model includes age, number of first-degree relatives with breast cancer, nulliparity or age at first live birth, number of benign breast biopsies, pathologic diagnosis of atypical hyperplasia, and age at menarche. The original model was further modified to predict expected rates of invasive breast cancer only (not invasive and noninvasive as originally designed) and to allow for race-specific determinations of risk.

‡ IBIS: 2-fold relative risk for ages 45 to 70, 4-fold relative risk for ages 40 to 44, 10-fold relative risk for ages 35 to 39 based on family history criteria. All criteria permit entry to trial at age 45 years.

1. First-degree relative who developed breast cancer at or before age 50.

2. First-degree relative with bilateral breast cancer (permits entry from age 40; if relative diagnosed before age 40, permits entry at age 35).

3. Two or more first-degree or second-degree relatives with breast cancer (permits entry from age 40 if both developed breast cancer before age 50, permits entry at age 35 if both relatives are first-degree and both developed breast cancer before age 50).

4. Benign breast biopsy and first-degree relative with breast cancer.

5. Lobular carcinoma in situ (permits entry from age 35).

6. Atypical hyperplasia (permits entry from age 40).

7. Nulliparous and a first-degree relative who developed breast cancer.

8. Risk equivalent (strong family history, not fitting specific categories, but judged to be at higher risk than eligibility category by the study chairman).

§ Family history criteria for Royal Marsden Hospital Trial:

1. One first-degree relative under 50 years old with breast cancer, or

2. One first-degree relative with bilateral breast cancer, or

3. One affected first-degree of any age plus another affected first-degree or second-degree relative

4. Benign breast biopsy and a first-degree relative with breast cancer

|| MORE:

Study Group 1: Femoral neck or lumbar spine bone mineral density T-score <-2.5.

Study Group 2: Low bone mineral density and one or more moderate or severe vertebral fractures or 2 or more milder vertebral fractures (20% to 25% reduction in height); or at least 2 moderate fractures (25% to 40% reduction from expected vertebral height), regardless of bone mineral density.

¶ Participants were required to have a cardiovascular risk score of 4 or more according to a point system: established coronary heart disease (4 points), arterial disease of the leg (4 points), at least 70 years old (2 points), diabetes mellitus (3 points), cigarette smoking (1 point), hypertension (1 point), and hyperlipidemia (1 point).

** Cohen, 2000, Johnston, 2000, and Jolly, 2003 include some of the same study participants.

†† Lufkin, 1998 and Nickelson, 1999 include some of the same study participants.

## Appendix D-2. Harms Outcomes from Trials

### Thromboembolic Events

All Thromboembolic Events-STAR

Trial Name | N | | Length of Treatment (years) | Length of FU (years) | Tamoxifen | | Raloxifene | | RR | 95% CI
Trial Name | Tamoxifen | Raloxifene | Length of Treatment (years) | Length of FU (years) | No. | Rate | No. | Rate | RR | 95% CI
STAR
Vogel, 2006^12^ | 9726 | 9745 | 5 | 6 | 141 | 3.71 | 100 | 2.61 | 0.7 | 0.54–0.91

All Thromboembolic Events- Tamoxifen Trials

Trial Name | N | | Length of Treatment (years) | Length of FU (years) | Placebo | | Tamoxifen | | RR | 95% CI | Notes
Trial Name | Placebo | Tamoxifen | Length of Treatment (years) | Length of FU (years) | No. | Rate | No. | Rate | RR | 95% CI | Notes
Royal Marsden
Powles, 2007^26^ | 1233 | 1238 | 7.8 | 13.2 | 3 | 0.31 | 8 | 0.82 | 2.62 | 0.69–9.87 | Active treatment
Powles, 2007^26^ | 1233 | 1238 | 8 | 13.2 | 6 | | 5 | | | | Post treatment P = 1.0
Powles, 1998^25^ | 1233 | 1238 | | 5.8 | | 0.8 | 5 | 0.68 | 0.85 | 0.26–2.79
Italian
Dicensi, 2005^27^ | 2708 | 2700 | 5 | 11 | 9 | 0.94 | 10 | 1.02 | 1.09 | 0.44–2.68 | on treatment
IBIS
Cuzick, 2007^20^ | 3375 | 3579 | 5 | 8 | 36 | 2.02 | 68 | 3.8 | | | Active treatment
Cuzick, 2007 20 | 3575 | 3579 | | | 24 | 2.24 | 26 | 2.42 | | | Post treatment
NSABP
Fisher, 1998^24^ | 6707 | 6681 | 4 | 4 | 2.8 | 1.07 | 53 | 2.03 | 1.9 | 1.20–3.00

All Thromboembolic Events- Raloxifene trials

Trial Name | N | | | Length of Treatment (years) | Length of FU (years) | Placebo | | R 60 | | R 120 | | RR | 95% CI
Trial Name | Placebo | R60 | R120 | Length of Treatment (years) | Length of FU (years) | No. | Rate | No. | Rate | No. | Rate | RR | 95% CI
MORE
Grady, 2004^39^ | | | | | 3.3 | 14 | 1.7 | 59 | 3.5 | | | 2.1 | 1.2–3.8
RUTH
Barrett-Connor, 2006^46^ | 5057 | 5044 | | | 5.6 | 71 | 2.53 | 103 | 3.67 | | | 1.44 | 1.06–1.95

All Thromboembolic Events- LIFT Trial

| N | | Length of Treatment | Placebo | | Tibolone | | RR | 95% CI | Notes
| Placebo | Tibolone | Length of Treatment | No. | Rate | No. | Rate | RR | 95% CI | Notes
Venous thromboembolism | 2257 | 2249 | 34 months | 9 | 1.3 | 5 | 0.8 | 0.57 | 0.19–1.69 | p=0.31

Deep Vein Thrombosis- STAR

Trial Name | N | | Length of Treatment (years) | Length of FU (years) | Tamoxifen | | Raloxifene | | RR | 95% CI
Trial Name | Tamoxifen | Raloxifene | Length of Treatment (years) | Length of FU (years) | No. | Rate | No. | Rate | RR | 95% CI
STAR Vogel, 2006^12^ | 9726 | 9745 | 5 | 6 | 87 | 2.29 | 65 | 1.69 | 0.74 | 0.53–1.03

Deep Vein Thrombosis- Tamoxifen trials

Trial Name | N | | Length of Treatment (years) | Length of FU (years) | Placebo | | Tamoxifen | | RR | 95% CI
Trial Name | Placebo | Tamoxifen | Length of Treatment (years) | Length of FU (years) | No. | Rate | No. | Rate | RR | 95% CI
Royal Marsden
NR
Italian
Decensi, 2005^27^ | 2708 | 2700 | | | 8 | 0.83 | 9 | 0.92 | 1.1 | 0.43–2.86
IBIS
NR
NSABP
Fisher, 2005^23^ | 6707 | 6681 | 5 years | 7 years | 34 | 0.84 | 49 | 1.21 | 1.44 | 0.91–2.30
Age ≤ 49 | | | | | 12 | 0.76 | 16 | 1.01 | 1.34 | 0.59–3.10
Age ≥ 50 | | | | | 22 | 0.89 | 33 | 1.33 | 1.49 | 0.84–2.68
Fisher, 1998^24^ | 6707 | 6681 | 5 years | 69 months | 22 | 0.84 | 35 | 1.34 | 1.60 | 0.91–2.86
A ge ≤ 49 | | | | | 8 | 0.78 | 11 | 1.08 | 1.39 | 0.51–3.99<
Age ≥ 50 | | | | | 14 | 0.88 | 24 | 1.51 | 1.71 | 0.85–3.58

Deep Vein Thrombosis- Raloxifene trials

Trial Name | N | | | Length of Treatment (years) | Length of FU (years) | Placebo | | R 60 | | R 120 | | RR | 95% CI | Notes
Trial Name | Placebo | R60 | R120 | Length of Treatment (years) | Length of FU (years) | No. | Rate | No. | Rate | No. | Rate | RR | 95% CI | Notes
MORE
Grady, 2004^39^ | | | | | | 7 | 0.8 | | combined | 2.5 | | 3.13 | 1.41–6.95
RUTH
Barrett-Connor, 2006**46 | 5057 | 5044 | | | 5.6 | 47 | 1.67 | 65 | 2.32 | | | 1.37 | 0.94–1.99 | Annualized rates

### Cardiovascular Events

Cardiovascular Outcomes- STAR

Trial Name | N | | Length of Treatment (years) | Length of FU (years) | Tamoxifen | | Raloxifene | | RR | 95% CI
Trial Name | Tamoxifen | Raloxifene | Length of Treatment (years) | Length of FU (years) | No. | Rate | No. | Rate | RR | 95% CI
STAR
Vogel, 2006^12^ All ischemic coronary heart disease | | | 5 | 3.9 | 114 | 3 | 126 | 3.29 | 1.1 | 0.85–1.43
Myocardial Infarction | | | | | 48 | 1.26 | 37 | 0.96 | 0.77 | 0.48–1.20
Severe angina (requiring PCI or CABG) | | | | | 51 | 1.34 | 63 | 1.64 | 1.23 | 0.84–1.81
Acute ischemic syndrome (new Q waves or angina requiring hospitalization) | | | | | 15 | 0.39 | 26 | 0.68 | 1.72 | 0.88–3.50

Cardiovascular Outcomes- Tamoxifen trials

Trial Name | N | | Length of Treatment (years) | Length of FU (years) | Placebo | | Tamoxifen | | RR | 95% CI | Notes | Outcome assessment
Trial Name | Placebo | Tamoxifen | Length of Treatment (years) | Length of FU (years) | No. | Rate | No. | Rate | RR | 95% CI | Notes | Outcome assessment
Royal Marsden
Powles 2007^26^: Active | 1233 | 1238 | 8 | 13.2 | 10 | 1.25 | 12 | 1.02 | 0.82 | 0.35–1.89 | p= 0.7 | “Cardiovasc-ular problems” not further defined.
Post | | | | | 11 | | 14 | | | | p= 0.7
Italian
Veronesi, 2007^29^: Myocardial Infarction | 2708 | 2700 | 5 | 4 | 5 | 0.48 | 5 | 0.49 | 1.04 | 0.3–3.58
Veronesi, 2007^29^: | | | | | 21 | 2.01 | 35 | 3.48 | 1.73 | 1.01–2.98 | | Cardiac Arrhythmias, Atrial Fibrillation
IBIS
Cuzick, 2007^20^ CHD events | 3575 | 3579 | 5 | 96 months | 71 | 2.73 | 64 | 2.37 | 1.15 | 0.81–1.64 | | Checklist of predefined side effects asked directly during main trial
All cardiac Active | | | | | 71 | 3.98 | 64 | 3.59 | 0.9 | 0.63–1.28 | | Mailed questionaires during follow-up
Post | | | | | 52 | 4.85 | 58 | 5.42 | 1.12 | 0.75–1.66 | | Illnesses confirmed with record review
MI; Active | | | | | 7 | 0.39 | 2 | 0.11 | 0.29 | 0.03–1.5
Post | | | | | 8 | 0.75 | 7 | 0.65 | 0.88 | 0.27–2.76
NSABP
Fisher, 2005^23^ Total CHD | 6707 | 6681 | 5 | 7 | 109 | 2.7 | 113 | 2.79 | 1.03 | 0.79–1.36 | | Total CHD includes: MI, acute coronary syndrome, severe angina
Fisher, 1998^24^ Total CHD | | | 5 | 69 months | 62 | 2.37 | 71 | 2.73 | 1.15 | 0.81–1.64
Fisher, 2005^23^ MI | | | | | 44 | 1.09 | 43 | 1.06 | 0.97 | 0.62–1.52
Fisher, 2005^23^ ACS | | | | | 32 | 0.79 | 36 | 0.89 | 1.12 | 0.68–1.86
Fisher, 2005^23^ Severe angina | | | | | 33 | 0.82 | 34 | 0.84 | 1.03 | 0.62–1.71
Fisher, 1998^24^ MI | 6707 | 6681 | 4 | 4 | 28 | 1.07 | 31 | 1.19 | 1.11 | 0.65–1.92

Cardiovascular Outcomes- Raloxifene Trials

Trial Name | N | | | Length of Treatment (years) | Length of FU (years) | Placebo | | R 60 | | R 120 | | RR | 95% CI | Notes
Trial Name | Placebo | R60 | R120 | Length of Treatment (years) | Length of FU (years) | No. | Rate | No. | Rate | No. | Rate | RR | 95% CI | Notes
MORE
Keech, 2005^41^ Cumulative CVD events (MI, CVA, CABG, PCA) | 2576 | 2557 | | 4 | 1 | 23 | | 25 | | | | | | P time trend 0.575
| | | | | 2 | 47 | | 40
| | | | | 3 | 71 | | 76
| | | | | 4 | 96 | | 82
Barret-Connor, 2002^32^:CHD | 2576 | | 5129 | 3.4 | 3.4 | 55 | | 45 | | 56 | | 0.88 | 0.53–1.40 | 60 mg
| | | | | | | | | | | | 1.02 | 0.71–1.47 | 120 mg
RUTH
Barrett-Connor, 2006^46^ Coronary events (death from coronary causes, non-fatal MI, ACS) | 5057 | 5044 | | | 5 | 553 | | 533 | | | | 0.95 | 0.84–1.07
Death CVD (CVD causes, MI, stroke, ACS) | | | | | | 1041 | | 1067 | | | | 1.01 | 0.93–1.10
Fatal CHD | | | | | | 273 | | 253 | | | | 0.92 | 0.77–1.09
Non-fatal MI | | | | | | 208 | | 183 | | | | 0.87 | 0.71–1.06

Cardiovascular Outcomes- LIFT trial

| N | | Length of Treatment | Placebo | | Tibolone | | RR | 95% CI | Notes
| Placebo | Tibolone | Length of Treatment | No. | Rate | No. | Rate | RR | 95% CI | Notes
CHD | 2257 | 2249 | 34 m | 20 | 3 | 27 | 4.1 | 1.37 | 0.77–2.45 | p=0.28
Sinus bradycardia | 2257 | 2249 | 34m | 52 | NR | 33 | NR | NR | NR | p=0.008

Stroke- STAR

Trial Name | N | | Length of Treatment (years) | Length of FU (years) | Tamoxifen | | Raloxifene | | RR | 95% CI | Notes
Trial Name | Tamoxifen | Raloxifene | Length of Treatment (years) | Length of FU (years) | No. | Rate | No. | Rate | RR | 95% CI | Notes
STAR
| 9726 | 9745 | 5 | 6 | 53 | 1.39 | 51 | 1.33 | 0.96 | 0.92–1.32 | R/T

Stroke- Tamoxifen trials

Trial Name | N | | Length of Treatment (years) | Length of FU (years) | Placebo | | Tamoxifen | | RR | 95% CI | Notes
Trial Name | Placebo | Tamoxifen | Length of Treatment (years) | Length of FU (years) | No. | Rate | No. | Rate | RR | 95% CI | Notes
Royal Marsden
Powles, 2007^26^ Active: | 1233 | 1238 | 7.8 | 13 | 9 | 0.94 | 7 | 0.72 | 0.76* | 0.28–2.05* | P = 0.6; Stroke not defined
Powles 2007^26^: Post | | | | | 7 | 0.93 | 3 | 0.41 | 0.44* | 0.11–1.69* | P = 0.3
Italian
Veronesi, 2007^29^ All cerebrovascular | 2708 | 2700 | 4 | 11 | 7 | 0.67 | 12 | 1.19 | 1.78 | 0.70–4.52 | only includes AEs during active treatment
Veronesi, 2007^29^ Stroke only | | | 4 | 11 | 2 | 0.19 | 6 | 0.59 | 3.11 | 0.63–15.4 | Stroke not further defined
IBIS
Cuzick, 2007^20^: Active | 3575 | 3579 | 5 | 5 | 8.5 | 0.45 | 8 | 0.45 | 1 | 0.33–3.06 | Stroke not further defined
Cuzick, 2007^20^: Post | | | 5 | 3 | 3 | 0.37 | 7 | 0.65 | 1.75 | 0.45–8.16
NSABP
Fisher, 1998^24^ | 6707 | 6681 | 4 | 4 | 24 | 0.91 | 38 | 1.45 | 1.59 | 0.93–2.77
Fisher, 2005^23^ | 6707 | 6681 | 5 | 7 | 50 | 1.23 | 71 | 1.75 | 1.42 | 0.97–2.08 | Stroke not further defined
Age≤49 | | | | | 8 | 0.5 | 9 | 0.57 | 1.13 | 0.39–3.36
Age≥50 | | | | | 42 | 1.7 | 62 | 2.5 | 1.47 | 0.97–2.22

Stroke- Raloxifene trials

Trial Name | N | | | Length of Treatment (years) | Length of FU (years) | Placebo | | R 60 | | R 120 | | RR | 95% CI | Notes
Trial Name | Placebo | R60 | R120 | Length of Treatment (years) | Length of FU (years) | No. | Rate | No. | Rate | No. | Rate | RR | 95% CI | Notes
MORE
Barrett-Connor, 2002^32^ | 2576 | 2557 | 2572 | 3.4 | 4 | 32 | | 22 | | 26 | | 0.69 0.81 | 0.40–1.18 0.49–1.36 | Raloxifene60mg Raloxifene120mg
CORE
NR
RUTH
Barrett- Connor, 2006^46^ | 5057 | 5044 | | 5.6 | 5.6 | 224 | 7.97 | 249 | 8.88 | | | 1.10 | 0.92–1.32

Stroke- LIFT Trial

N | | Length of Treatment | Placebo | | Tibolone | | RR | 95% CI | Notes
Placebo | Tibolone | Length of Treatment | No. | Rate | No. | Rate | RR | 95% CI | Notes
2257 | 2249 | 34 months | 13 | 1.9 | 28 | 4.3 | 2.19 | 1.14–4.23 | > 70 yrs 6.6; 60–69 yrs 3.4. includes ischemic and hemorrhagic stroke

Transient Ischemic Attack- STAR

Trial Name | N | | Length of Treatment (years) | Length of FU (years) | Tamoxifen | | Raloxifene | | RR | 95% CI | Notes
Trial Name | Tamoxifen | Raloxifene | Length of Treatment (years) | Length of FU (years) | No. | Rate | No. | Rate | RR | 95% CI | Notes
STAR
| 9726 | 9745 | 5 | 6 | 41 | 1.08 | 50 | 1.3 | 1.21 | 0.79–1.88 | R/T

Transient Ischemic Attack- Tamoxifen trials

Trial Name | N | | Length of Treatment (years) | Length of FU (years) | Placebo | | Tamoxifen | | RR | 95% CI
Trial Name | Placebo | Tamoxifen | Length of Treatment (years) | Length of FU (years) | No. | Rat e | No. | Rate | RR | 95% CI
Royal Marsden
Powles, 2007^26^: Active | NR
Post | NR
Italian
Veronesi, 2007^29^ | 2708 | 2700 | 4 | 5 | 5 | 0.48 | 6 | 0.59 | 1.24 | 0.38–4.08
IBIS
Cuzick, 2007^20^: Active | 3575 | 3579 | 5 | 5 | 9 | 0.5 | 4 | 0.22 | 0.44 | 0.11–1.57
Post | | | 5 | 3 | 13 | 1.21 | 13 | 1.21 | 1 | 0.43–2.34
NSABP
Fisher, 2005^23^ | 6707 | 6681 | 7 | | 34 | 0.84 | 31 | 0.76 | 0.91 | 0.54–1.52
Age≤49 | | | | | 7 | 0.44 | 4 | 0.25 | 0.57 | 0.12–2.25
Age≥50 | | | | | 27 | 1.1 | 27 | 1.09 | 0.99 | 0.56–1.76
Fisher, 1998 | 6707 | 6681 | 4 | 4 | 25 | 0.95 | 19 | 0.73 | 0.76 | 0.40–1.44

Transient Ischemic Attack- LIFT trial

| N | | Length of Treatment | Placebo | | Treatment | | RR | 95% CI | notes
| Placebo | Tibolone | Length of Treatment | No. | Rate | No. | Rate | RR | 95% CI | notes
TIA | 2257 | 2249 | 34 months | 0.20% | NR | 0.30% | NR | NR | NR | Reported as rare

### Genitourinary Outcomes

Uterine Outcomes- STAR

Trial Name | N | | Length of Treatment (years) | Length of FU (years) | Tamoxifen | | Raloxifene | | RR | 95% CI | Notes
Trial Name | Tamoxifen | Raloxifene | Length of Treatment (years) | Length of FU (years) | No. | Rate | No. | Rate | RR | 95% CI | Notes
STAR
Hyperplasia | 9726 | 9745 | 5 | 6 | 84 | 4.69 | 14 | 0.76 | 0.16 | 0.09–0.29
Hysterectomy | | | | | 244 | 13.57 | 111 | 6.04 | 0.44 | 0.35–0.56
Uterine bleeding | | | | | | NR | | NR
Uterine cancer | | | | | | 2 | | 1.25 | 0.62 | 0.35–1.08

Uterine Outcomes- Tamoxifen trials

Trial Name | N | | Length of Treatment (years) | Length of FU (years) | Placebo | | Tamoxifen | | RR | 95% CI | Notes
Trial Name | Placebo | Tamoxifen | Length of Treatment (years) | Length of FU (years) | No. | Rate | No. | Rate | RR | 95% CI | Notes
Royal Marsden
Powles, 2007^26^ | 1233 | 1238 | _ | 13.2 | 5 | 0.29 | 13 | 0.76 | 2.59 | 0.93–7.24 | Entire trial period
Hysterectomy | | | | | 96 | | 177
Period abnormality | | | | | 439 | | 496 | | | | Active Treatment
Period abnormality | | | | | 87 | | 119 | | | | Post Treatment
IBIS
Total Uterine cancer | 2292 | 2347 | | 8 | 11 | 0.60 | 17 | 0.91 | 1.51 | 0.71–3.23 | Active and post
Vasomotor/Gyn | | | | | 1983 | | 2389 | | 1.2 | 1.16–1.25 | Active Treatment
Vasomotor/Gyn | | | | | 1438 | | 1508 | | 1.06 | 0.99–1.12 | Post Treatment
NSABP
Fisher, 2005^23^ Uterine cancer cumulative | 4194 | 4097 | 5 Y | 7 | 17 | 0.68 | 53 | 2.24 | 3.28 | 1.87–6.03
Uterine <49 | | | | | 9 | 0.82 | 12 | 1.16 | 1.42 | 0.55–3.81
Uterine cancer ≥50 | | | | | 8 | 0.58 | 48 | 3.08 | 5.33 | 2.47–13.17
Fisher, 1998^24^ | 4194 | 4097 | | 4 | 15 | 0.91 | 36 | 2.3 | 2.53 | 1.35–4.97

Uterine Outcomes- Raloxifene trials

Trial Name | N | | | Length of Treatment (years) | (Length of FU years) | Placebo | | R 60 | | R 120 | | RR | 95% CI | Notes
Trial Name | Placebo | R60 | R120 | Length of Treatment (years) | (Length of FU years) | No. | Rate | No. | Rate | No. | Rate | RR | 95% CI | Notes
MORE
Grady, 2004^39^ Endometrial cancer | 1999 | 3960 | | 3.3 | 3.3 | 5 | NR | 9 | NR | | | 0.9 | 0.3
Uterine bleeding | | | | | | 72 | | 79 | | 65 | | | | P 0.946
Endometrial cavity fluid | | | | | | 76 | | 99 | | 111 | | | | P 0.009
CORE
Martino, 2004^51^ Endometrial hyperplasia | | | | | 4 | 2 | 0.2 | 1 | 0.05 | | | | | P 0.24
Endometrial hyperplasia | | | | | 8 | 3 | 0.29 | 8 | 0.37 | | | | | P > 0.99
RUTH
Barrett-Connor, 2006^46^ Endometrial Cancer | 3882 | 3900 | | 5.6 | 5.6 | 17 | 0.79 | 21 | 0.97 | | | 1.23 | 0.65–2.33 | P>0.53
Benign uterine/uterine bleeding | | | | | | 107 | | 102 | | | | | | P > 0.74
Uterine sarcoma | | | | | | 0 | | 1
Ovarian cancer | | | | | | 10 | | 17 | | | | | | P 0.17

Vaginal Outcomes- Tamoxifen trials

Trial Name | N | | Length of Treatment (years) | Length of FU (years) | Placebo | | Tamoxifen | | RR | 95% CI | Notes
Trial Name | Placebo | Tamoxifen | Length of Treatment (years) | Length of FU (years) | No. | Rate | No. | Rate | RR | 95% CI | Notes
Royal Marsden
Powles, 2007^26^ | 1233 | 1238 | 8 | 13.2
vaginal discharge | | | | | 167 | | 321 | | | | Active Treatment P < 0.001
Vaginal discharge | | | | | 17 | | 41 | | | | Post Treatment P < 0.001
Vaginal symptoms | | | | | 17 | | 37 | | | | Active Treatment P = 0.008
Vaginal symptoms | | | | | 0 | | 1 | | | | Post Treatment P = 0.5
Italian
Veronesi, 2007^29^: Vaginal dryness | 1697 | 1638 | 5 | 11.2 | | 29.9 | | 34.1 | 1.14 | 0.97–1.34
Vaginal discharge | | | | | | 17.6 | | 66.6 | 3.44 | 2.9–4.09
IBIS
Cuzick, 2002^19^ “gynecologic or vasomotor” | 3566 | 3573 | 5 | 50 months | 2414 | | 2922 | | | | P < 0.0001
NSABP
Fisher, 1998^24^: Vaginal discharge moderately to more bothersome | 6707 | 6681 | 5 | 5 | 13% | | 29%

Vaginal Outcomes- Raloxifene trials

Trial Name | N | | | Length of Treatment (years) | Length of FU (years) | Placebo | | R 60 | | R 120 | | RR | 95% CI | Notes
Trial Name | Placebo | R60 | R120 | Length of Treatment (years) | Length of FU (years) | No. | Rate | No. | Rate | No. | Rate | RR | 95% CI | Notes
MORE
Cauley, 2001^33^ | 2576 | 2557 | 2572 | 3 | 4 | | | | | | | | | Other than bleeding; not different than placebo (P>0.7) P 3.6%, R60 4.1%, R120 3.2%
RUTH
NR

Vaginal Outcomes – LIFT Trial

| N | | Length of Treatment | Placebo | | Tibolone | | RR | 95% CI | Notes
| Placebo | Tibolone | Length of Treatment | No. | Rate | No. | Rate | RR | 95% CI | Notes
vaginal infection | 2257 | 2249 | 34 months | 56 | NR | 186 | NR | NR | NR | p=0.007
vaginal discharge | 2257 | 2249 | 34 months | 40 | NR | 221 | NR | NR | NR | p<0.001
vaginal bleeding | 1773 | 1746 | 34 months | 45 | NR | 165 | NR | NR | NR | Those with uterus; p <0.001

Urinary Outcomes- STAR

Trial Name | N | | Length of Treatment (years) | Length of FU (years) | Tamoxifen | | Raloxifene | | RR | 95% CI
Trial Name | Tamoxifen | Raloxifene | Length of Treatment (years) | Length of FU (years) | No. | Rate | No. | Rate | RR | 95% CI
STAR
Bladder Cancer | 9726 | 9745 | 5 | 6 | | 0.18 | | 0.16 | 0.85 | 0.24–2.96

Urinary Outcomes- Tamoxifen trials

Trial Name | N | | Length of Treatment (years) | Length of FU (years) | Placebo | | Tamoxifen | | RR | 95% CI | Notes
Trial Name | Placebo | Tamoxifen | Length of Treatment (years) | Length of FU (years) | No. | Rate | No. | Rate | RR | 95% CI | Notes
Royal Marsden
Bladder symptoms | 1233 | 1238 | 8 | 13.2 | 25 | | 27 | | | | Active Treatment P=0.9
Post | | | | | 1 | | 3 | | | | P = 0.4
Italian
Active | 2708 | 2700 | 5 | 11 | 140 | 14.4 | 202 | 21.9 | 1.52 | 1.23–1.89
IBIS
NR
NSABP
NR

### Breast Outcomes

Breast Density Outcomes- Tamoxifen trials

Trial Name | N | | Length of Treatment (years) | Length of FU (years) | Placebo | | Tamoxifen | | RR | 95% CI | Notes
Trial Name | Placebo | Tamoxifen | Length of Treatment (years) | Length of FU (years) | No. | Rate | No. | Rate | RR | 95% CI | Notes
Royal Marsden
NR
Italian
NR
IBIS
Cuzick, 2004^58^ | 430 | 388 | 18 | 18 54 months | 3.50% 7.30% | | 7.90% 13.70% | | | | Decreased density Decreased density
NSABP
Brisson, 2000^55^ | 33 | 36 | 3.3–3.5 | 1.0–3.4 | | | | | | | Women with lower breast density: 38.5% (T) vs 6.7% (P); P = 0.069
| | | | 3.5–5 | | | | | | | 47.8% vs 22%, P=0.114

ER Negative Breast Cancer- STAR

Trial Name | N | | Length of Treatment (years) | Length of FU (years) | Tamoxifen | | Raloxifene | | RR | 95% CI | Notes
Trial Name | Tamoxifen | Raloxifene | Length of Treatment (years) | Length of FU (years) | No. | Rate | No. | Rate | RR | 95% CI | Notes
STAR
Vogel, 2006^12^ | 9726 | 9745 | 5 | 6 | 44 | 1.16 | 51 | 1.34 | | | R/T 1.15 (0.75–1.77)

ER Negative Breast Cancer- Tamoxifen trials

Trial Name | N | | Length of Treatment (years) | Length of FU (years) | Placebo | | Tamoxifen | | RR | 95% CI
Trial Name | Placebo | Tamoxifen | Length of Treatment (years) | Length of FU (years) | No. | Rate | No. | Rate | RR | 95% CI
Royal Marsden
Powles, 2007^26^ | 1233 | 1238 | | 13.24 | 17 | 1 | 24 | 1.4 | 1.4 | 0.7–2.6
Italian
Veronesi, 2007^29^ | 2708 | 2700 | | 11 | 19 | 0.64 | 21 | 0.7 | 1.1 | 0.59–2.05
IBIS
Cuzick, 2007^20^ | 3375 | 3579 | 5 | 8 | 35 | 1.23 | 35 | 1.23 | 1 | 0.61–1.65
NSABP
Fisher, 1998^24^ | 6599 | 6576 | 5 | 47.7 months | 1 | 1.2 | | 1.46 | 1.22 | 0.74–2.03
Fisher, 2005^23^ | | | 5 | 7 | 42 | 1.06 | 56 | 1.39 | 1.31 | 0.86–2.01

ER negative Breast Cancer- raloxifene trials

Trial Name | N | | | Length of Treatment (years) | Length of FU (years) | Placebo | | R 60 | | R 120 | | RR | 95% CI
Trial Name | Placebo | R60 | R120 | Length of Treatment (years) | Length of FU (years) | No. | Rate | No. | Rate | No. | Rate | RR | 95% CI
MORE | 2576 | 2557 | 2572 | | 4 | 4 | | 9 | | | | 1.13 | 0.35–3.66
CORE
Martino, 2004^51^ | 1286 | 2725 | | | 4 | 3 | 0.55 | 7 | 0.61 | | | 1.13 | 0.29–4.35
RUTH
Barrett-Connor, 2006^46^ | 5057 | 5044 | | | 5.6 | 9 | | 13 | | | | 1.44 | 0.61–3.36

Breast Outcomes – LIFT Trial

| N | | Length of Treatment | Placebo | | Tibolone | | RR | 95% CI | Notes
| Placebo | Tibolone | Length of Treatment | No. | Rate | No. | Rate | RR | 95% CI | Notes
Breast Discomfort | 2257 | 2249 | 34 months | 65 | NR | 203 | NR | NR | NR | P<0.001

### Opthalmalogic Disorders

Opthalmologic Outcomes- STAR

Trial Name | N | | Length of Treatment (years) | Length of FU (years) | Tamoxifen | | Raloxifene | | RR | 95% CI | Notes
Trial Name | Tamoxifen | Raloxifene | Length of Treatment (years) | Length of FU (years) | No. | Rate | No. | Rate | RR | 95% CI | Notes
STAR
Cataracts | 9726 | 9745 | 5 | 6 | 394 | 12.3 | 313 | 9.7 | 0.79 | 0.68–0.92 | Self report
Cataracts surgery | | | | | 260 | 8 | 215 | 6.6 | 0.82 | 0.68–0.99

Opthalmologic Outcomes- Tamoxifen trials

Trial Name | N | | Length of Treatment (years) | Length of FU (years) | Placebo | | Tamoxifen | | RR | 95% CI | Notes
Trial Name | Placebo | Tamoxifen | Length of Treatment (years) | Length of FU (years) | No. | Rate | No. | Rate | RR | 95% CI | Notes
Royal Marsden
Powell, 2007^26^ Cataracts | 1233 | 1238 | 8 | 13.2 | 3 | 0.18 | 12 | 0.70 | 3.99 | 1.13–14.14 | Active Treatment
Italian
Veronesi, 2007^29^ “Opthamologic diseases” | 2708 | 2700 | 5 | 11 | 118 | 11.65 | 112 | 11.39 | 0.98 | 0.75– 1.27 | Active Treatment
IBIS
Cuzick, 2007^20^: Cataracts | 3575 | 3579 | 60 months | 96 months | 34 | 1.90 | 29 | 1.63 | 0.85 | 0.52–1.40 | Active
Cataracts : Post | | | | | 20 | | 38 | | 1.92 | 1.12–3.29 | Active
Eye complaints : Active | | | | | 896 | | 901 | | 1 | 0.93–1.09 | Self report
Eye complaints: Post | | | | | 597 | | 622 | | 1.05 | 0.95–1.17
NASABP
Fisher, 2005^23^: Cataracts | 6131 | 6101 | 5 | 7 | | 22.9 | | 27.8 | 1.21 | 1.10–1.34
Cataracts surgery | | | | | | 7.58 | | 10.54 | 1.39 | 1.19–1.63
Fisher, 1998^24^: Cataracts | 6131 | 6101 | 5 | 69 months | 507 | 21.72 | 574 | 24.82 | 1.14 | 1.01–1.29
Cataracts surgery | | | | | 73 | 3 | 114 | 4.72 | 1.57 | 1.16–2.14

Opthalmologic Outcomes-Raloxifene trials

Trial Name | N | | | Length of Treatment (years) | Length of FU (years) | Placebo | | R 60 | | R 120 | | RR | 95% CI | Notes
Trial Name | Placebo | R60 | R120 | Length of Treatment (years) | Length of FU (years) | No. | Rate | No. | Rate | No. | Rate | RR | 95% CI | Notes
MORE
Grady, 2004^39^: Cataracts | 2576 | 5129 | | | 3.3 | 160 | | 291 | | | | 0.9 | 0.8–1.1 | Self report
Cataracts surgery | | | | | 3.3 | 86 | | 163 | | | | 1 | 0.7–1.2
CORE
RUTH
Barrett-Connor, 2006^46^ Cataracts | 5057 | 5044 | | | 5.6 | 391 | 13.91 | 374 | 13.34 | | | 0.96 | 0.83–1.11 | P = 0.56 Unsolicited Self report

### Gastrointestinal Disorders

Gastrointestinal Outcomes – LIFT Trial

| N | | Length of Treatment | Placebo | | Tibolone | | RR | 95% CI | Notes
| Placebo | Tibolone | Length of Treatment | No. | Rate | No. | Rate | RR | 95% CI | Notes
Gastroenteritis | 2257 | 2249 | 34 months | 87 | NR | 57 | NR | NR | NR | P<0.01

### Other Adverse Events That Impact Quality of Life

Vasomotor Outcomes-tamoxifen trials

Trial Name | N | | Length of Treatment(years) | Length of FU (years) | Placebo | | Tamoxifen | | RR | 95% CI | Notes
Trial Name | Placebo | Tamoxifen | Length of Treatment(years) | Length of FU (years) | No. | Rate | No. | Rate | RR | 95% CI | Notes
Royal Marsden
Powles, 2007^26^ Hot flashes | 1233 | 1238 | 8 | 13.2 | 394 | | 598 | | | | Active P<0.001
Post | | | | | 47 | | 73 | | | | P < 0.001
Vasomotor: Active | | | | | 96 | | 162 | | | | P < 0.001
Post | | | | | 10 | | 19 | | | | P = 0.1
Italian
Veronesi, 2007^29^ Hot flashes | 1697 | 1638 | 5 | 11.2 | 446 | 67.2 | 635 | 119.3 | 1.78 | 1.57–2.0
IBIS
Cuzick, 2007^20^ Gynecologic & vasomotor | 3566 | 3573 | 5 | 50 | 1983 | | 2389 | | 1.2 | 1.16–1.25 | Predefined categories, can’t separate gyn/vm
Gynecologic: Post | | | | | 1438 | | 1508 | | 1.06 | 0.99–1.12
NSABP
Fisher, 1998^24^ | 6707 | 6681 | 5 | 69 months | 28.70% | | 45.70% | | | | Hot flashes moderately or more bothersome

Weight Outcomes – LIFT Trial

| N | | Length of Treatment | Placebo | | Tibolone | | RR | 95% CI | Notes
| Placebo | Tibolone | Length of Treatment | No. | Rate | No. | Rate | RR | 95% CI | Notes
Weight Gain | 2121 | 2050 | 34 months | 81 | NR | 109 | NR | NR | NR | NR

### Mortality

Total Death-STAR

Trial Name | N | | Length of Treatment (years) | Length of FU (years) | Tamoxifen | | Raloxifene | | RR | 95% CI
Trial Name | Tamoxifen | Raloxifene | Length of Treatment (years) | Length of FU (years) | No. | Rate | No. | Rate | RR | 95% CI
STAR
| | | | | 101 | 2.64 | 96 | 2.49 | 0.94 | 0.71–1.26

Total Death-Tamoxifen

Trial Name | N | | Length of Treatment (years) | Length of FU (years) | Placebo | | Tamoxifen | | RR | 95% CI | Notes
Trial Name | Placebo | Tamoxifen | Length of Treatment (years) | Length of FU (years) | No. | Rate | No. | Rate | RR | 95% CI | Notes
Royal Marsden
Powles, 1998^25^: Total deaths | | | | | 9 | | 6
Powles, 1998^25^: Deaths-Breast Cancer | | | | | 5 | | 5
Powles, 2007^26^ | 1233 | 1238 | 8 | 13.2 | 54 | | 54 | | 0.99 | 0.68–1.44 | P = 0.99
Italian
Veronesi, 2007^29^ | 1697 | 1638 | 5 | 11.2 | 38 | | 36 | | 0.95 | 0.6–1.49
IBIS
Cuzick, 2002^19^ | 3566 | 3573 | 5 | 50 months | 11 | | 25 | | 1.55 | 0.68–3.65 | P=0.028
Cuzick, 2007^20^ | | | 5 | 96 months | 55 | | 65 | | 1.18 | 0.81–1.73
NSABP
Fisher, 2005^23^ | 6707 | 6681 | 5 | 7 | 114 | 2.8 | 126 | 3.08 | 1.1 | 0.85–1.43
Fisher, 1998^24^ | | | 5 | 69 months | 71 | | 57 | | 0.81 | 0.56–1.16

Total Death-Raloxifene trials

Trial Name | N | | | Length of Treatment (years) | Length of FU (years) | Placebo | | R 60 | | R 120 | | RR | 95% CI | Notes
Trial Name | Placebo | R60 | R120 | Length of Treatment (years) | Length of FU (years) | No. | Rate | No. | Rate | No. | Rate | RR | 95% CI | Notes
MORE
Barrett-Connor, 2004^31^ | 2576 | 2557 | 2572 | | 4 | 36 | | 62 | | | | 0..85 | 0.56–1.28 | Raloxifene 60 + 120mg
CORE
Martino, 2005^43^ | | | | | 4 | 29 | | 47 | | | | | | P=0.27
RUTH
Barrett-Connor, 2006^46^ | 5057 | 5044 | | 5.6 | 5.6 | 595 | | 554 | | | | 0.92 | 0.82–1.03

### Total Death

Total Death-LIFT trial

N | | Length of Treatment | Placebo | | Tibolone | | RR | 95% CI | Notes
Placebo | Tibolone | Length of Treatment | No. | Rate | No. | Rate | RR | 95% CI | Notes
2257 | 2249 | 34 m | 28 | 1.2 | 26 | 1.2 | NR | NR | p=0.89

| Raloxifene Trials | | | | | | | | | | | | Tibolone Trials
Outcome | Morii, 2003^82^ | Delmas, 1997^74^ | Cohen, 2000^73^ | McClung, 2006^80^ | Lufkin, 1998^79^ | Nickelsen, 1999^83^ | Meunier, 1999^81^ | Jolly, 2003^78^ | Goldstein, 2005^76^ | Palacios, 2004^84^ | Walsh, 1998^85^ | Johnston, 2000^77^ | Bots, 2001^89^ Langer, 2006^90^ | Landgren, 2002^91^ | Gallagher, 2001^92^ | Swanson, 2006^93^ | Hudita, 2003^94^ | Onalan, 2005^96^ | Lundstrom, 2002^95^ | Beral, 2003^98^, 2005^97^
Leg cramps | o | | | + | | | | o | | | | o
Anxiety | | | | | | | | | | | | | | | o
Depression/mood change | | | | | | o | | | | o | | | | | | | | −
Ovarian cancer
Vaginal bleeding | o | o | o | o | o | | | o | | o | o | o | + | | o | o | +, o^‡^
Urinary symptoms | | | | | | | | | o | | | | | | | −
Sexual symptoms | | | | | | | | | | | | | | | | − | −
Gynecologic | | o | | | o | | | | | | | o | o | | | o^§^ | −\|\| | | | +
Breast symptoms | o | o | | o | o | | | | o | o | o | o | | | | o | o | | o^¶^
GI symptoms | + | | | | | | | | | | | o | | o
Headaches | | | | | | | | | | | | | | o | o | o
Peripheral edema | | | | | | | | | | | | o
Weight gain | | | | | | | | | | o | + | | | | o | o
Influenza syndrome | | | | | | | | | | o | | | | | o | o
Flushing | o | o | | + | | o | o | + | | o | + | + | | − | −, o^#^ | − | −
Malaise/lethargy | +^**^ | | | | | | | | | o | | | | | | o
Pain/joint pain | | | | | + | | | | | o | | | | o | o

* Statistically significant differences between treatment and placebo groups are indicated by: + outcome increased in treatment groups; − outcome decreased in treatment groups; O no differences between treatment and placebo groups for the outcome; blank cells, outcome not reported.

‡ + at 3 months; O at 6 months

§ Uterine spasm, enlarged abdomen, genital pruritus.

|| Vaginal dryness, sexual function.

¶ Breast density, breast pain.

# - for 2.5 mg/daily; O for 0.3, 0.625, and 1.25 mg/day.

** Comparing 120 mg to placebo or 60 mg.