# List of Excluded Studies

1 Raloxifene and prevention of vertebral fracture (cont’d): mainly when oestrogen is contraindicated. Prescrire Int. 2000;9(50):190-191. Review/No data. [pmid: 11475503].
2 Summaries for patients. Using medication to prevent breast cancer: recommendations from the United States Preventive Services Task Force. Ann Intern Med. 2002;137(1):162. Review/No data.
3 Tibolone: cancers of the breast and endometrium. Prescrire Int. 2006;15(83):107. No relevant data.
4 Abramson N, Aster RH. Retrospective assessment of hypercoagulability in breast cancer prevention trial. J Clin Oncol. 2002;20(19):4133-4134. Review/No data. [pmid: 12351619].
5 Abramson N, Costantino JP, Garber JE, et al. Effect of Factor V Leiden and prothrombin G20210-->A mutations on thromboembolic risk in the national surgical adjuvant breast and bowel project breast cancer prevention trial. J Natl Cancer Inst. 2006;98(13):904-910. No relevant outcomes. [pmid: 16818854].
6 Adomaityte J, Farooq M, Qayyum R. Effect of raloxifene therapy on venous thromboembolism in postmenopausal women. A meta-analysis. Thromb Haemost. 2008;99(2):338-342. Review/No data. [pmid: 18278183].
7 Al-Delaimy WK, Cho E, Chen WY, et al. A prospective study of smoking and risk of breast cancer in young adult women. Cancer Epidemiol Biomarkers Prev. 2004;13(3):398-404. Single risk factor only. [pmid: 15006915].
8 Aldrighi JM, Quail DC, Levy-Frebault J, et al. Predictors of hot flushes in postmenopausal women who receive raloxifene therapy. Am J Obstet Gynecol. 2004;191(6):1979-1988. No relevant data. [pmid: 15592280].
9 American College of Obstetrics, Gynecologists Committee on Gynecologic Practice. ACOG committee opinion. No. 336: Tamoxifen and uterine cancer. Obstet Gynecol. 2006;107(6):1475-1478. Review/No data. [pmid: 16738185].
10 Andersson M, Storm HH, Mouridsen HT. Incidence of new primary cancers after adjuvant tamoxifen therapy and radiotherapy for early breast cancer. J Natl Cancer Inst. 1991;83(14):1013-1017. Wrong type of study. [pmid: 2072407].
11 Andrieu N, Clavel F, Auquier A, et al. Variations in the risk of breast cancer associated with a family history of breast cancer according to age at onset and reproductive factors. J Clin Epidemiol. 1993;46(9):973-980. Single risk factor only. [pmid: 8263582].
12 Andrieu N, Goldgar DE, Easton DF, et al. Pregnancies, breast-feeding, and breast cancer risk in the International BRCA1/2 Carrier Cohort Study (IBCCS). J Natl Cancer Inst. 2006;98(8):535-544. Family history only model. [pmid: 16622123].
13 Andrieu N, Prevost T, Rohan TE, et al. Variation in the interaction between familial and reproductive factors on the risk of breast cancer according to age, menopausal status, and degree of familiality. Int J Epidemiol. 2000;29(2):214-223. No relevant data. [pmid: 10817116].
14 Antoniou AC, Durocher F, Smith P, et al. BRCA1 and BRCA2 mutation predictions using the BOADICEA and BRCAPRO models and penetrance estimation in high-risk French-Canadian families. Breast Cancer Res. 2006;8(1):R3. Family history only model. [pmid: 16417652].
15 Antoniou AC, Pharoah PD, McMullan G, et al. Evidence for further breast cancer susceptibility genes in addition to BRCA1 and BRCA2 in a population-based study. Genet Epidemiol. 2001;21(1):1-18. Family history only model. [pmid: 11443730].
16 Antoniou AC, Pharoah PPD, Smith P, et al. The BOADICEA model of genetic susceptibility to breast and ovarian cancer [see comment]. Br J Cancer. 2004;91(8):1580-1590. Family history only model. [pmid: 15381934].
17 Archer DF, Hendrix S, Gallagher JC, et al. Endometrial effects of tibolone. J Clin Endocrinol Metab. 2007;92(3):911-918. Wrong type of study. [pmid: 17192288].
18 Arun B, Hortobagyi GN. Progress in breast cancer chemoprevention. Endocr Relat Cancer. 2002;9(1):15-32. No relevant data. [pmid: 11914180].
19 Ascher SM, Imaoka I, Lage JM. Tamoxifen-induced uterine abnormalities: the role of imaging. Radiology. 2000;214(1):29-38. Review/No data. [pmid: 10644098].
20 Ashing-Giwa KT, Padilla GV, Tejero JS, et al. Breast cancer survivorship in a multiethnic sample: challenges in recruitment and measurement. Cancer. 2004;101(3):450-465. Does not address key questions. [pmid: 15274058].
21 Atkins JN. The breast cancer prevention trial: a correction. JAMA. 1994;272(17):1328. Review/No data. [pmid: 7933393].
22 Bakour SH, Gupta JK, Khan KS. Risk factors associated with endometrial polyps in abnormal uterine bleeding. Int J Gynaecol Obstet. 2002;76(2):165-168. Review/No data. [pmid: 11818111].
23 Baptista MZ, Prieto VG, Chon S, et al. Tamoxifen-related vasculitis. J Clin Oncol. 2006;24(21):3504-3505. Wrong population. [pmid: 16849770].
24 Barakat RR. The effect of tamoxifen on the endometrium. Oncology. 9(2):129-134. discussion 139–140. Review/No data. [pmid: 8771096].
25 Barcenas CH, Hosain GMM, Arun B, et al. Assessing BRCA carrier probabilities in extended families. J Clin Oncol. 2006;24(3):354-360. Family history only model. [pmid: 16421416].
26 Barrett-Connor E, Wenger NK, Grady D, et al. Coronary heart disease in women, randomized clinical trials, HERS and RUTH. Maturitas. 1998;31(1):1-7. Review/No data. [pmid: 10091198].
27 Barron TI, Connolly R, Bennett K, et al. Early discontinuation of tamoxifen: a lesson for oncologists. Cancer. 2007;109(5):832-839. Wrong population. [pmid: 17243168].
28 Baum M, Houghton J, Riley D. Tamoxifen to prevent breast cancer. Lancet. 1991;338(8759):114. Review/No data. [pmid: 1676439].
29 Becher H, Schmidt S, Chang-Claude J. Reproductive factors and familial predisposition for breast cancer by age 50 years. A case-control-family study for assessing main effects and possible gene-environment interaction [see comment]. Int J Epidemiol. 2003;32(1):38-48. Family history only model. [pmid: 12690006].
30 Beckmann MW, Bani MR, Fasching PA, et al. Risk and risk assessment for breast cancer: molecular and clinical aspects. Maturitas. 2007;57(1):56-60. Family history only model. [pmid: 17386982].
31 Beiner ME, Finch A, Rosen B, et al. The risk of endometrial cancer in women with BRCA1 and BRCA2 mutations. A prospective study. Gynecol Oncol. 2007;104(1):7-10. Wrong population. [pmid: 16962648].
32 Beitler JJ. Tamoxifen and sexuality: Let’s listen to the data speak. J Clin Oncol. 1999;17(11):3689-3690. Wrong population. [pmid: 10550170].
33 Benichou J, Gail MH, Mulvihill JJ. Graphs to estimate an individualized risk of breast cancer. J Clin Oncol. 1996;14(1):103-110. No relevant data. [pmid: 8558184].
34 Berg AO. United States Preventive Services Task Force. Chemoprevention of breast cancer: recommendations and rationale. Am J Nurs. 2003;103(5):107. No relevant data.
35 Bergh J. Breast-cancer prevention: is the risk-benefit ratio in favour of tamoxifen. Lancet. 2003;362(9379):183-184. Review/No data. [pmid: 12885476].
36 Bernatsky S, Ramsey-Goldman R, Boivin J-F, et al. Do traditional Gail model risk factors account for increased breast cancer in women with lupus. J Rheumatol. 2003;30(7):1505-1507. Population not applicable. [pmid: 12858448].
37 Bernstein L, Patel AV, Ursin G, et al. Lifetime recreational exercise activity and breast cancer risk among black women and white women. J Natl Cancer Inst. 2005;97(22):1671-1679. Single risk factor only. [pmid: 16288120].
38 Bernstein L, Ross RK, Henderson BE. Prospects for the primary prevention of breast cancer. Am J Epidemiol. 1992;135(2):142-152. Review/No data. [pmid: 1311141].
39 Bevers TB. Raloxifene and the prevention of breast cancer. Expert Opin Pharmacother. 2006;7(16):2301-2307. Review/No data. [pmid: 17059385].
40 Blumenthal RS, Baranowski B, Dowsett SA. Cardiovascular effects of raloxifene: the arterial and venous systems. Am Heart J. 2004;147(5):783-789. Review/No data. [pmid: 15131531].
41 Boardman LA, Thibodeau SN, Schaid DJ, et al. Increased risk for cancer in patients with the Peutz-Jeghers syndrome. Ann Intern Med. 1998;128(11):896-899. Population not applicable. [pmid: 9634427].
42 Bober SL, Hoke LA, Duda RB, et al. Recommendation recall and satisfaction after attending breast/ovarian cancer risk counseling. J Genet Couns. 2007;16(6):755-762. No relevant outcomes. [pmid: 17674165].
43 Bondy ML, Newman LA. Assessing breast cancer risk: evolution of the Gail Model [comment]. J Natl Cancer Inst. 2006;98(17):1172-1173. No relevant data. [pmid: 16954464].
44 Bordeleau LJ, Lipa JE, Neligan PC. Management of the BRCA mutation carrier or high-risk patient. Clin Plast Surg. 2007;34(1):15-27. Family history only model. [pmid: 17307068].
45 Boss SM, Huster WJ, Neild JA, et al. Effects of raloxifene hydrochloride on the endometrium of postmenopausal women. Am J Obstet Gynecol. 1997;177(6):1458-1464. Review/No data. [pmid: 9423751].
46 Boyapati SM, Shu XO, Jin F, et al. Dietary calcium intake and breast cancer risk among Chinese women in Shanghai. Nutr Cancer. 2003;46(1):38-43. Single risk factor only. [pmid: 12925302].
47 Bradbury BD, Lash TL, Kaye JA, et al. Tamoxifen-treated breast carcinoma patients and the risk of acute myocardial infarction and newly-diagnosed angina. Cancer. 2005;103(6):1114-1121. Wrong population. [pmid: 15712362].
48 Bradbury J. CORE breast-cancer prevention trial. Lancet Oncol. 2005;6(1):8. Review/No data. [pmid: 15672490].
49 Bremnes Y, Ursin G, Bjurstam N, et al. Different measures of smoking exposure and mammographic density in postmenopausal Norwegian women: a cross-sectional study. Breast Cancer Res. 2007;9(5):R73. Single risk factor only. [pmid: 17963507].
50 Brenner DE. Cancer chemoprevention. Crit Rev Oncol Hematol. 2000;33(3):155-156. Review/No data. [pmid: 10789489].
51 Brewster AM, Christo DK, Lai H, et al. Breast carcinoma chemoprevention in the community setting. Estimating risks and benefits. Cancer. 2005;103(6):1147-1153. No relevant outcomes. [pmid: 15674856].
52 Brinker A, Beitz J. Spontaneous reports of pulmonary embolism in association with raloxifene. Obstet Gynecol. 2001;98(6):1151. Review/No data. [pmid: 11755578].
53 Brown K. Breast cancer chemoprevention: risk-benefit effects of the antioestrogen tamoxifen. Expert Opin Drug Saf. 2002;1(3):253-267. Review/No data. [pmid: 12904141].
54 Brown P. Risk assessment: controversies and management of moderate- to high-risk individuals. Breast J. 2005;11(Suppl 1):S11-19. No relevant data. [pmid: 15725110].
55 Bush TL, Blumenthal R, Lobo R, et al. SERMs and cardiovascular disease in women. How do these agents affect risk?. Postgrad Med. 2001;(Spec No: 17–24). Review/No data.
56 Bushnell C. The cerebrovascular risks associated with tamoxifen use. Expert Opin Drug Saf. 2005;4(3):501-507. Review/No data. [pmid: 15934856].
57 Bushnell CD, Goldstein LB. Risk of ischemic stroke with tamoxifen treatment for breast cancer: a meta-analysis. Neurology. 2004;63(7):1230-1233. Review/No data. [pmid: 15477543].
58 Byrne C, Rockett H, Holmes MD. Dietary fat, fat subtypes, and breast cancer risk: lack of an association among postmenopausal women with no history of benign breast disease. Cancer Epidemiol Biomarkers Prev. 2002;11(3):261-265. Single risk factor only. [pmid: 11895875].
59 Byrne C, Schairer C, Brinton LA, et al. Effects of mammographic density and benign breast disease on breast cancer risk (United States). Cancer Causes Control. 2001;12(2):103-110. Single risk factor only. [pmid: 11246838].
60 Calle EE, Rodriguez C, Walker KA, et al. Tubal sterilization and risk of breast cancer mortality in US women. Cancer Causes Control. 2001;12(2):127-135. Single risk factor only. [pmid: 11246841].
61 Cattaneo M, Baglietto L, Zighetti ML, et al. Tamoxifen reduces plasma homocysteine levels in healthy women. Br J Cancer. 1998;77(12):2264-2266. Wrong type of study. [pmid: 9649143].
62 Cersosimo RJ. Tamoxifen for prevention of breast cancer. Ann Pharmacother. 2003;37(2):268-273. Review/No data. [pmid: 12549959].
63 Chan K, Morris GJ. Chemoprevention of breast cancer for women at high risk. Semin Oncol. 2006;33(6):642-646. Review/No data. [pmid: 17145342].
64 Chang J, Powles TJ, Ashley SE, et al. The effect of tamoxifen and hormone replacement therapy on serum cholesterol, bone mineral density and coagulation factors in healthy postmenopausal women participating in a randomised, controlled tamoxifen prevention study. Ann Oncol. 1996;7(7):671-675. Wrong drugs. [pmid: 8905024].
65 Chen WY, Colditz GA. Risk factors and hormone-receptor status: epidemiology, risk-prediction models and treatment implications for breast cancer. Nat Clin Pract Oncol. 2007;4(7):415-423. No relevant data. [pmid: 17597706].
66 Chiechi LM, Secreto G. Breast cancer and replacement therapy: which women are at risk. Clin Exp Obstet Gynecol. 1999;26(2):105-108. Single risk factor only. [pmid: 10459451].
67 Chittacharoen A, Theppisai U, Manonai J. Transvaginal color Doppler sonographic evaluation of the uterus in postmenopausal women on daily raloxifene therapy. Climacteric. 2002;5(2):156-159. Wrong type of study. [pmid: 12051111].
68 Chlebowski RT, Col N, Winer EP, et al. American Society of Clinical Oncology technology assessment of pharmacologic interventions for breast cancer risk reduction including tamoxifen, raloxifene, and aromatase inhibition. J Clin Oncol. 2002;20(15):3328-3343. Review/No data. [pmid: 12149307].
69 Chlebowski RT, Collyar DE, Somerfield MR, et al. American Society of Clinical Oncology technology assessment on breast cancer risk reduction strategies: tamoxifen and raloxifene. J Clin Oncol. 1999;17(6):1939-1955. Review/No data. [pmid: 10561236].
70 Chlebowski RT, Geller ML. Adherence to endocrine therapy for breast cancer. Oncology. 2006;71:1-2. 1. 9. Wrong population. [pmid: 17344666].
71 Chlebowski RT, Prentice R. Tibolone in older postmenopausal women. N Engl J Med. 2008;359(20):2172-2173. author reply 2173. No data. [pmid: 19005202].
72 Chow CK, Venzon D, Jones EC, et al. Effect of tamoxifen on mammographic density. Cancer Epidemiol Biomarkers Prev. 2000;9(9):917-921. Wrong drugs. [pmid: 11008909].
73 Cittadini J, Ben J, Badano AR, et al. Use of a new steroid (Org OD 14) in the climacteric syndrome. Reproduccion. 1982;6(2):69-79. Not english. [pmid: 6814971].
74 Clamp A, Danson S, Clemons M. Hormonal risk factors for breast cancer: identification, chemoprevention, and other intervention strategies. Lancet Oncol. 2002;3(10):611-619. Review/No data. [pmid: 12372723].
75 Clamp A, Danson S, Clemons M. Hormonal and genetic risk factors for breast cancer. Surg. 2003;1(1):23-31. No relevant data.
76 Clarkson TB. Does tibolone exacerbate atherosclerosis. Eur Heart J. 2006;27:635-637. Editorial/No data. [pmid: 16415302].
77 Claus EB. Risk models used to counsel women for breast and ovarian cancer: a guide for clinicians. Fam Cancer. 2001;1:3-4. 197. 206. No relevant data. [pmid: 14574009].
78 Claus EB, Stowe M, Carter D, et al. The risk of a contralateral breast cancer among women diagnosed with ductal and lobular breast carcinoma in situ: data from the Connecticut Tumor Registry. Breast. 2003;12(6):451-456. Does not address key questions. [pmid: 14659121].
79 Cohen I. Benign gynecologic conditions in tamoxifen-treated patients. Am J Obstet Gynecol. 2006;194(4):1204-1205. author reply 1205. Review/No data. [pmid: 16580343].
80 Collins LC, Baer HJ, Tamimi RM, et al. The influence of family history on breast cancer risk in women with biopsy-confirmed benign breast disease: results from the Nurses’ Health Study. Cancer. 2006;107(6):1240-1247. Family history only model. [pmid: 16902983].
81 Costa A, Sacchini V, Decensi A. Retinoids and tamoxifen in breast cancer chemoprevention. Int J Clin Lab Res. 1993;23(2):53-55. Review/No data. [pmid: 8518414].
82 Couch FJ, Cerhan JR, Vierkant RA, et al. Cigarette smoking increases risk for breast cancer in high-risk breast cancer families. Cancer Epidemiol Biomarkers Prev. 2001;10(4):327-332. Single risk factor only. [pmid: 11319172].
83 Crabbe WW. The tamoxifen controversy. Oncol Nurs Forum. 1996;23(5):761-766. No relevant outcomes. [pmid: 8792346].
84 Crona N, Samsioe G, Lindberg UB, et al. Treatment of climacteric complaints with Org OD 14: a comparative study with oestradiol valerate and placebo. Maturitas. 1988;9(4):303-308. Trial N too small. [pmid: 3288845].
85 Crowell EB Jr, Jubelirer SJ. Breast cancer risks and prevention: implications of the Breast Cancer Prevention Trial results. W V Med J. 2000;96(6):598-601. No relevant data. [pmid: 11194088].
86 Cui Y, Miller AB, Rohan TE. Cigarette smoking and breast cancer risk: update of a prospective cohort study. Breast Cancer Res Treat. 2006;100(3):293-299. Single risk factor only. [pmid: 16773435].
87 Culver J, Lowstuter K, Bowling L. Assessing breast cancer risk and BRCA1/2 carrier probability. Breast Dis. 2006;27:5-20. Family history only model. [pmid: 17917138].
88 Cummings SR. Primary prevention of breast cancer: new approaches. Maturitas. 2007;57(1):39-41. Review/No data. [pmid: 17391879].
89 Curtis MG. Comparative tolerability of first-generation selective estrogen receptor modulators in breast cancer treatment and prevention. Drug Saf. 2001;24(14):1039-1053. Review/No data. [pmid: 11735660].
90 Cuzick J. A brief review of the current breast cancer prevention trials and proposals for future trials. Eur J Cancer. 2000;36(10):1298-1302. No relevant data. [pmid: 10882870].
91 Cykert S, Phifer N, Hansen C. Tamoxifen for breast cancer prevention: a framework for clinical decisions. Obstet Gynecol. 2004;104(3):433-442. No relevant outcomes. [pmid: 15339751].
92 da Silva BB, Lopes IM, Gebrim LH. Effects of raloxifene on normal breast tissue from premenopausal women. Breast Cancer Res Treat. 2006;95(2):99-103. Review/No data. [pmid: 16205837].
93 de Bock GH, Jacobi CE, Jonker MA, et al. A breast cancer prediction model. Stat Med. 2005;24(10):1610-1612. author reply 1612. No relevant data. [pmid: 15880578].
94 De Leo V, la Marca A, Morgante G, et al. Randomized control study of the effects of raloxifene on serum lipids and homocysteine in older women. Am J Obstet Gynecol. 2001;184(3):350-353. Trial N too small. [pmid: 11228485].
95 de Lima GR, Facina G, Shida JY, et al. Effects of low dose tamoxifen on normal breast tissue from premenopausal women. Eur J Cancer. 1990;39(7):891-898. Trial N too small. [pmid: 12706357].
96 de Valk-de Roo GW, Stehouwer CD, Meijer P, et al. Both raloxifene and estrogen reduce major cardiovascular risk factors in healthy postmenopausal women: A 2-year, placebo-controlled study. Arterioscler Thromb Vasc Biol. 1999;19(12):2993-3000. Trial N too small. [pmid: 10591680].
97 Decensi A, Robertson C, Ballardini B, et al. Effect of tamoxifen on lipoprotein(a) and insulin-like growth factor-I (IGF-I) in healthy women. Eur J Cancer. 1999;35(4):596-600. Wrong type of study. [pmid: 10492633].
98 Delmas PD, Davis SR, Hensen J, et al. Effects of tibolone and raloxifene on bone mineral density in osteopenic postmenopausal women. Osteoporos Int. 2008;19(8):1153-1160. No placebo. [pmid: 18256777].
99 DeMichele A, Troxel AB, Berlin JA, et al. Impact of raloxifene or tamoxifen use on endometrial cancer risk: a population-based case-control study. J Clin Oncol. 2008;26(25):4151-4159. Wrong population. [pmid: 18757329].
100 Dias AR Jr, de Mello NR, Eluf Gebara OC, et al. Conjugated equine estrogen, raloxifene and arterial stiffness in postmenopausal women. Climacteric. 2008;11(5):390-396. Review/No data. [pmid: 18781483].
101 Dibble SL, Roberts SA, Nussey B. Comparing breast cancer risk between lesbians and their heterosexual sisters. Womens Health Issues. 2004;14(2):60-68. Single risk factor only. [pmid: 15120415].
102 Dignam JJ, Fisher B. Occurrence of stroke with tamoxifen in NSABP B-24. Lancet. 2000;355(9206):848-849. Wrong population. [pmid: 10711957].
103 Centre for Reviews and Dissemination. Chemoprevention of breast cancer: a joint guideline from the Canadian Task Force on Preventive Health Care and the Canadian Breast Cancer Initiative’s Steering Committee on Clinical Practice Guidelines for the Care and Treatment of Breast Cancer (Structured abstract). Database of Abstracts of Reviews of Effects. 2008;(3). Review/No data.
104 Domchek SM, Eisen A, Calzone K, et al. Application of breast cancer risk prediction models in clinical practice. J Clin Oncol. 2003;21(4):593-601. Does not address key questions. [pmid: 12586794].
105 Doren M, Rubig A, Coelingh Bennink HJ, et al. Resistance of pelvic arteries and plasma lipids in postmenopausal women: comparative study of tibolone and continuous combined estradiol and norethindrone acetate replacement therapy. Am J Obstet Gynecol. 2000;183(3):575-582. Wrong type of study. [pmid: 10992176].
106 Doren M, Rubig A, Coelingh Bennink HJ, et al. Differential effects on the androgen status of postmenopausal women treated with tibolone and continuous combined estradiol and norethindrone acetate replacement therapy. Fertil Steril. 2001;75(3):554-559. Wrong type of study. [pmid: 11239541].
107 Draper MW, Flowers DE, Huster WJ, et al. A controlled trial of raloxifene (LY139481) HCl: impact on bone turnover and serum lipid profile in healthy postmenopausal women. J Bone Miner Res. 1996;11(6):835-842. Trial N too small. [pmid: 8725181].
108 Eilertsen AL, Sandvik L, Steinsvik B, et al. Differential impact of conventional-dose and low-dose postmenopausal hormone therapy, tibolone and raloxifene on C-reactive protein and other inflammatory markers. J Thromb Haemost. 2008;6(6):928-934. No placebo. [pmid: 18394014].
109 Eliassen AH, Missmer SA, Tworoger SS, et al. Endogenous steroid hormone concentrations and risk of breast cancer: does the association vary by a woman’s predicted breast cancer risk. J Clin Oncol. 2006;24(12):1823-1830. Single risk factor only. [pmid: 16567770].
110 Eng-Wong J, Hursting SD, Venzon D, et al. Effect of raloxifene on insulin-like growth factor-I, insulin-like growth factor binding protein-3, and leptin in premenopausal women at high risk for developing breast cancer. Cancer Epidemiol Biomarkers Prev. 2003;12(12):1468-1473. Wrong type of study. [pmid: 14693739].
111 Eng-Wong J, Orzano-Birgani J, Chow CK, et al. Effect of raloxifene on mammographic density and breast magnetic resonance imaging in premenopausal women at increased risk for breast cancer. Cancer Epidemiol Biomarkers Prev. 2008;17(7):1696-1701. Trial N too small. [pmid: 18583470].
112 Eng-Wong J, Reynolds JC, Venzon D, et al. Effect of raloxifene on bone mineral density in premenopausal women at increased risk of breast cancer. J Clin Endocrinol Metab. 2006;91(10):3941-3946. Wrong type of study. [pmid: 16868059].
113 Esserman LJ, Ozanne EM, Dowsett M, et al. Tamoxifen may prevent both ER+ and ER− breast cancers and select for ER- carcinogenesis: an alternative hypothesis. Breast Cancer Res. 2005;7(6):R1153-1158. Review/No data. [pmid: 16457695].
114 Euhus DM. Understanding mathematical models for breast cancer risk assessment and counseling. Breast J. 2001;7(4):224-232. Population not applicable. [pmid: 11678799].
115 Euhus DM, Leitch AM, Huth JF, et al. Limitations of the Gail model in the specialized breast cancer risk assessment clinic. Breast J. 2002;8(1):23-27. No relevant data. [pmid: 11856157].
116 Evans DGR, Howell A. Breast cancer risk-assessment models. Breast Cancer Res. 2007;9(5):213. No relevant data. [pmid: 17888188].
117 Fabian CJ, Kimler BF. Use of biomarkers for breast cancer risk assessment and prevention. J Steroid Biochem Mol Biol. 2007;106:1-5. 31. 39. Single risk factor only. [pmid: 18027398].
118 Fasching PA, Bani MR, Nestle-Kramling C, et al. Evaluation of mathematical models for breast cancer risk assessment in routine clinical use. Eur J Cancer Prev. 2007;16(3):216-224. No relevant data. [pmid: 17415092].
119 Faupel-Badger JM, Prindiville SA, Venzon D, et al. Effects of raloxifene on circulating prolactin and estradiol levels in premenopausal women at high risk for developing breast cancer. Cancer Epidemiol Biomarkers Prev. 2006;15(6):1153-1158. Trial N too small. [pmid: 16775175].
120 Feigelson HS, Jonas CR, Teras LR, et al. Weight gain, body mass index, hormone replacement therapy, and postmenopausal breast cancer in a large prospective study [see comment]. Cancer Epidemiol Biomarkers Prev. 2004;13(2):220-224. Single risk factor only. [pmid: 14973094].
121 Finelli PF. Thrombosis of the cerebral veins and sinuses. N Engl J Med. 2005;353(3):314-315. Review/No data. [pmid: 16038058].
122 Fisher B, Costantino JP, Redmond CK, et al. Endometrial cancer in tamoxifen-treated breast cancer patients: findings from the National Surgical Adjuvant Breast and Bowel Project (NSABP) B-14. J Natl Cancer Inst. 1994;86(7):527-537. Wrong population. [pmid: 8133536].
123 Freedman AN, Seminara D, Gail MH, et al. Cancer risk prediction models: a workshop on development, evaluation, and application. J Natl Cancer Inst. 2005;97(10):715-723. No relevant data. [pmid: 15900041].
124 Fugere P, Scheele WH, Srikanth KR, et al. Raloxifene does not stimulate the uterus in postmenopausal women as compared to continuous combined hormone replacement therapy following 24 months of treatment. Fertil Steril. 1999;72:S182-183. No relevant outcomes.
125 Fugh-Berman A, Epstein S. Should healthy women take tamoxifen. N Engl J Med. 1992;327(22):1596-1597. Review/No data. [pmid: 1435889].
126 Furberg A-S, Veierod MB, Wilsgaard T, et al. Serum high-density lipoprotein cholesterol, metabolic profile, and breast cancer risk. J Natl Cancer Inst. 2004;96(15):1152-1160. No relevant data. [pmid: 15292387].
127 Gail MH. The estimation and use of absolute risk for weighing the risks and benefits of selective estrogen receptor modulators for preventing breast cancer. Ann N Y Acad Sci. 2001;949:286-291. Does not address key questions. [pmid: 11795364].
128 Gail MH, Anderson WF, Garcia-Closas M, et al. Absolute risk models for subtypes of breast cancer. J Natl Cancer Inst. 2007;99(22):1657-1659. No relevant data. [pmid: 18000214].
129 Gail MH, Costantino JP, Bryant J, et al. Weighing the risks and benefits of tamoxifen treatment for preventing breast cancer [erratum appears in J Natl Cancer Inst 2000 Feb 2;92(3):275]. J Natl Cancer Inst. 1999;91(21):1829-1846. Review/No data. [pmid: 10547390].
130 Gail MH, Greene MH. Gail model and breast cancer. Lancet. 2000;355:1017. No relevant data. [pmid: 10768462].
131 Ganz PA. Impact of tamoxifen adjuvant therapy on symptoms, functioning, and quality of life. J Natl Cancer Inst Monogr. 2001:130-134. Review/No data. [pmid: 11773306].
132 Ganz PA, Day R, Costantino J. Compliance with quality of life data collection in the National Surgical Adjuvant Breast and Bowel Project (NSABP) Breast Cancer Prevention Trial. Stat Med. 1998;17:5-7. 613. 622. Review/No data.
133 Ganz PA, Land SR. Risks, benefits, and effects on quality of life of selective estrogen-receptor modulator therapy in postmenopausal women at increased risk of breast cancer. Menopause. 2008;15:797-803. Review/No data. [pmid: 18596601].
134 Ganz PA, Land SR, Wickerham DL, et al. The study of tamoxifen and raloxifene (STAR): First report of patient-reported outcomes (PROs) from the NSABP P-2 Breast Cancer Prevention Study. J Clin Oncol. 2006;24(18 Suppl):18s. Review/No data.
135 Garnero P, Jamin C, Benhamou CL, et al. Effects of tibolone and combined 17beta-estradiol and norethisterone acetate on serum C-reactive protein in healthy post-menopausal women: a randomized trial. Hum Reprod. 2002;17(10):2748-2753. Wrong type of study. [pmid: 12351557].
136 Geiger AM, Fischberg GM, Chen W, et al. Stroke risk and tamoxifen therapy for breast cancer. J Natl Cancer Inst. 2004;96(20):1528-1536. Wrong population. [pmid: 15494603].
137 Genazzani AR, Petraglia F, Facchinetti F, et al. Effects of Org OD 14 on pituitary and peripheral beta-endorphin in castrated rats and post-menopausal women. Maturitas. 1987;(Suppl 1):35-48. Trial N too small. [pmid: 2957569].
138 Gluck O, Maricic M. Raloxifene: recent information on skeletal and non-skeletal effects. Curr Opin Rheumatol. 2002;14(4):429-432. Review/No data. [pmid: 12118180].
139 Goldstein SR. The effect of SERMs on the endometrium. Ann N Y Acad Sci. 2001;949:237-242. Review/No data. [pmid: 11795358].
140 Goldstein SR. An update on non-uterine gynaecological effects on raloxifene. Eur J Cancer. 2002;38(Suppl 6):S65-66. Review/No data. [pmid: 12409080].
141 Gorin SS, Wang C, Raich P, et al. Decision making in cancer primary prevention and chemoprevention. Ann Behav Med. 2006;32(3):179-187. No relevant data. [pmid: 17107290].
142 Grabrick DM, Hartmann LC, Cerhan JR, et al. Risk of breast cancer with oral contraceptive use in women with a family history of breast cancer. JAMA. 2000;284(14):1791-1798. Single risk factor only. [pmid: 11025831].
143 Grainger DJ, Schofield PM. Tamoxifen for the prevention of myocardial infarction in humans: preclinical and early clinical evidence. Circulation. 2005;112(19):3018-3024. Review/No data. [pmid: 16275887].
144 Grann VR, Jacobson JS, Troxel AB, et al. Barriers to minority participation in breast carcinoma prevention trials. Cancer. 2005;104(2):374-379. Does not address key questions. [pmid: 15937913].
145 Grey AB, Stapleton JP, Evans MC, et al. The effect of the anti-estrogen tamoxifen on cardiovascular risk factors in normal postmenopausal women. J Clin Endocrinol Metab. 1995;80(11):3191-3195. No relevant outcomes. [pmid: 7593425].
146 Gronwald J, Byrski T, Huzarski T, et al. A survey of preventive measures among BRCA1 mutation carriers from Poland. Clin Genet. 2007;71(2):153-157. No relevant outcomes. [pmid: 17250664].
147 Guerrieri-Gonzaga A, Robertson C, Bonanni B, et al. Preliminary results on safety and activity of a randomized, double-blind, 2 × 2 trial of low-dose tamoxifen and fenretinide for breast cancer prevention in premenopausal women [erratum appears in J Clin Oncol 2006 Jul 1;24(19):3221 Note: Formelli, Franca [added]]. J Clin Oncol. 2006;24(1):129-135. Wrong population. [pmid: 16382122].
148 Hammar M, Christau S, Nathorst-Boos J, et al. A double-blind, randomised trial comparing the effects of tibolone and continuous combined hormone replacement therapy in postmenopausal women with menopausal symptoms. Br J Obstet Gynaecol. 1998;105(8):904-911. Wrong type of study. [pmid: 9746385].
149 Hansdottir H. Raloxifene for older women: a review of the literature. Clin Interv Aging. 2008;3(1):45-50. Review/No data. [pmid: 18488877].
150 Hendrick A, Subramanian VP. Tamoxifen and thromboembolism. JAMA. 1980;243(6):514-515. Wrong population. [pmid: 7351776].
151 Herrington DM, Klein KP. Effects of SERMs on important indicators of cardiovascular health: lipoproteins, hemostatic factors, and endothelial function. Womens Health Issues. 2001;11(2):95-102. Review/No data. [pmid: 11275512].
152 Hofvind S, Moller B, Thoresen S, et al. Use of hormone therapy and risk of breast cancer detected at screening and between mammographic screens. Int J Cancer. 2006;118(12):3112-3117. Single risk factor only. [pmid: 16395702].
153 Hollingsworth AB, Singletary SE, Morrow M, et al. Current comprehensive assessment and management of women at increased risk for breast cancer. Am J Surg. 2004;187(3):349-362. No relevant data. [pmid: 15006563].
154 Howell A. The endocrine prevention of breast cancer. Baillieres Best Pract Res Clin Endocrinol Metab. 2008;22(4):615-623. Review/No data.
155 Ingle JN. Tamoxifen and endometrial cancer: new challenges for an “old” drug. Gynecol Oncol. 1994;55(2):161-163. Review/No data. [pmid: 7959277].
156 Isaacs C. Venous thromboembolic disease and stroke in women taking tamoxifen for breast cancer chemoprevention. Clin Adv Hematol Oncol. 2005;3(12):913-914. Review/No data. [pmid: 16555431].
157 Iversen ES Jr, Katki HA, Chen S, et al. Limited family structure and breast cancer risk. JAMA. 2007;298(17). No relevant data.
158 Jonker MA, Jacobi CE, Hoogendoorn WE, et al. Modeling familial clustered breast cancer using published data. Cancer Epidemiol Biomarkers Prev. 2003;12(12):1479-1485. Family history only model. [pmid: 14693741].
159 Jordan VC. Optimising endocrine approaches for the chemoprevention of breast cancer beyond the Study of Tamoxifen and Raloxifene (STAR) trial. Eur J Cancer. 2006;42(17):2909-2913. Review/No data. [pmid: 17064889].
160 Jordan VC. SERMs: meeting the promise of multifunctional medicines. J Natl Cancer Inst. 2007;99(5):350-356. Review/No data. [pmid: 17341726].
161 Juraskova I, Butow P, Lopez A, et al. Improving informed consent: pilot of a decision aid for women invited to participate in a breast cancer prevention trial (IBIS-II DCIS). Health Expect. 2008;11(3):252-262. Wrong Population. [pmid: 18816321].
162 Kaaks R, Berrino F, Key T, et al. Serum sex steroids in premenopausal women and breast cancer risk within the European Prospective Investigation into Cancer and Nutrition (EPIC). J Natl Cancer Inst. 2005;97(10):755-765. Single risk factor only. [pmid: 15900045].
163 Kardinal CG, Veith R. Prevention of breast cancer in high-risk women. J La State Med Soc. 1999;151(4):198-201. No relevant data. [pmid: 10234895].
164 Kaur JS, Roubidoux MA, Sloan J, et al. Can the Gail model be useful in American Indian and Alaska Native populations. Cancer. 2004;100(5):906-912. No relevant data. [pmid: 14983484].
165 Kerlikowske K, Ichikawa L, Miglioretti DL, et al. Longitudinal measurement of clinical mammographic breast density to improve estimation of breast cancer risk. J Natl Cancer Inst. 2007;99(5):386-395. Single risk factor only. [pmid: 17341730].
166 Kessel B, Nachtigall L, Plouffe L, et al. Effect of raloxifene on sexual function in postmenopausal women. Climacteric. 2003;6(3):248-256. No relevant outcomes. [pmid: 14567773].
167 Key TJ, Appleby PN, Reeves GK, et al. Body mass index, serum sex hormones, and breast cancer risk in postmenopausal women. J Natl Cancer Inst. 2003;95(16):1218-1226. Single risk factor only. [pmid: 12928347].
168 Keyzer JF, Melnikow J, Kuppermann M, et al. Recruitment strategies for minority participation: challenges and cost lessons from the POWER interview. Ethn Dis. 2005;15(3):395-406. No relevant outcomes. [pmid: 16108298].
169 Kimya Y, Cengiz C, Tolunay S. Endometrial polyps, cystic glandular hyperplasia and atypical leiomyoma associated with tamoxifen therapy. Int J Gynaecol Obstet. 1994;46(1):69-70. Review/No data. [pmid: 7805990].
170 King MC, Wieand S, Hale K, et al. Tamoxifen and breast cancer incidence among women with inherited mutations in BRCA1 and BRCA2: National Surgical Adjuvant Breast and Bowel Project (NSABP-P1) Breast Cancer Prevention Trial. JAMA. 2001;286(18):2251-2256. Wrong population. [pmid: 11710890].
171 Kinsinger LS, Harris R. Chemoprevention of breast cancer: a promising idea with an uncertain future. Lancet. 2002;360(9336):813-814. Review/No data. [pmid: 12243912].
172 Kinsinger LS, Harris R, Woolf SH, et al. Chemoprevention of breast cancer: a summary of the evidence for the U.S. Preventive Services Task Force [summary for patients in Ann Intern Med 2002 Jul 2;137(1):I62;PMID: 12093267]. Ann Intern Med. 2002;137(1):59-69. Review/No data. [pmid: 12093250].
173 Koh KK, Ahn JY, Jin DK, et al. Significant differential effects of hormone therapy or tibolone on markers of cardiovascular disease in postmenopausal women: a randomized, double-blind, placebo-controlled, crossover study. Arterioscler Thromb Vasc Biol. 2003;23(10):1889-1894. Wrong type of study. [pmid: 12933531].
174 Komi J, Lankinen KS, Harkonen P, et al. Effects of ospemifene and raloxifene on hormonal status, lipids, genital tract, and tolerability in postmenopausal women. Menopause. 2005;12(2):202-209. Wrong type of study. [pmid: 15772568].
175 Kopans DB. Basic physics and doubts about relationship between mammographically determined tissue density and breast cancer risk. Radiology. 2008;246(2):348-353. Does not address key questions. [pmid: 18227535].
176 Kramer R, Brown P. Should tamoxifen be used in breast cancer prevention. Drug Saf. 2004;27(13):979-989. Review/No data. [pmid: 15471505].
177 Kulacoglu DN, Costantino J, Demirci FY, et al. Tamoxifen and retinal vaso-occlusive disease. Invest Ophthalmol Vis Sci. 2004;45(5269). Review/No data.
178 Kuller LH. Recruitment strategies for a possible tamoxifen trial. Prev Med. 1991;20(1):119-124. No relevant data. [pmid: 1901168].
179 Laan E, van Lunsen RH, Everaerd W. The effects of tibolone on vaginal blood flow, sexual desire and arousability in postmenopausal women. Climacteric. 2001;4(1):28-41. Trial N too small. [pmid: 11379375].
180 Lamont EB, Christakis NA, Lauderdale DS. Favorable cardiac risk among elderly breast carcinoma survivors. Cancer. 2003;98(1):2-10. Wrong population. [pmid: 12833448].
181 Lavie O, Barnett-Griness O, Narod SA, et al. The risk of developing uterine sarcoma after tamoxifen use. Int J Gynecol Cancer. 2008;18(2):352-356. Wrong population. [pmid: 18334013].
182 Lee W-L, Chao H-T, Cheng M-H, et al. Rationale for using raloxifene to prevent both osteoporosis and breast cancer in postmenopausal women. Maturitas. 2008;60(2):92-107. Review/No data. [pmid: 18534794].
183 Leo L, Tessarolo M, Febo G, et al. Tamoxifen and endometrial cancer: new data for an old problem. Review Eur J Gynaecol Oncol. 1997;18(5):429-433. Review/No data. [pmid: 9378170].
184 Levine M, Moutquin JM, Walton R, et al. Chemoprevention of breast cancer. A joint guideline from the Canadian Task Force on Preventive Health Care and the Canadian Breast Cancer Initiative’s Steering Committee on Clinical Practice Guidelines for the Care and Treatment of Breast Cancer. CMAJ. 2001;164(12):1681-1690. Review/No data. [pmid: 11450210].
185 Lewis CL, Kinsinger LS, Harris RP, et al. Breast cancer risk in primary care: implications for chemoprevention. Arch of Intern Med. 2004;164(17):1897-1903. Review/No data. [pmid: 15451765].
186 Liao JB, Lin JY. Estrogen receptor expression in an endometrial stromal sarcoma after tamoxifen therapy. Eur J Gynaecol Oncol. 2001;22(6):417-419. Wrong type of study. [pmid: 11874071].
187 Lloyd G, McGing E, Cooper A, et al. A randomised placebo controlled trial of the effects of tibolone on blood pressure and lipids in hypertensive women. J Hum Hypertens. 2000;14(2):99-104. Trial N too small. [pmid: 10723115].
188 Lo SS, Vogel VG. Endocrine prevention of breast cancer using selective oestrogen receptor modulators (SORMs). Baillieres Best Pract Res Clin Endocrinol Metab. 2004;18(1):97-111. No relevant data.
189 Love RR. Tamoxifen chemoprevention: public health goals, toxicities for all and benefits to a few. Ann Oncol. 1995;6(2):127-128. Review/No data. [pmid: 7786819].
190 Love RR, Cameron L, Connell BL, et al. Symptoms associated with tamoxifen treatment in postmenopausal women. Arch Intern Med. 1991;151(9):1842-1847. Review/No data. [pmid: 1888251].
191 MacKarem G, Roche CA, Hughes KS. The effectiveness of the Gail model in estimating risk for development of breast cancer in women under 40 years of age. Breast J. 2001;7(1):34-39. No relevant data. [pmid: 11348413].
192 Mandeville R, Houde M. Tamoxifen and breast cancer prevention: are we aware of the risks. Cancer Prev Control. 1997;1(1):66-72. Review/No data. [pmid: 9765729].
193 Mannucci PM, Bettega D, Chantarangkul V, et al. Effect of tamoxifen on measurements of hemostasis in healthy women. Arch Intern Med. 1996;156(16):1806-1810. Wrong type of study. [pmid: 8790074].
194 Maricic M, Gluck O. Review of raloxifene and its clinical applications in osteoporosis. Expert Opin Pharmacother. 2002;3(6):767-775. No relevant data. [pmid: 12036416].
195 Martino S, Costantino J, McNabb M, et al. The role of selective estrogen receptor modulators in the prevention of breast cancer: comparison of the clinical trials. Oncologist. 2004;9(2):116-125. Review/No data. [pmid: 15047916].
196 Masjuan J, Pardo J, Callejo JM, et al. Tamoxifen: a new risk factor for cerebral sinus thrombosis. Neurology. 2004;62(2):334-335. Wrong population. [pmid: 14745086].
197 Maucort-Boulch D, Roy P. Modeling the effect of tamoxifen chemoprevention on long-term mortality in white women at high risk of breast cancer. Eur J Cancer Prev. 2006;15(4):347-352. Review/No data. [pmid: 16835505].
198 McDonald CC, Alexander FE, Whyte BW, et al. Cardiac and vascular morbidity in women receiving adjuvant tamoxifen for breast cancer in a randomised trial. The Scottish Cancer Trials Breast Group BMJ. 1995;311(7011):977-980. Wrong population. [pmid: 7580638].
199 McDonald CC, Stewart HJ. Fatal myocardial infarction in the Scottish adjuvant tamoxifen trial. The Scottish Breast Cancer Committee BMJ. 1991;303(6800):435-437. Wrong population. [pmid: 1912833].
200 McTiernan A, Gilligan MA, Redmond C. Assessing individual risk for breast cancer: risky business. J Clin Epidemiol. 1997;50(5):547-556. No relevant data. [pmid: 9180647].
201 McTiernan A, Kuniyuki A, Yasui Y, et al. Comparisons of two breast cancer risk estimates in women with a family history of breast cancer. Cancer Epidemiol Biomarkers Prev. 2001;10(4):333-338. Does not address key questions. [pmid: 11319173].
202 Melnikow J, Kuenneth C, Helms LJ, et al. Chemoprevention: drug pricing and mortality: the case of tamoxifen. Cancer. 2006;107(5):950-958. Review/No data. [pmid: 16865680].
203 Meyer MA. Cerebral sinus thrombosis with tamoxifen. Neurology. 2001;57(11):2150. Review/No data. [pmid: 11739856].
204 Mijatovic V, Netelenbos C, van der Mooren MJ, et al. Randomized, double-blind, placebo-controlled study of the effects of raloxifene and conjugated equine estrogen on plasma homocysteine levels in healthy postmenopausal women. Fertility and sterility. 1998;70(6):1085-1089. Review/No data. [pmid: 9848300].
205 Mortimer JE, Urban JH. Long-term toxicities of selective estrogen-receptor modulators and antiaromatase agents. Oncology. 17(5):652-659. Review/No data. [pmid: 12800793].
206 Mourits MJ, De Vries EG, Willemse PH, et al. Tamoxifen treatment and gynecologic side effects: a review. Obstet Gynecol. 2001;97:855-866. Review/No data. [pmid: 11336777].
207 Nathorst-Boos J, Hammar M. Effect on sexual life—a comparison between tibolone and a continuous estradiol-norethisterone acetate regimen. Maturitas. 1997;26(1):15-20. Wrong type of study. [pmid: 9032742].
208 Nayfield SG, Gorin MB. Tamoxifen-associated eye disease. A review. J Clin Oncol. 1996;14(3):1018-1026. Review/No data. [pmid: 8622006].
209 Neven P, Lunde T, Benedetti-Panici P, et al. A multicentre randomised trial to compare uterine safety of raloxifene with a continuous combined hormone replacement therapy containing oestradiol and norethisterone acetate. BJOG. 2003;110(2):157-167. Review/No data. [pmid: 12618160].
210 Neven P, Quail D, Levrier M, et al. Uterine effects of estrogen plus progestin therapy and raloxifene: adjudicated results from the EURALOX study. Obstet Gynecol. 2004;103:881-891. No relevant outcomes. [pmid: 15121561].
211 Neven P, Vergote I. Controversies regarding tamoxifen and uterine carcinoma. Curr Opin Obstet Gynecol. 1998;10(1):9-14. Review/No data. [pmid: 9484623].
212 Neves-E-Castro M. Association of ovarian and uterine cancers with postmenopausal hormonal treatments. Clin Obstet Gynecol. 2008;51(3):607-617. Review/No data. [pmid: 18677154].
213 Nevinny-Stickel J. Double-blind cross-over study with Org OD 14 and placebo in postmenopausal patients. Arch Gynecol. 1983;234(1):27-31. Trial N too small. [pmid: 6660926].
214 Newcomb PA, Love RR, Phillips JL, et al. Using a population-based cancer registry for recruitment in a pilot cancer control study. Prev Med. 1990;19(1):61-65. Wrong population. [pmid: 2181434].
215 Novotny J, Pecen L, Petruzelka L, et al. Breast cancer risk assessment in the Czech female population--an adjustment of the original Gail model. Breast Cancer Res Treat. 2006;95(1):29-35. Population not applicable. [pmid: 16319995].
216 O’Connell G, Arnold A. Tamoxifen and cancer of the endometrium. CMAJ. 1993;148:2113-2114. Review/No data. [pmid: 8324682].
217 Odabasi AR, Yuksel H, Kafkas S, et al. Effects of tibolone on abdominal subcutaneous fat, serum leptin levels, and anthropometric indices: a 6-month, prospective, randomized, placebo-controlled, double-blind study. Adv Ther. 2006;23(6):926-937. Trial N too small. [pmid: 17276962].
218 Olevsky OM, Martino S. Randomized clinical trials of raloxifene: reducing the risk of osteoporosis and breast cancer in postmenopausal women. Menopause. 2008;15:790-796. Review/No data. [pmid: 18596600].
219 Olsson H, Bladstrom A, Ingvar C, et al. A population-based cohort study of HRT use and breast cancer in southern Sweden. Br J Cancer. 2001;85(5):674-677. Single risk factor only. [pmid: 11531250].
220 Ozanne EM, Klemp JR, Esserman LJ. Breast cancer risk assessment and prevention: a framework for shared decision-making consultations. Breast J. 2006;12(2):103-113. No relevant data. [pmid: 16509834].
221 Palmer JR, Wise LA, Horton NJ, et al. Dual effect of parity on breast cancer risk in African-American women. J Natl Cancer Inst. 2003;95(6):478-483. Single risk factor only. [pmid: 12644541].
222 Palomares MR, Machia JRB, Lehman CD, et al. Mammographic density correlation with Gail model breast cancer risk estimates and component risk factors. Cancer Epidemiol Biomarkers Prev. 2006;15(7):1324-1330. Single risk factor only. [pmid: 16835331].
223 Palomba S, Zullo F, Orio F Jr, et al. Does raloxifene inhibit the growth of uterine fibroids? [comment]. Fertil Steril. 2004;81(6):1719-1720. author reply 1720–1711. Review/No data. [pmid: 15193512].
224 Pasacreta JV, McCorkle R. Providing accurate information to women about tamoxifen therapy for breast cancer: current indications, effects, and controversies. Oncol Nurs Forum. 1998;25(9):1577-1583. No relevant data. [pmid: 9802053].
225 Patel AV, Callel EE, Bernstein L, et al. Recreational physical activity and risk of postmenopausal breast cancer in a large cohort of US women. Cancer Causes Control. 2003;14(6):519-529. Single risk factor only. [pmid: 12948283].
226 Peshkin BN, Isaacs C, Finch C, et al. Tamoxifen as chemoprevention in BRCA1 and BRCA2 mutation carriers with breast cancer: a pilot survey of physicians. J Clin Oncol. 2003;21(23):4322-4328. Wrong population. [pmid: 14645421].
227 Peto R, Collins R, Gray R. Large-scale randomized evidence: large, simple trials and overviews of trials. Ann N Y Acad Sci. 1993;703:314-340. Wrong type of study. [pmid: 8192313].
228 Pines A, Levo Y. Why is the RUTH trial so important. Maturitas. 2007;56(2):111-112. Review/No data. [pmid: 17092665].
229 Porch JV, Lee IM, Cook NR, et al. Estrogen-progestin replacement therapy and breast cancer risk: the Women’s Health Study (United States). Cancer Causes Control. 2002;13(9):847-854. Single risk factor only. [pmid: 12462550].
230 Potter CE, Beldock JG. Object Class Networks (OCNs) for interface-independent calculation with Gail and Claus models. Ann N Y Acad Sci. 1995;768:308-311. No relevant data. [pmid: 8526375].
231 Powles TJ. Chemoprevention of breast cancer using tamoxifen. Endocrine Related Cancer. 1997;4:255-260. Review/No data.
232 Powles TJ. The Royal Marsden Hospital (RMH) trial: key points and remaining questions. Ann N Y Acad Sci. 2001;949:109-112. Review/No data. [pmid: 11795342].
233 Powles TJ. Prevention of breast cancer using SERMs. Adv Exp Med Biol. 2008;630:232-236. Review/No data. [pmid: 18637495].
234 Prentice RL. Aspects of the science of cancer prevention trials: lessons from the conduct and planning of clinical trials of a low-fat diet intervention among women. Prev Med. 1991;20(1):147-157. No relevant outcomes. [pmid: 2008423].
235 Reynolds P, Hurley S, Goldberg DE, et al. Active smoking, household passive smoking, and breast cancer: evidence from the California Teachers Study. J Natl Cancer Inst. 2004;96(1):29-37. Single risk factor only. [pmid: 14709736].
236 Reynolds P, Hurley SE, Hoggatt K, et al. Correlates of active and passive smoking in the California Teachers Study cohort. J Womens Health. 2004;13(7):778-790. Single risk factor only.
237 Rhodes DJ. Identifying and counseling women at increased risk for breast cancer. Mayo Clin Proc. 2002;77(4):355-360. quiz 360–351. No relevant data. [pmid: 11936931].
238 Richardson H, Johnston D, Pater J, et al. The. National Cancer Institute. of Canada Clinical Trials Group MAP.3 trial: An international breast cancer prevention trial. Current Oncology. 2007;14(3):89-95. Review/No data.
239 Richardson LC, Hall IJ. Diagnostic accuracy of the Gail model in the Black Women’s Health Study. Breast J. 2007;13(4):329-331. No relevant data. [pmid: 17593035].
240 Robinson E, Kimmick GG, Muss HB. Tamoxifen in postmenopausal women a safety perspective. Drugs Aging. 1996;8(5):329-337. Review/No data. [pmid: 8935395].
241 Rohatgi N, Blau R, Lower EE. Raloxifene is associated with less side effects than tamoxifen in women with early breast cancer: a questionnaire study from one physician’s practice. J Womens Health Gend Based Med. 2002;11(3):291-301. Wrong population. [pmid: 11988138].
242 Rondanina G, Puntoni M, Severi G, et al. Psychological and clinical factors implicated in decision making about a trial of low-dose tamoxifen in hormone replacement therapy users. J Clin Oncol. 2008;26(9):1537-1543. No relevant data. [pmid: 18349406].
243 Rutqvist LE. Re: second cancers after adjuvant tamoxifen therapy for breast cancer. J Natl Cancer Inst. 1497;88(20):1497-1499. author reply. Wrong population. [pmid: 8841030].
244 Sakorafas GH, Krespis E, Pavlakis G. Risk estimation for breast cancer development; a clinical perspective. Surg Oncol. 2002;10(4):183-192. No relevant data. [pmid: 12020673].
245 Salant T, Lauderdale DS. Impact of incidental bilateral salpingo-oophorectomy in a family member on breast cancer risk assessment: clinical considerations. Cancer Detect Prev. 2006;30(4):329-332. Single risk factor only. [pmid: 16971050].
246 Salih AK, Fentiman IS. Breast cancer prevention: present and future. Cancer Treat Rev. 2001;27(5):261-273. No relevant data. [pmid: 11871862].
247 Schrag D, Kuntz KM, Garber JE, et al. Life expectancy gains from cancer prevention strategies for women with breast cancer and BRCA1 or BRCA2 mutations. JAMA. 2000;283(5):617-624. Wrong population. [pmid: 10665701].
248 Schwartz LM, Woloshin S. News media coverage of screening mammography for women in their 40s and tamoxifen for primary prevention of breast cancer. JAMA. 2002;287(23):3136-3142. No relevant outcomes. [pmid: 12069679].
249 Scutt D, Lancaster GA, Manning JT. Breast asymmetry and predisposition to breast cancer. Breast Cancer Res. 2006;8(2):R14. Single risk factor only. [pmid: 16563179].
250 Senkus-Konefka E, Konefka T, Jassem J. The effects of tamoxifen on the female genital tract. Cancer Treat Rev. 2004;30(3):291-301. Review/No data. [pmid: 15059652].
251 Serati M, Uccella S, Bolis P. Tibolone in older postmenopausal women. N Engl J Med. 2008;359(20):2173. No data. [pmid: 19009673].
252 Sestak I, Kealy R, Edwards R, et al. Influence of hormone replacement therapy on tamoxifen-induced vasomotor symptoms. J Clin Oncol. 2006;24(24):3991-3996. Wrong population. [pmid: 16921052].
253 Sharma S, Albertazzi P, Bottazzi M. The long-term effect of raloxifene on the genitourinary tract. Climacteric. 2007;10(3):244-248. Wrong type of study. [pmid: 17487651].
254 Singletary SE. Rating the risk factors for breast cancer. Ann Surg. 2003;237(4):474-482. No relevant data. [pmid: 12677142].
255 Sismondi P, Biglia N, Giai M, et al. Metabolic effects of tamoxifen in postmenopause. Anticancer Res. 1994;14:2237-2244. No relevant outcomes. [pmid: 7840529].
256 Sismondi P, Biglia N, Ujcic E, et al. Raloxifene and endometrial cancer. Tumori. 2001;87(5):S18-19. Review/No data. [pmid: 11765199].
257 Slattery ML, Edwards S, Murtaugh MA, et al. Physical activity and breast cancer risk among women in the southwestern United States. Ann Epidemiol. 2007;17(5):342-353. Single risk factor only. [pmid: 17462544].
258 Slomovitz BM, Sun CC, Ramirez PT, et al. Does tamoxifen use affect prognosis in breast cancer patients who develop endometrial cancer. Obstet Gynecol. 2004;104(2):255-260. Review/No data. [pmid: 15291996].
259 Smith RE, Good BC. Chemoprevention of breast cancer and the trials of the National Surgical Adjuvant Breast and Bowel Project and others. Endocr Relat Cancer. 2003;10(3):347-357. Review/No data. [pmid: 14503912].
260 Soderqvist G, Conner P, Christow A. Effects of tibolone vs estradiol/NETA on proliferation in the mammary gland of health women in vivo—a double-blind, randomized, placebo-controlled study (abstract). Climacteric. 2002;5(Suppl 1):49. Wrong type of study.
261 Spicer DV, Pike MC, Henderson BE. Ovarian cancer and long-term tamoxifen in premenopausal women. Lancet. 1991;337(8754):1414. Review/No data. [pmid: 1674785].
262 Sporn MB, Dowsett SA, Mershon J, et al. Role of raloxifene in breast cancer prevention in postmenopausal women: clinical evidence and potential mechanisms of action. Clin Ther. 2004;26(6):830-840. No relevant outcomes. [pmid: 15262454].
263 Stahlberg C, Pedersen AT, Lynge E, et al. Increased risk of breast cancer following different regimens of hormone replacement therapy frequently used in Europe. Int J Cancer. 2004;109(5):721-727. Single risk factor only. [pmid: 14999781].
264 Stearns V, Gallagher A, Kleer CG, et al. A pilot study to establish a clinical model to perform phase II studies of breast cancer chemopreventive agents in women at high risk with biomarkers as surrogate endpoints for activity. Clin Cancer Res. 2004;10(24):8332-8340. Review/No data. [pmid: 15623610].
265 Stefanick ML. Risk-benefit profiles of raloxifene for women. N Engl J Med. 2006;355(2):190-192. Single risk factor only. [pmid: 16837684].
266 Stefanick ML, Anderson GL, Margolis KL, et al. Effects of conjugated equine estrogens on breast cancer and mammography screening in postmenopausal women with hysterectomy. JAMA. 2006;295(14):1647-1657. Single risk factor only. [pmid: 16609086].
267 Stolzenberg-Solomon RZ, Chang S-C, Leitzmann MF, et al. Folate intake, alcohol use, and postmenopausal breast cancer risk in the Prostate, Lung, Colorectal, and Ovarian Cancer Screening Trial. Am J Clin Nutr. 2006;83(4):895-904. Single risk factor only. [pmid: 16600944].
268 Suzuki R, Orsini N, Mignone L, et al. Alcohol intake and risk of breast cancer defined by estrogen and progesterone receptor status—a meta-analysis of epidemiological studies. Int J Cancer. 2008;122(8):1832-1841. Single risk factor only. [pmid: 18067133].
269 Suzuki R, Ye W, Rylander-Rudqvist T, et al. Alcohol and postmenopausal breast cancer risk defined by estrogen and progesterone receptor status: a prospective cohort study. J Natl Cancer Inst. 2005;97(21):1601-1608. Single risk factor only. [pmid: 16264180].
270 Swede H, Mirand AL, Menezes RJ, et al. Association of regular aspirin use and breast cancer risk. Oncology. 2005;68(1):40-47. Single risk factor only. [pmid: 15802928].
271 Sweeney C, Blair CK, Anderson KE, et al. Risk factors for breast cancer in elderly women. Am J Epidemiol. 2004;160(9):868-875. Population not applicable. [pmid: 15496539].
272 Sweeney C, Giuliano AR, Baumgartner KB, et al. Oral, injected and implanted contraceptives and breast cancer risk among U.S. Hispanic and non-Hispanic white women. Int J Cancer. 2007;121(11):2517-2523. Single risk factor only. [pmid: 17657739].
273 Swerdlow AJ, Jones ME. Ovarian cancer risk in premenopausal and perimenopausal women treated with tamoxifen: a case-control study. Br J Cancer. 2007;96(5):850-855. Wrong population. [pmid: 17285129].
274 Taskin O, Muderrisoglu H, Akar M, et al. Comparison of the effects of tibolone and estrogen replacement therapy on echocardiographic basic cardiac functions in post-menopausal women: a randomized placebo controlled study. Maturitas. 2004;48(4):354-359. Trial N too small. [pmid: 15283927].
275 Tchou J, Morrow M. Available models for breast cancer risk assessment: how accurate are they. J Am Coll Surg. 2003;197(6):1029-1035. No relevant data. [pmid: 14644292].
276 Tjonneland A, Christensen J, Olsen A, et al. Alcohol intake and breast cancer risk: the European Prospective Investigation into Cancer and Nutrition (EPIC). Cancer Causes Control. 2007;18(4):361-373. Single risk factor only. [pmid: 17364225].
277 Torres-Mejia G, De Stavola B, Allen DS, et al. Mammographic features and subsequent risk of breast cancer: a comparison of qualitative and quantitative evaluations in the Guernsey prospective studies. Cancer Epidemiol Biomarkers Prev. 2005;14(5):1052-1059. Single risk factor only. [pmid: 15894652].
278 Travis LB, Hill D, Dores GM, et al. Cumulative absolute breast cancer risk for young women treated for Hodgkin lymphoma. J Natl Cancer Inst. 2005;97(19):1428-1437. Population not applicable. [pmid: 16204692].
279 Travis RC, Allen DS, Fentiman IS, et al. Melatonin and breast cancer: a prospective study [see comment]. J Natl Cancer Inst. 2004;96(6):475-482. Single risk factor only. [pmid: 15026473].
280 Trentham-Dietz A, Nichols HB, Egan KM, et al. Cigarette smoking and risk of breast carcinoma in situ. Epidemiology. 2007;18(5):629-638. Single risk factor only. [pmid: 17700252].
281 Tseng M, Weinberg CR, Umbach DM, et al. Calculation of population attributable risk for alcohol and breast cancer. Cancer Causes Control. 1999;10(2):119-123. Single risk factor only. [pmid: 10231160].
282 Tworoger SS, Missmer SA, Barbieri RL, et al. Plasma sex hormone concentrations and subsequent risk of breast cancer among women using postmenopausal hormones. J Natl Cancer Inst. 2005;97(8):595-602. Single risk factor only. [pmid: 15840882].
283 Vachon CM, van Gils CH, Sellers TA, et al. Mammographic density, breast cancer risk and risk prediction. Breast Cancer Res. 2007;9(6):217. Single risk factor only. [pmid: 18190724].
284 Varras M, Polyzos D, Akrivis C. Effects of tamoxifen on the human female genital tract: review of the literature. Eur J Gynaecol Oncol. 2003;24:3-4. 258. 268. Review/No data.
285 Veronesi A, Pizzichetta MA, Ferlante MA, et al. Tamoxifen as adjuvant after surgery for breast cancer and tamoxifen or placebo as chemoprevention in healthy women: different compliance with treatment. Tumori. 1998;84(3):372-375. No relevant data. [pmid: 9678620].
286 Veronesi U, Costa A. Breast cancer chemoprevention. Cancer Treat Res. 1992;60:357-367. No relevant data. [pmid: 1355997].
287 Vogel VG. Assessing women’s potential risk of developing breast cancer. Oncology. 1461;10(10):1451-1458. No relevant data. [pmid: 8905840].
288 Vogel VG. Reducing the risk of breast cancer with tamoxifen in women at increased risk. J Clin Oncol. 2001;19(18 Suppl):87S-92S. No relevant data. [pmid: 11560980].
289 Vogel VG. Recent results from clinical trials using SERMs to reduce the risk of breast cancer. Ann N Y Acad Sci. 2006;1089:127-142. Review/No data. [pmid: 17261762].
290 Vogel VG, Costantino JP, Wickerham DL, et al. Re: tamoxifen for prevention of breast cancer: report of the National Surgical Adjuvant Breast and Bowel Project P-1 Study. J Natl Cancer Inst. 2002;94(19):1504. Review/No data. [pmid: 12359860].
291 Vogelvang TE, Mijatovic V, van der Mooren MJ, et al. Effect of raloxifene and hormone therapy on serum markers of brain and whole-body cholesterol metabolism in postmenopausal women. Maturitas. 2005;50(4):312-320. No relevant outcomes. [pmid: 15780532].
292 Walker ID, Davidson JF, Richards A, et al. The effect of the synthetic steroid Org OD14 on fibrinolysis and blood lipids in postmenopausal women. Thromb Haemost. 1985;53(3):303-305. Trial N too small. [pmid: 3901389].
293 Wang J, Costantino JP, Tan-Chiu E, et al. Lower-category benign breast disease and the risk of invasive breast cancer. J Natl Cancer Inst. 2004;96(8):616-620. Population not applicable. [pmid: 15100339].
294 Warwick J, Pinney E, Warren RML, et al. Breast density and breast cancer risk factors in a high-risk population. Breast. 2003;12(1):10-16. Review/No data. [pmid: 14659350].
295 Wenger NK. Drugs for cardiovascular disease prevention in women: implications of the AHA Guidelines—2007 Update. Drugs. 2008;68(3):339-358. Review/No data. [pmid: 18257610].
296 Will BP, Nobrega KM, Berthelot JM, et al. First do no harm: extending the debate on the provision of preventive tamoxifen. Br J Cancer. 2001;85(9):1280-1288. Wrong type of study. [pmid: 11720461].
297 Winkler UH, Altkemper R, Kwee B, et al. Effects of tibolone and continuous combined hormone replacement therapy on parameters in the clotting cascade: a multicenter, double-blind, randomized study. Fertil Steril. 2000;74(1):10-19. Wrong type of study. [pmid: 10899490].
298 Wolmark N, Dunn BK. The role of tamoxifen in breast cancer prevention: issues sparked by the NSABP Breast Cancer Prevention Trial (P-1). Ann N Y Acad Sci. 2001;949:99-108. Review/No data. [pmid: 11795386].
299 Wooltorton E. Tamoxifen for breast cancer prevention: safety warning. CMAJ. 2002;167(4):378-379. Review/No data. [pmid: 12197698].
300 Yen TWF, Hunt KK, Mirza NQ, et al. Physician recommendations regarding tamoxifen and patient utilization of tamoxifen after surgery for ductal carcinoma in situ. Cancer. 2004;100(5):942-949. Wrong population. [pmid: 14983489].
301 Zhang SM, Manson JE, Rexrode KM, et al. Use of oral conjugated estrogen alone and risk of breast cancer. Am J Epidemiol. 2007;165(5):524-529. Single risk factor only. [pmid: 17132697].
302 Zhang SM, Willett WC, Selhub J, et al. Plasma folate, vitamin B6, vitamin B12, homocysteine, and risk of breast cancer. J Natl Cancer Inst. 2003;95(5):373-380. Single risk factor only. [pmid: 12618502].