# Abbreviations

AHRQ: Agency for Healthcare Research and Quality
BCDDP: Breast Cancer Detection and Demonstration Project
BCPCG: Breast Cancer Prevention Collaborative Group
BCSC: Breast Cancer Surveillance Consortium
BMD: Bone Mineral Density
BMI: Body Mass Index
BRCA1: Breast Cancer Susceptibility Gene 1
BRCA2: Breast Cancer Susceptibility Gene 2
CEE: Conjugated Equine Estrogens
CER: Comparative Effectiveness Reviews
CHD: Coronary Heart Disease
CI: Confidence Interval
CORE: Continuing Outcomes Relevant to Evista Trial
CT: Computed Tomography
DCIS: Ductal carcinoma in situ
DVT: Deep Vein Thrombosis
E/O: Expected/Observed Ratio
EPC: Evidence-based Practice Center
ER−: Estrogen Receptor Negative
ER+: Estrogen Receptor Positive
FDA: Food and Drug Administration
GRADE: Grades of Recommendation Assessment, Development and Evaluation
HR: Hazard Ratio
IBIS-1: International Breast Cancer Intervention Study
IT1-GM: Italian-1 Gail Model
IT-GM: Italian Gail Model
LCIS: Lobular Carcinoma in situ
LIFT: Long-Term Intervention on Fractures with Tibolone Trial
MeSH: Medical Subject Headings
MI: Myocardial Infarction
MORE: Multiple Outcomes of Raloxifene Evaluation Trial
MPA: Medroxyprogesterone Acetate
MWS: Million Women’s Study
NNT: Number needed to treat
NR: Not reported
NSABP P-1: National Surgical Adjuvant Breast and Bowel Project
OPAL: Osteoporosis Prevention and Arterial effects of tiboLone Trial
PE: Pulmonary Embolism
PICOTS: Population, Intervention, Comparator, Outcomes, Timing of outcomes measurement and Setting
RCT: Randomized Controlled Trial
RH: Relative Hazard
RR: Risk Ratio
RUTH: Raloxifene Use for the Heart Trial
SCHIP: State Children’s Health Insurance Program
SEER: Surveillance, Epidemiology, and End Results
SERMs: Selective Estrogen Receptor Modulators
SRC: Scientific Resource Center
STAR: Study of Tamoxifen and Raloxifene
STEAR: Selective Tissue Estrogenic Activity Regulator
THEBES: The Tibolone Histology of the Endometrium and Breast Endpoints Study
TIA: Transient Ischemic Attack
UK: United Kingdom
US: United States of America
USPSTF: United States Preventive Services Task Force
VTE: Venous Thrombotic Event
WHI: Women’s Health Initiative