# References

1 Deyo RA, Mirza SK, Martin BI. Back pain prevalence and visit rates. Spine (Phila Pa 1976). 2006;31(23):2724-7. [pmid: 17077742].
2 Walker BF. The prevalence of low back pain: a systematic review of the literature from 1966 to 1998. J Spinal Disord. 2000;13(3):205-17. [pmid: 10872758].
3 Luo X, Pietrobon R, Sun SX, et al. Estimates and patterns of direct health care expenditures among individuals with back pain in the United States. Spine (Phila Pa 1976). 2004;29(1):79-86. [pmid: 14699281].
4 Martin BI, Deyo RA, Mirza SK, et al. Expenditures and health status among adults with back and neck problems. Jama. 2008;299(6):656-64. [pmid: 18270354].
5 Stewart WF, Ricci JA, Chee E, et al. Lost productive time and cost due to common pain conditions in the US workforce. Jama. 2003;290(18):2443-54. [pmid: 14612481].
6 Pengel LHM, Herbert RD, Maher CG, et al. Acute low back pain: systematic review of its prognosis. BMJ. 2003;327(7410):323-7. [pmid: 12907487].
7 Chou R, Shekelle P. Will this patient develop persistent disabling low back pain?. Jama. 2010;303(13):1295-302. [pmid: 20371789].
8 Deyo RA, Dworkin SF, Amtmann D, et al. Report of the NIH Task Force on Research Standards for Chronic Low Back Pain. Spine (Phila Pa 1976). 2014;39(14):1128-43. [pmid: 24887571].
9 Frymoyer JW. Predictors of low back pain disability. J Clinical Orthop Relat Res. 1987;22:89-98. [pmid: 2955993].
10 Engel CC, Von Korff M, Katon WJ. Back pain in primary care: predictors of high health-care costs. Pain. 1996;65:197-204. [pmid: 8826507].
11 Waddell G, McCulloch JA, Kummel E, et al. Nonorganic physical signs in low-back pain. Spine (Phila Pa 1976). 1980;5(2):117-25. [pmid: 6446157].
12 Jarvik JG, Deyo RA. Diagnostic evaluation of low back pain with emphasis on imaging. Ann Intern Med. 2002;137(7):586-97. [pmid: 12353946].
13 van Tulder MW, Assendelft WJ, Koes BW, et al. Spinal radiographic findings and nonspecific low back pain: a systematic review of observational studies. Spine. 1997;22(4):427-34. [pmid: 9055372].
14 Chou R, Qaseem A, Snow V, et al. Diagnosis and treatment of low back pain: A joint clinical practice guideline from the American College of Physicians and the American Pain Society. Ann Intern Med. 2007;147(7):478-91. [pmid: 17909209].
15 Chou R, Huffman LH, American Pain S, et al. Medications for acute and chronic low back pain: a review of the evidence for an American Pain Society/American College of Physicians clinical practice guideline. Ann Intern Med. 2007;147(7):505-14. [pmid: 17909211].
16 Chou R, Huffman LH, American Pain Society, et al. Nonpharmacologic therapies for acute and chronic low back pain: a review of the evidence for an American Pain Society/American College of Physicians clinical practice guideline. Ann Intern Med. 2007;147(7):492-504. [pmid: 17909210].
17 Chou R, Atlas SJ, Stanos SP, et al. Nonsurgical interventional therapies for low back pain: a review of the evidence for an American Pain Society clinical practice guideline. Spine. 2009;34(10):1078-93. [pmid: 19363456].
18 Chou R, Baisden J, Carragee EJ, et al. Surgery for low back pain: A review of the evidence for an American pain society clinical practice guideline. Spine (Phila Pa 1976). 2009;34(10):1094-109. [pmid: 19363455].
19 Owens D, Lohr KN, Atkins D, et al. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Rockville, MD. Agency for Healthcare Research and Quality. 2011.
20 Chou R, Huffman L, editors. Guideline for the Use of Chronic Opioid Therapy in Chronic Noncancer Pain. Evidence Review. American Pain Society in Conjunction with American Academy of Pain Medicine. Glenview, IL. 2009. American Pain Society, ed.
21 Agency for Healthcare Research and Quality. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication 10(13)-EHC063-EF. 2014. www.effectivehealthcare.ahrq.gov. April 4th, 2014.
22 Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication 10(12)-EHC063-EF. Rockville, MD. January. 2014.
23 Shea BJ, Hamel C, Wells GA, et al. AMSTAR is a reliable and valid measurement tool to assess the methodological quality of systematic reviews. J Clin Epidemiol. 2009;62(10):1013-20. [pmid: 19230606].
24 Agency for Healthcare Research and Quality. Integrating Bodies of Evidence: Existing Systematic Reviews and Primary Studies. 2015.
25 Furlan AD, Reardon R, Weppler C. Opioids for chronic noncancer pain: a new Canadian practice guideline. CMAJ. 2010;182(9):923-30. [pmid: 20439443].
26 U.S. Preventive Services Task Force Procedure Manual. AHRQ Publication 08-05118-EF. Rockville, MD. 2008.
27 Atkins D, Chang SM, Gartlehner G, et al. Assessing applicability when comparing medical interventions: AHRQ and the Effective Health Care Program. J Clin Epidemiol. 2011;64(11):1198-207. [pmid: 21463926].
28 Ostelo RW, Deyo RA, Stratford P, et al. Interpreting change scores for pain and functional status in low back pain: towards international consensus regarding minimal important change. Spine (Phila Pa 1976). 2008;33(1):90-4. [pmid: 18165753].
29 Chou R, Huffman L. Guideline for the evaluation and management of low back pain: evidence review. Glenview IL. American Pain Society. 2007.
30 Milgrom C, Finestone A, Lev B, et al. Overexertional lumbar and thoracic back pain among recruits: a prospective study of risk factors and treatment regimens. J Spinal Disord. 1993;6(3):187-93. [pmid: 8347966].
31 van Tulder MW, Scholten RJ, Koes BW, et al. Nonsteroidal anti-inflammatory drugs for low back pain: a systematic review within the framework of the Cochrane Collaboration Back Review Group. Spine (Phila Pa 1976). 2000;25(19):2501-13. [pmid: 11013503].
32 van Tulder MW, Scholten RJ, Koes BW, et al. Non-steroidal anti-inflammatory drugs for low back pain. Cochrane Database Syst Rev. 2000;(2). CD000396. [pmid: 10796356].
33 Evans DP, Burke MS, Newcombe RG. Medicines of choice in low back pain. Curr Med Res Opin. 1980;6(8):540-7. [pmid: 6446445].
34 Hickey RF. Chronic low back pain: a comparison of diflunisal with paracetamol. N Z Med J. 1982;95(707):312-4. [pmid: 6212783].
35 Muckle DS. Flurbiprofen for the treatment of soft tissue trauma. Am J Med. 1986;80(3A):76-80. [pmid: 2938471].
36 Wiesel SW, Cuckler JM, Deluca F, et al. Acute low-back pain. An objective analysis of conservative therapy. Spine (Phila Pa 1976). 1980;5(4):324-30. [pmid: 6450448].
37 Stein D, Peri T, Edelstein E, et al. The efficacy of amitriptyline and acetaminophen in the management of acute low back pain. Psychosomatics. 1996;37(1):63-70. [pmid: 8600497].
38 Hackett GI, Seddon D, Kaminski D. Electroacupuncture compared with paracetamol for acute low back pain. Practitioner. 1988;232(1443):163-4. [pmid: 2973008].
39 Doran DM, Newell DJ. Manipulation in treatment of low back pain: a multicentre study. Br Med J. 1975;2(5964):161-4. [pmid: 123815].
40 Roelofs PDDM, Deyo RA, Koes BW, et al. Nonsteroidal anti-inflammatory drugs for low back pain: an updated Cochrane review. Spine. 2008;33(16):1766-74. [pmid: 18580547].
41 Roelofs PDDM, Deyo RA, Koes BW, et al. Non-steroidal anti-inflammatory drugs for low back pain. Cochrane Database Syst Rev. 2008;(1). CD000396. [pmid: 18253976].
42 Nadler SF, Steiner DJ, Erasala GN, et al. Continuous low-level heat wrap therapy provides more efficacy than Ibuprofen and acetaminophen for acute low back pain. Spine (Phila Pa 1976). 2002;27(10):1012-7. [pmid: 12004166].
43 Williams CM, Maher CG, Latimer J, et al. Efficacy of paracetamol for acute low-back pain: a double-blind, randomised controlled trial. Lancet. 2014;384(9954):1586-96. [pmid: 25064594].
44 van Tulder MW, Jellema P, van Poppel MNM, et al. Lumbar supports for prevention and treatment of low-back pain. Cochrane Database Syst Rev. 2000;(3). Art. No.: CD001823. [pmid: 17636685].
45 Dreiser RL, Le Parc JM, Velicitat P, et al. Oral meloxicam is effective in acute sciatica: two randomised, double-blind trials versus placebo or diclofenac. Inflamm Res. Suppl 1. 2001;50:S17-23. [pmid: 11339516].
46 Famaey JP, Bruhwyler J, Geczy J, et al. Open controlled randomized multicenter comparison of nimesulide and diclofenac in the treatment of subacute and chronic low back pain. J Clin Res. 1998;1(219-238):219-38.
47 Pohjolainen T, Jekunen A, Autio L, et al. Treatment of acute low back pain with the COX-2-selective anti-inflammatory drug nimesulide: results of a randomized, double-blind comparative trial versus ibuprofen. Spine (Phila Pa 1976). 2000;25(12):1579-85. [pmid: 10851109].
48 Ximenes A, Robles M, Sands G, et al. Valdecoxib is as efficacious as diclofenac in the treatment of acute low back pain. Clin J Pain. 2007;23(3):244-50. [pmid: 17314584].
49 Zerbini C, Ozturk ZE, Grifka J, et al. Efficacy of etoricoxib 60 mg/day and diclofenac 150 mg/day in reduction of pain and disability in patients with chronic low back pain: results of a 4-week, multinational, randomized, double-blind study. Curr Med Res Opin. 2005;21(12):2037-49. [pmid: 16368055].
50 Herrmann WA, Geertsen MS. Efficacy and safety of lornoxicam compared with placebo and diclofenac in acute sciatica/lumbo-sciatica: an analysis from a randomised, double-blind, multicentre, parallel-group study. Int J Clin Pract. 2009;63(11):1613-21. [pmid: 19832818].
51 Majchrzycki M, Kocur P, Kotwicki T. Deep tissue massage and nonsteroidal anti-inflammatory drugs for low back pain: a prospective randomized trial. Scientific WorldJournal. 2014;2014:287597. [pmid: 24707200].
52 Shirado O, Doi T, Akai M, et al. Multicenter randomized controlled trial to evaluate the effect of home-based exercise on patients with chronic low back pain: the Japan low back pain exercise therapy study. Spine. 2010;35(17):E811-9. [pmid: 20628332].
53 Amlie E, Weber H, Holme I. Treatment of acute low-back pain with piroxicam: results of a double-blind placebo-controlled trial. Spine (Phila Pa 1976). 1987;12(5):473-6. [pmid: 2957801].
54 Babej-Dolle R, Freytag S, Eckmeyer J, et al. Parenteral dipyrone versus diclofenac and placebo in patients with acute lumbago or sciatic pain: randomized observer-blind multicenter study. Int J Clin Pharmacol Ther. 1994;32(4):204-9. [pmid: 8032581].
55 Basmajian JV. Acute back pain and spasm. A controlled multicenter trial of combined analgesic and antispasm agents. Spine (Phila Pa 1976). 1989;14(4):438-9. [pmid: 2524114].
56 Dreiser RL, Marty M, Ionescu E, et al. Relief of acute low back pain with diclofenac-K 12.5 mg tablets: a flexible dose, ibuprofen 200 mg and placebo-controlled clinical trial. Int J Clin Pharmacol Ther. 2003;41(9):375-85. [pmid: 14518597].
57 Goldie I. A clinical trial with indomethacin (indomee(R)) in low back pain and sciatica. Acta Orthop Scand. 1968;39(1):117-28. [pmid: 4239771].
58 Jacobs JH, Grayson MF. Trial of an anti-inflammatory agent (indomethacin) in low back pain with and without radicular involvement. Br Med J. 1968;3(5611):158-60. [pmid: 4232743].
59 Lacey PH, Dodd GD, Shannon DJ. A double blind, placebo controlled study of piroxicam in the management of acute musculoskeletal disorders. Eur J Rheumatol Inflamm. 1984;7(3):95-104. [pmid: 6443759].
60 Szpalski M, Hayez JP. Objective functional assessment of the efficacy of tenoxicam in the treatment of acute low back pain. A double-blind placebo-controlled study. Br J Rheumatol. 1994;33(1):74-8. [pmid: 8162464].
61 Weber H, Aasand G. The effect of phenylbutazone on patients with acute lumbago-sciatica. A double blind trial. J Oslo City Hosp. 1980;30(5):69-72. [pmid: 6446598].
62 Weber H, Holme I, Amlie E. The natural course of acute sciatica with nerve root symptoms in a double-blind placebo-controlled trial evaluating the effect of piroxicam. Spine (Phila Pa 1976). 1993;18(11):1433-8. [pmid: 8235813].
63 Berry H, Bloom B, Hamilton EB, et al. Naproxen sodium, diflunisal, and placebo in the treatment of chronic back pain. Ann Rheum Dis. 1982;41(2):129-32. [pmid: 6462116].
64 Birbara CA, Puopolo AD, Munoz DR, et al. Treatment of chronic low back pain with etoricoxib, a new cyclo-oxygenase-2 selective inhibitor: improvement in pain and disability--a randomized, placebo-controlled, 3-month trial. J Pain. 2003;4(6):307-15. [pmid: 14622687].
65 Coats TL, Borenstein DG, Nangia NK, et al. Effects of valdecoxib in the treatment of chronic low back pain: results of a randomized, placebo-controlled trial. Clin Ther. 2004;26(8):1249-60. [pmid: 15476906].
66 Katz N, Ju WD, Krupa DA, et al. Efficacy and safety of rofecoxib in patients with chronic low back pain: results from two 4-week, randomized, placebo-controlled, parallel-group, double-blind trials. Spine (Phila Pa 1976). 2003;28(9):851-8. discussion 9. [pmid: 12941996].
67 Chrubasik S, Model A, Black A, et al. A randomized double-blind pilot study comparing Doloteffin and Vioxx in the treatment of low back pain. Rheumatology (Oxford). 2003;42(1):141-8. [pmid: 12509627].
68 Colberg K, Hettich M, Sigmund R, et al. The efficacy and tolerability of an 8-day administration of intravenous and oral meloxicam: a comparison with intramuscular and oral diclofenac in patients with acute lumbago. German Meloxicam Ampoule Study Group. Curr Med Res Opin. 1996;13(7):363-77. [pmid: 8862936].
69 Chaparro EL, Furlan AD, Deshpande A, et al. Opioids compared to placebo or other treatments for chronic low-back pain. Cochrane Database Syst Rev. 2014;(5).
70 Buynak R, Shapiro DY, Okamoto A, et al. Efficacy and safety of tapentadol extended release for the management of chronic low back pain: results of a prospective, randomized, double-blind, placebo- and active-controlled Phase III study. [Erratum appears in Expert Opin Pharmacother. 2010 Nov;11(16):2773]. Expert Opin Pharmacother. 2010;11(11):1787-804. [pmid: 20578811].
71 Chu LF, D'Arcy N, Brady C, et al. Analgesic tolerance without demonstrable opioid-induced hyperalgesia: a double-blinded, randomized, placebo-controlled trial of sustained-release morphine for treatment of chronic nonradicular low-back pain. Pain. 2012;153(8):1583-92. [pmid: 22704854].
72 Hale M, Khan A, Kutch M, et al. Once-daily OROS hydromorphone ER compared with placebo in opioid-tolerant patients with chronic low back pain. [Erratum appears in Curr Med Res Opin. 2010 Aug;26(8):1904]. Curr Med Res Opin. 2010;26(6):1505-18. [pmid: 20429852].
73 Hale ME, Ahdieh H, Ma T, et al. Efficacy and safety of OPANA ER (oxymorphone extended release) for relief of moderate to severe chronic low back pain in opioid-experienced patients: a 12-week, randomized, double-blind, placebo-controlled study. J Pain. 2007;8(2):175-84. [pmid: 17145204].
74 Katz N, Rauck R, Ahdieh H, et al. A 12-week, randomized, placebo-controlled trial assessing the safety and efficacy of oxymorphone extended release for opioid-naive patients with chronic low back pain. Curr Med Res Opin. 2007;23(1):117-28. [pmid: 17257473].
75 Khoromi S, Cui L, Nackers L, et al. Morphine, nortriptyline and their combination vs. placebo in patients with chronic lumbar root pain. Pain. 2007;130(1-2):66-75. [pmid: 17182183].
76 Webster LR, Butera PG, Moran LV, et al. Oxytrex minimizes physical dependence while providing effective analgesia: a randomized controlled trial in low back pain. J Pain. 2006;7(12):937-46. [pmid: 17157780].
77 Peloso PM, Fortin L, Beaulieu A, et al. Analgesic efficacy and safety of tramadol/ acetaminophen combination tablets (Ultracet) in treatment of chronic low back pain: a multicenter, outpatient, randomized, double blind, placebo controlled trial. J Rheumatol. 2004;31(12):2454-63. [pmid: 15570651].
78 Ruoff GE, Rosenthal N, Jordan D, et al. Tramadol/acetaminophen combination tablets for the treatment of chronic lower back pain: a multicenter, randomized, double-blind, placebo-controlled outpatient study. Clin Ther. 2003;25(4):1123-41. [pmid: 12809961].
79 Schnitzer TJ, Gray WL, Paster RZ, et al. Efficacy of tramadol in treatment of chronic low back pain. J Rheumatol. 2000;27(3):772-8. [pmid: 10743823].
80 Uberall MA, Mueller-Schwefe GHH, Terhaag B. Efficacy and safety of flupirtine modified release for the management of moderate to severe chronic low back pain: results of SUPREME, a prospective randomized, double-blind, placebo- and active-controlled parallel-group phase IV study. Curr Med Res Opin. 2012;28(10):1617-34. [pmid: 22970658].
81 Vorsanger GJ, Xiang J, Gana TJ, et al. Extended-release tramadol (tramadol ER) in the treatment of chronic low back pain. J Opioid Manag. 2008;4(2):87-97. [pmid: 18557165].
82 Gordon A, Callaghan D, Spink D, et al. Buprenorphine transdermal system in adults with chronic low back pain: a randomized, double-blind, placebo-controlled crossover study, followed by an open-label extension phase. Clin Ther. 2010;32(5):844-60. [pmid: 20685494].
83 O'Donnell JB, Ekman EF, Spalding WM, et al. The effectiveness of a weak opioid medication versus a cyclo-oxygenase-2 (COX-2) selective non-steroidal anti-inflammatory drug in treating flare-up of chronic low-back pain: results from two randomized, double-blind, 6-week studies. J Int Med Res. 2009;37(6):1789-802. [pmid: 20146877].
84 Steiner DJ, Sitar S, Wen W, et al. Efficacy and safety of the seven-day buprenorphine transdermal system in opioid-naive patients with moderate to severe chronic low back pain: an enriched, randomized, double-blind, placebo-controlled study. J Pain Symptom Manage. 2011;42(6):903-17. [pmid: 21945130].
85 Hale ME, Dvergsten C, Gimbel J. Efficacy and safety of oxymorphone extended release in chronic low back pain: results of a randomized, double-blind, placebo- and active-controlled phase III study. J Pain. 2005;6(1):21-8. [pmid: 15629415].
86 Jamison RN, Raymond SA, Slawsby EA, et al. Opioid therapy for chronic noncancer back pain. A randomized prospective study. Spine (Phila Pa 1976). 1998;23(23):2591-600. [pmid: 9854758].
87 Cloutier C, Taliano J, O'Mahony W, et al. Controlled-release oxycodone and naloxone in the treatment of chronic low back pain: a placebo-controlled, randomized study. Pain Res Manag. 2013;18(2):75-82. [pmid: 23662289].
88 Hyup Lee J, Lee C-S, Ultracet ERSG. A randomized, double-blind, placebo-controlled, parallel-group study to evaluate the efficacy and safety of the extended-release tramadol hydrochloride/acetaminophen fixed-dose combination tablet for the treatment of chronic low back pain. Clin Ther. 2013;35(11):1830-40. [pmid: 24183364].
89 Rauck RL, Nalamachu S, Wild JE, et al. Single-entity hydrocodone extended-release capsules in opioid-tolerant subjects with moderate-to-severe chronic low back pain: a randomized double-blind, placebo-controlled study. Pain Med. 2014;15(6):975-85. [pmid: 24517082].
90 Schiphorst Preuper HR, Geertzen JHB, van Wijhe M, et al. Do analgesics improve functioning in patients with chronic low back pain? An explorative triple-blinded RCT. Eur Spine J. 2014;23(4):800-6. [pmid: 24526247].
91 Nalamachu S, Hale M, Khan A. Hydromorphone extended release for neuropathic and non-neuropathic/nociceptive chronic low back pain: a post hoc analysis of data from a randomized, multicenter, double-blind, placebo-controlled clinical trial. J Opioid Manag. 2014;10(5):311-22. [pmid: 25350473].
92 Furlan A, Chaparro LE, Irvin E, et al. A comparison between enriched and nonenriched enrollment randomized withdrawal trials of opioids for chronic noncancer pain. Pain Res Manag. 2011;16(5):337-51. [pmid: 22059206].
93 Sullivan MD, Howe CQ. Opioid therapy for chronic pain in the United States: promises and perils. Pain. Suppl 1. 2013;154:S94-100. [pmid: 24036286].
94 Carson S, Thakurta S, Low A, et al. Drug Class Review: Long-Acting Opioid Analgesics: Final Update 6 Report [Internet]. Drug Class Reviews. 2011. [pmid: 21977550].
95 Allan L, Richarz U, Simpson K, et al. Transdermal fentanyl versus sustained release oral morphine in strong-opioid naive patients with chronic low back pain. Spine (Phila Pa 1976). 2005;30(22):2484-90. [pmid: 16284584].
96 Rauck RL, Bookbinder SA, Bunker TR, et al. The ACTION study: a randomized, open-label, multicenter trial comparing once-a-day extended-release morphine sulfate capsules (AVINZA) to twice-a-day controlled-release oxycodone hydrochloride tablets (OxyContin) for the treatment of chronic, moderate to severe low back pain. J Opioid Manag. 2006;2(3):155-66. [pmid: 17319449].
97 Hale ME, Fleischmann R, Salzman R, et al. Efficacy and safety of controlled-release versus immediate-release oxycodone: randomized, double-blind evaluation in patients with chronic back pain. Clin J Pain. 1999;15(3):179-83. [pmid: 10524470].
98 Salzman RT, Roberts MS, Wild J, et al. Can a controlled-release oral dose form of oxycodone be used as readily as an immediate-release form for the purpose of titrating to stable pain control?. J Pain Symptom Manage. 1999;18(4):271-9. [pmid: 10534967].
99 Hale M, Speight K, Harsanyi Z, et al. Efficacy of 12 hourly controlled-release codeine compared with as required dosing of acetaminophen plus codeine in patients with chronic low back pain. Pain Res Manage. 1997;2(1):33-8.
100 Gostick N, Allen J, Cranfield R, et al. A comparison of the efficacy and adverse effects of controlled-release dihydrocodeine and immediate-release dihydrocodeine in the treatment of pain in osteoarthritis and chronic back pain. Paper presented at: Proceedings of The Edinburgh Symposium on Pain Control and Medical Education. 1989.
101 Nicholson B, Ross E, Sasaki J, et al. Randomized trial comparing polymer-coated extended-release morphine sulfate to controlled-release oxycodone HCl in moderate to severe nonmalignant pain. Curr Med Res Opin. 2006;22(8):1503-14. [pmid: 16870075].
102 Beaulieu AD, Peloso P, Bensen W, et al. A randomized, double-blind, 8-week crossover study of once-daily controlled-release tramadol versus immediate-release tramadol taken as needed for chronic noncancer pain. Clin Ther. 2007;29(1):49-60. [pmid: 17379046].
103 van Tulder MW, Touray T, Furlan AD, et al. Muscle relaxants for non-specific low-back pain. Cochrane Database Syst Rev. 2009;(4).
104 Baptista R, Brizzi J, Josef H, et al. Terepeutica da lombalgia com a tizanidina. Folha Medica. 1988.
105 Baratta RR. A double-blind comparative study of carisoprodol, propoxyphene, and placebo in the management of low back syndrome. Curr Ther Res Clin Exp. 1976;20(3):233-40. [pmid: 134877].
106 Basmajian JV. Cyclobenzaprine hydrochloride effect on skeletal muscle spasm in the lumbar region and neck: two double-blind controlled clinical and laboratory studies. Arch Phys Med Rehabil. 1978;59(2):58-63. [pmid: 623512].
107 Berry H, Hutchinson D. Tizanidine and ibuprofen in acute low-back pain: results of a double-blind multicentre study in general practice. J Int Med Res. 1988;16(2):83-91. [pmid: 2967781].
108 Berry H, Hutchinson DR. A multicentre placebo-controlled study in general practice to evaluate the efficacy and safety of tizanidine in acute low-back pain. J Int Med Res. 1988;16:75-82. [pmid: 2967780].
109 Bianchi M. Evaluation of cyclobenzaprine for skeletal muscle spasm of local origin. Postgrad Med Comm. 1978:25-9.
110 Borenstein D, Lacks S, Wiesel S. Cyclobenzarpine and naproxen versus naproxen alone in the treatment of acute low back pain and muscle spasm. Clin Ther. 1990;12:125-31. [pmid: 2141299].
111 Bragstad A, Bilkra G. Evaluation of a new skeletal muscle relaxant in the treatment of low back pain (a comparison of DS 103-282 wiht chlorzoxazone). Curr Ther Res. 1979;26(1):39-43.
112 Casale R. Acute low back pain: symptomatic treatment with a muscle relaxing drug. Clin J Pain. 1988;4:81-8.
113 Corts Giner JR. Estudio DS 103-282: relajante muscular en lumbalgia aguda o lumbao (estudio doble ciego de tizanidina + paracetamol vs. placebo + paracetamol. Rev Esp de Cir Ost. 1989:119-24.
114 Dapas F, Hartman SF, Martinez L, et al. Baclofen for the treatment of acute low-back syndrome. A double-blind comparison with placebo. Spine. 1985;10(4):345-9. [pmid: 2931831].
115 Gold R. Orphenadrine Citrate: Sedative or Muscle Relaxant?. Clin Ther. 1978;1(6):451-3.
116 Hindle TH 3rd. Comparison of carisoprodol, butabarbital, and placebo in treatment of the low back syndrome. Calif Med. 1972;117(2):7-11. [pmid: 4262210].
117 Hingorani K. Orphenadine/Paracetamol in backache: a double-blind controlled trial. Br J Clin Pract. 1971;25:227-31. [pmid: 4253016].
118 Klinger N, Wilson R, Kanniainen C, et al. Intravenous orphenadrine for the treatment of lumbar paravertebral muscle strain. Curr Ther Res. 1988;43(2):247-54.
119 Lepisto P. A comparative trial of ds 103-283 and placebo in the treatment of acute skeletal muscle spasms due to disorders of the back. Ther Res. 1979;26(4):454-59.
120 Pipino F, Menarini C, Lombardi G, et al. A direct myotonolytic (Pridinol Mesilate) for the mangement of chronic low back pain: A multicentre, comparitive clinical evaluation. Eur J Clin Res. 1991;1(1):55-70.
121 Pratzel HG, Alken RG, Ramm S. Efficacy and tolerance of repeated oral doses of tolperisone hydrochloride in the treatment of painful reflex muscle spasm: results of a prospective placebo-controlled double-blind trial. Pain. 1996;67(2-3):417-25. [pmid: 8951937].
122 Rollings H. Management of acute musculoskeletal conditions - Thoracolumbar strain or sprain: A doulbe-blind evaluation comparing the efficacy and safety of carisoprodol with cyclobenzaprene hydrochloride. Curr Ther Res. 1983;34(6):917-28.
123 Sirdalud Ternelin Asia-Pacific Study Group. Efficacy and gastroprotective effects of tizanidine plus diclofenac versus placebo plus dicofenac in patients with painful muscle spasms. Curr Ther Res. 1998;59:13-22.
124 Sweetman BJ, Baig A, Parsons DL. Mefenamic acid, chlormezanone-paracetamol, ethoheptazine-aspirin-meprobamate: a comparative study in acute low back pain. Br J Clin Pract. 1987;41(2):619-24. [pmid: 2960369].
125 Tervo T, Petaja L, Lepisto P. A controlled clinical trial of a muscle relaxants analgesic combination in the treatment of acute lumbago. Br J Clin Pract. 1976;30:62-4. [pmid: 130920].
126 Pareek A, Chandurkar N, Chandanwale AS, et al. Aceclofenac-tizanidine in the treatment of acute low back pain: a double-blind, double-dummy, randomized, multicentric, comparative study against aceclofenac alone. Eur Spine J. 2009;18(12):1836-42. [pmid: 19421791].
127 Ralph L, Look M, Wheeler W, et al. Double-blind, placebo-controlled trial of carisoprodol 250-mg tablets in the treatment of acute lower-back spasm. Curr Med Res Opin. 2008;24(2):551-8. [pmid: 18194591].
128 Boyles WF, Glassmann JM, Soyka JP. Management of acute musculoskeletal conditions: Thoracolumbar strain or sprain. A double-blind evaluation comparing the efficacy and safety of carisoprodol with diazepam. Today's Therapeutic Trends. 1983;1(1):1-16.
129 Hennies OL. A new skeletal muscle relaxant (DS 103-282) compared to diazepam in the treatment of muscle spasm of local origin. J Int Med Res. 1981;9(1):62-8. [pmid: 6451461].
130 Arbus L, Fajadet B, Aubert D, et al. Activity of tetrazepam (Myolastan®)* * Myolastan® - tetrazepam; Sanofi Recherche, Toulouse, France. in low back pain. A double-blind trial v. placebo. Clinical Trials Journal. 1990;27(4):258-67.
131 Hingorani K. Diazepam in backache. A double-blind controlled trial. Ann Phys Med. 1966;8(8):303-6. [pmid: 4224750].
132 Moll W. Therapy of acute lumbovertebral syndromes through optimal muscle relaxation using diazepam. Results of a double-blind study on 68 cases. Med Welt. 1973;24(45):1747-51. [pmid: 4272092].
133 Salzmann E, Pforringer W, Paal G, et al. Treatment of chronic low-back syndrome with tetrazepam in a placebo controlled double-blind trial. J Drug Devel. 1992;4(4):219-28.
134 Weber H. Comparison of the effect of diazepam and levomepromazine on pain in patients with acute lumbago-sciatica. J Oslo City Hosp. 1980;30(5):65-8. [pmid: 6446597].
135 Brotz D, Maschke E, Burkard S, et al. Is there a role for benzodiazepines in the management of lumbar disc prolapse with acute sciatica?. Pain. 2010;149(3):470-5. [pmid: 20362397].
136 Schnitzer TJ, Ferraro A, Hunsche E, et al. A comprehensive review of clinical trials on the efficacy and safety of drugs for the treatment of low back pain. J Pain Sympt Mgmt. 2004;28(1):72-95. [pmid: 15223086].
137 Salerno SM, Browning R, Jackson JL. The effect of antidepressant treatment on chronic back pain: a meta-analysis. Arch Intern Med. 2002;162(1):19-24. [pmid: 11784215].
138 Staiger TO, Gaster B, Sullivan MD, et al. Systematic review of antidepressants in the treatment of chronic low back pain. Spine. 2003;28(22):2540-5. [pmid: 14624092].
139 Urquhart DM, Hoving JL, Assendelft JJW, et al. Antidepressants for non-specific low back pain. Cochrane Database Syst Rev. 2010;(10).
140 Alcoff J, Jones E, Rust P, et al. Controlled trial of imipramine for chronic low back pain. J Fam Pract. 1982;14(5):841-6. [pmid: 6210751].
141 Atkinson JH, Slater MA, Capparelli EV, et al. Efficacy of noradrenergic and serotonergic antidepressants in chronic back pain: a preliminary concentration-controlled trial. J Clin Psychopharmacol. 2007;27(2):135-42. [pmid: 17414235].
142 Atkinson JH, Slater MA, Wahlgren DR, et al. Effects of noradrenergic and serotonergic antidepressants on chronic low back pain intensity. Pain. 1999;83(2):137-45. [pmid: 10534584].
143 Atkinson JH, Slater MA, Williams RA, et al. A placebo-controlled randomized clinical trial of nortriptyline for chronic low back pain. Pain. 1998;76(3):287-96. [pmid: 9718247].
144 Dickens C, Jayson M, Sutton C, et al. The relationship between pain and depression in a trial using paroxetine in sufferers of chronic low back pain. Psychosomatics. 2000;41(6):490-9. [pmid: 11110112].
145 Goodkin K, Gullion CM, Agras WS. A randomized, double-blind, placebo-controlled trial of trazodone hydrochloride in chronic low back pain syndrome. Journal of Clinical Psychopharmacology. 1990;10(4):269-78. [pmid: 2149565].
146 Jenkins DG, Ebbutt AF, Evans CD. Tofranil in the treatment of low back pain. J Int Med Res. 1976;4(2 Suppl):28-40. [pmid: 140827].
147 Katz J, Pennella-Vaughan J, Hetzel RD, et al. A randomized, placebo-controlled trial of bupropion sustained release in chronic low back pain. J Pain. 2005;6(10):656-61. [pmid: 16202958].
148 Pheasant H, Bursk A, Goldfarb J, et al. Amitriptyline and chronic low back pain: a randomized double-blind crossover study. Spine (Phila Pa 1976). 1983;8:552-7. [pmid: 6228015].
149 Treves R, Montaine de la Roque P, Dumond JJ, et al. Prospective study of the analgesic action of clomipramine versus placebo in refractory lumbosciatica (68 cases). Rev Rhum Mal Osteoartic. 1991;58(7):549-52. [pmid: 1833813].
150 Farajirad S, Behdani F, Hebrani P, et al. Comparison between the effects of amitriptyline and bupropione on the quality of life and the reduction in the severity of pain in patients with chronic low-back pain. Neurosurg Q. 2013;23(4):227-9.
151 Mazza M, Mazza O, Pazzaglia C, et al. Escitalopram 20 mg versus duloxetine 60 mg for the treatment of chronic low back pain. Expert Opin Pharmacother. 2010;11(7):1049-52. [pmid: 20402551].
152 Skljarevski V, Ossanna M, Liu-Seifert H, et al. A double-blind, randomized trial of duloxetine versus placebo in the management of chronic low back pain. Eur J Neurol. 2009;16(9):1041-8. [pmid: 19469829].
153 Skljarevski V, Zhang S, Desaiah D, et al. Duloxetine versus placebo in patients with chronic low back pain: a 12-week, fixed-dose, randomized, double-blind trial. J Pain. 2010;11(12):1282-90. [pmid: 20472510].
154 Skljarevski V, Desaiah D, Liu-Seifert H, et al. Efficacy and safety of duloxetine in patients with chronic low back pain. Spine. 2010;35(13):E578-85. [pmid: 20461028].
155 Schreiber S, Vinokur S, Shavelzon V, et al. A randomized trial of fluoxetine versus amitriptyline in musculo-skeletal pain. Isr J Psychiatr Rel. 2001;38(2):88-94. [pmid: 11475920].
156 Khoromi S, Patsalides A, Parada S, et al. Topiramate in chronic lumbar radicular pain. J Pain. 2005;6(12):829-36. [pmid: 16326371].
157 McCleane GJ. Does gabapentin have an analgesic effect on background, movement and referred pain? A randomised, double-blind, placebo controlled study. The Pain Clinic. 2001;13(2):103-7.
158 Muehlbacher M, Nickel MK, Kettler C, et al. Topiramate in treatment of patients with chronic low back pain: a randomized, double-blind, placebo-controlled study. Clin J Pain. 2006;22(6):526-31. [pmid: 16788338].
159 Yildirim K, Şışecıoğlu M, Karatay S, et al. The effectiveness of gabapentin in patients with chronic radiculopathy. The Pain Clinic. 2003;15(3):213-8.
160 Baron R, Freynhagen R, Tolle TR, et al. The efficacy and safety of pregabalin in the treatment of neuropathic pain associated with chronic lumbosacral radiculopathy. Pain. 2010;150(3):420-7. [pmid: 20493632].
161 Baron R, Martin-Mola E, Muller M, et al. Effectiveness and Safety of Tapentadol Prolonged Release (PR) Versus a Combination of Tapentadol PR and Pregabalin for the Management of Severe, Chronic Low Back Pain With a Neuropathic Component: A Randomized, Double-blind, Phase 3b Study. Pain pract. 2014. [pmid: 24738609].
162 Kalita J, Kohat AK, Misra UK, et al. An open labeled randomized controlled trial of pregabalin versus amitriptyline in chronic low backache. J Neurol Sci. 2014;342(1-2):127-32. [pmid: 24857356].
163 Markman JD, Frazer ME, Rast SA, et al. Double-blind, randomized, controlled, crossover trial of pregabalin for neurogenic claudication. Neurology. 2014. [pmid: 25503625].
164 Pota V, Barbarisi M, Sansone P, et al. Combination therapy with transdermal buprenorphine and pregabalin for chronic low back pain. Pain manag. 2012;2(1):23-31. [pmid: 24654615].
165 Romano CL, Romano D, Bonora C, et al. Pregabalin, celecoxib, and their combination for treatment of chronic low-back pain. J Orthop Trauma. 2009;10(4):185-91. [pmid: 19921480].
166 Yaksi A, Ozgonenel L, Ozgonenel B. The efficiency of gabapentin therapy in patients with lumbar spinal stenosis. Spine. 2007;32(9):939-42. [pmid: 17450066].
167 Atkinson J, Slater M, Patel S, et al. Gabapentin for chronic back pain: a randomized clinical trial. J Pain. 2010;11(4, Supplement):S37.
168 Finckh A, Zufferey P, Schurch MA, et al. Short-term efficacy of intravenous pulse glucocorticoids in acute discogenic sciatica. A randomized controlled trial. Spine (Phila Pa 1976). 2006;31(4):377-81. [pmid: 16481946].
169 Friedman BW, Holden L, Esses D, et al. Parenteral corticosteroids for Emergency Department patients with non-radicular low back pain. J Emerg Med. 2006;31(4):365-70. [pmid: 17046475].
170 Haimovic IC, Beresford HR. Dexamethasone is not superior to placebo for treating lumbosacral radicular pain. Neurology. 1986;36(12):1593-4. [pmid: 2946981].
171 Porsman O, Friis H. Prolapsed lumbar disc treated with intramuscularly administered dexamethasonephosphate. A prospectively planned, double-blind, controlled clinical trial in 52 patients. Scand J Rheumatol. 1979;8(3):142-4. [pmid: 386492].
172 Eskin B, Shih RD, Fiesseler FW, et al. Prednisone for emergency department low back pain: a randomized controlled trial. J Emerg Med. 2014;47(1):65-70. [pmid: 24739318].
173 Friedman BW, Esses D, Solorzano C, et al. A randomized placebo-controlled trial of single-dose IM corticosteroid for radicular low back pain. Spine. 2008;33(18):E624-9. [pmid: 18665021].
174 Holve RL, Barkan H. Oral steroids in initial treatment of acute sciatica. J Am Board Fam Med. 2008;21(5):469-74. [pmid: 18772303].
175 Rodrigues LCL, Natour J. A double-blind, randomized controlled, prospective trial assessing the effectiveness of oral corticoids in the treatment of symptomatic lumbar canal stenosis. J Negat Results Biomed. 2014;13:13. [pmid: 25099318].
176 Hedeboe J, Buhl M, Ramsing P. Effects of using dexamethasone and placebo in the treatment of prolapsed lumbar disc. Acta Neurol Scand. 1982;65(1):6-10. [pmid: 7039210].
177 Hofferberth B, Gottschaldt M, Grass H, et al. The usefulness of dexamethasonephosphate in the conservative treatment of lumbar pain--a double-blind study (author's transl). Arch Psychiatr Nervenkr. 1982;231(4):359-67. [pmid: 6214237].
178 Clare HA, Adams R, Maher CG. A systematic review of efficacy of McKenzie therapy for spinal pain. Aust J Physiother. 2004;50(4):209-16. [pmid: 15574109].
179 Hayden JA, van Tulder MW, Malmivaara A, et al. Exercise therapy for treatment of non-specific low back pain. Cochrane Database Syst Rev. 2005;(3). [pmid: 16034851].
180 Hayden JA, van Tulder MW, Malmivaara AV, et al. Meta-analysis: exercise therapy for nonspecific low back pain. Ann Intern Med. 2005;142(9):765-75. [pmid: 15867409].
181 Kool J, de Bie R, Oesch P, et al. Exercise reduces sick leave in patients with non-acute non-specific low back pain: a meta-analysis. J Rehabil Med. 2004;36(2):49-62. [pmid: 15180219].
182 Liddle SD, Baxter GD, Gracey JH. Exercise and chronic low back pain: what works?. Pain. 2004;107(1-2):176-90. [pmid: 14715404].
183 Machado LA, de Souza M, Ferreira PH, et al. The McKenzie method for low back pain: a systematic review of the literature with a meta-analysis approach. Spine (Phila Pa 1976). 2006;31(9):E254-62. [pmid: 16641766].
184 McNeely ML, Torrance G, Magee DJ. A systematic review of physiotherapy for spondylolysis and spondylolisthesis. Man Ther. 2003;8(2):80-91. [pmid: 12890435].
185 UK BEAM Trial Team. United Kingdom back pain exercise and manipulation (UK BEAM) randomised trial: effectiveness of physical treatments for back pain in primary care. BMJ. 2004;329(7479):1377. [pmid: 15556955].
186 Bystrom MG, Rasmussen-Barr E, Grooten WJA. Motor control exercises reduces pain and disability in chronic and recurrent low back pain: a meta-analysis. Spine. 2013;38(6):E350-8. [pmid: 23492976].
187 van Middelkoop M, Rubinstein SM, Verhagen AP, et al. Exercise therapy for chronic nonspecific low-back pain. Baillieres Best Pract Res Clin Rheumatol. 2010;24(2):193-204. [pmid: 20227641].
188 Oesch P, Kool J, Hagen KB, et al. Effectiveness of exercise on work disability in patients with non-acute non-specific low back pain: Systematic review and meta-analysis of randomised controlled trials. J Rehabil Med. 2010;42(3):193-205. [pmid: 20411212].
189 Alexandre NM, de Moraes MA, Correa Filho HR, et al. Evaluation of a program to reduce back pain in nursing personnel. Rev Saude Publica. 2001;35(4):356-61. [pmid: 11600924].
190 Donzelli S, Di Domenica E, Cova AM, et al. Two different techniques in the rehabilitation treatment of low back pain: a randomized controlled trial. Eura Medicophys. 2006;42(3):205-10. [pmid: 17039216].
191 Elnaggar IM, Nordin M, Sheikhzadeh A, et al. Effects of spinal flexion and extension exercises on low-back pain and spinal mobility in chronic mechanical low-back pain patients. Spine (Phila Pa 1976). 1991;16(8):967-72. [pmid: 1835157].
192 Ferreira ML, Ferreira PH, Latimer J, et al. Comparison of general exercise, motor control exercise and spinal manipulative therapy for chronic low back pain: A randomized trial. Pain. 2007;131(1-2):31-7. [pmid: 17250965].
193 Frost H, Lamb SE, Doll HA, et al. Randomised controlled trial of physiotherapy compared with advice for low back pain. BMJ. 2004;329(7468):708. [pmid: 15377573].
194 Galantino ML, Bzdewka TM, Eissler-Russo JL, et al. The impact of modified Hatha yoga on chronic low back pain: a pilot study. Altern Ther Health Med. 2004;10(2):56-9. [pmid: 15055095].
195 Gladwell V, Head S, Haggar M, et al. Does a Program of Pilates Improve Chronic Non-Specific Low Back Pain?. J Sport Rehabil. 2006;15(4):338-50. [pmid: 23128349].
196 Goldby LJ, Moore AP, Doust J, et al. A randomized controlled trial investigating the efficiency of musculoskeletal physiotherapy on chronic low back disorder. Spine (Phila Pa 1976). 2006;31(10):1083-93. [pmid: 16648741].
197 Harts CC, Helmhout PH, de Bie RA, et al. A high-intensity lumbar extensor strengthening program is little better than a low-intensity program or a waiting list control group for chronic low back pain: a randomised clinical trial. Aust J Physiother. 2008;54(1):23-31. [pmid: 18298356].
198 Hildebrandt VH, Proper KI, van den Berg R, et al. Cesar therapy is temporarily more effective in patients with chronic low back pain than the standard treatment by family practitioner: randomized, controlled and blinded clinical trial with 1 year follow-up. Ned Tijdschr Geneeskd. 2000;144(47):2258-64. [pmid: 11109471].
199 Johannsen F, Remvig L, Kryger P, et al. Exercises for chronic low back pain: a clinical trial. J Orthop Sports Phys Ther. 1995;22(2):52-9. [pmid: 7581431].
200 Koldas Dogan S, Sonel Tur B, Kurtais Y, et al. Comparison of three different approaches in the treatment of chronic low back pain. Clin Rheumatol. 2008;27(7):873-81. [pmid: 18188660].
201 Lewis JS, Hewitt JS, Billington L, et al. A randomized clinical trial comparing two physiotherapy interventions for chronic low back pain. Spine (Phila Pa 1976). 2005;30(7):711-21. [pmid: 15803071].
202 Mannion AF, Muntener M, Taimela S, et al. A randomized clinical trial of three active therapies for chronic low back pain. Spine (Phila Pa 1976). 1999;24(23):2435-48. [pmid: 10626305].
203 Niemisto L, Lahtinen-Suopanki T, Rissanen P, et al. A randomized trial of combined manipulation, stabilizing exercises, and physician consultation compared to physician consultation alone for chronic low back pain. Spine (Phila Pa 1976). 2003;28(19):2185-91. [pmid: 14520029].
204 Risch SV, Norvell NK, Pollock ML, et al. Lumbar strengthening in chronic low back pain patients. Physiologic and psychological benefits. Spine (Phila Pa 1976). 1993;18(2):232-8. [pmid: 8185727].
205 Rittweger J, Just K, Kautzsch K, et al. Treatment of chronic lower back pain with lumbar extension and whole-body vibration exercise: a randomized controlled trial. Spine (Phila Pa 1976). 2002;27(17):1829-34. [pmid: 12221343].
206 Roche G, Ponthieux A, Parot-Shinkel E, et al. Comparison of a functional restoration program with active individual physical therapy for patients with chronic low back pain: a randomized controlled trial. Arch Phys Med Rehabil. 2007;88(10):1229-35. [pmid: 17908562].
207 Sherman KJ, Cherkin DC, Erro J, et al. Comparing yoga, exercise, and a self-care book for chronic low back pain: a randomized, controlled trial. Ann Intern Med. 2005;143(12):849-56. [pmid: 16365466].
208 Sjogren T, Nissinen KJ, Jarvenpaa SK, et al. Effects of a workplace physical exercise intervention on the intensity of headache and neck and shoulder symptoms and upper extremity muscular strength of office workers: a cluster randomized controlled cross-over trial. Pain. 2005;116(1-2):119-28. [pmid: 15927388].
209 Smeets RJ, Vlaeyen JW, Hidding A, et al. Active rehabilitation for chronic low back pain: cognitive-behavioral, physical, or both? First direct post-treatment results from a randomized controlled trial [ISRCTN22714229]. BMC Musculoskelet Disord. 2006;7:5. [pmid: 16426449].
210 Tekur P, Singphow C, Nagendra HR, et al. Effect of short-term intensive yoga program on pain, functional disability and spinal flexibility in chronic low back pain: a randomized control study. J Altern Complement Med. 2008;14(6):637-44. [pmid: 18673078].
211 Tritilanunt T, Wajanavisit W. The efficacy of an aerobic exercise and health education program for treatment of chronic low back pain. J Med Assoc Thai. Suppl 2. 2001;84:S528-33. [pmid: 11853276].
212 Turner JA, Clancy S, McQuade KJ, et al. Effectiveness of behavioral therapy for chronic low back pain: a component analysis. J Consult Clin Psychol. 1990;58(5):573-9. [pmid: 2147702].
213 Williams KA, Petronis J, Smith D, et al. Effect of Iyengar yoga therapy for chronic low back pain. Pain. 2005;115(1-2):107-17. [pmid: 15836974].
214 Yelland MJ, Glasziou PP, Bogduk N, et al. Prolotherapy injections, saline injections, and exercises for chronic low-back pain: a randomized trial. Spine (Phila Pa 1976). 2004;29(1):9-16. discussion. [pmid: 14699269].
215 Yozbatiran N, Yildirim Y, Parlak B. Effects of fitness and aquafitness exercises on physical fitness in patients with chronic low back pain. The Pain Clinic. 2004;16(1):35-42.
216 Niemisto L, Rissanen P, Sarna S, et al. Cost-effectiveness of combined manipulation, stabilizing exercises, and physician consultation compared to physician consultation alone for chronic low back pain: a prospective randomized trial with 2-year follow-up. Spine (Phila Pa 1976). 2005;30(10):1109-15. [pmid: 15897822].
217 Alaranta H, Rytokoski U, Rissanen A, et al. Intensive physical and psychosocial training program for patients with chronic low back pain. A controlled clinical trial. Spine (Phila Pa 1976). 1994;19(12):1339-49. [pmid: 8066514].
218 Bendix AF, Bendix T, Ostenfeld S, et al. Active treatment programs for patients with chronic low back pain: a prospective, randomized, observer-blinded study. Eur Spine J. 1995;4(3):148-52. [pmid: 7552649].
219 Bendix AF, Bendix T, Vaegter K, et al. Multidisciplinary intensive treatment for chronic low back pain: a randomized, prospective study. Cleve Clin J Med. 1996;63(1):62-9. [pmid: 8590519].
220 Bendix T, Bendix A, Labriola M, et al. Functional restoration versus outpatient physical training in chronic low back pain: a randomized comparative study. Spine (Phila Pa 1976). 2000;25(19):2494-500. [pmid: 11013502].
221 Harkapaa K, Jarvikoski A, Mellin G, et al. A controlled study on the outcome of inpatient and outpatient treatment of low back pain. Part I. Pain, disability, compliance, and reported treatment benefits three months after treatment. Scand J Rehabil Med. 1989;21(2):81-9. [pmid: 2526364].
222 Hurri H. The Swedish back school in chronic low back pain. Part I. Benefits. Scand J Rehabil Med. 1989;21(1):33-40. [pmid: 2523558].
223 Jousset N, Fanello S, Bontoux L, et al. Effects of functional restoration versus 3 hours per week physical therapy: a randomized controlled study. Spine (Phila Pa 1976). 2004;29(5):487-93. discussion 94. [pmid: 15129059].
224 White AW. Low back pain in men receiving workmen's compensation. Can Med Assoc J. 1966;95(2):50-6. [pmid: 4222996].
225 Ferreira PH, Ferreira ML, Maher CG, et al. Specific stabilisation exercise for spinal and pelvic pain: A systematic review. Aust J Physiother. 2006;52(2):79-88. PMID. [pmid: 16764545].
226 Franca FR, Burke TN, Hanada ES, et al. Segmental stabilization and muscular strengthening in chronic low back pain: a comparative study. Clinics. 2010;65(10):1013-7. [pmid: 21120303].
227 Rasmussen-Barr E, Ang B, Arvidsson I, et al. Graded exercise for recurrent low-back pain: a randomized, controlled trial with 6-, 12-, and 36-month follow-ups. Spine. 2009;34(3):221-8. [pmid: 19179916].
228 Unsgaard-Tondel M, Fladmark AM, Salvesen O, et al. Motor control exercises, sling exercises, and general exercises for patients with chronic low back pain: a randomized controlled trial with 1-year follow-up. Phys Ther. 2010;90(10):1426-40. [pmid: 20671099].
229 Akbari A, Khorashadizadeh S, Abdi G. The effect of motor control exercise versus general exercise on lumbar local stabilizing muscles thickness: Randomized controlled trial of patients with chronic low back pain. J Back Musculoskeletal Rehabil. 2008;21(2):105-12.
230 Critchley DJ, Ratcliffe J, Noonan S, et al. Effectiveness and cost-effectiveness of three types of physiotherapy used to reduce chronic low back pain disability: a pragmatic randomized trial with economic evaluation. Spine. 2007;32(14):1474-81. [pmid: 17572614].
231 Miller ER, Schenk RJ, Karnes JL, et al. A comparison of the McKenzie approach to a specific spine stabilization program for chronic low back pain. J Manual Manipulative Ther. 2005;13(2):103-12.
232 Costa LOP, Maher CG, Latimer J, et al. Motor control exercise for chronic low back pain: a randomized placebo-controlled trial. Phys Ther. 2009;89(12):1275-86. [pmid: 19892856].
233 Shaughnessy M, Caulfield B. A pilot study to investigate the effect of lumbar stabilisation exercise training on functional ability and quality of life in patients with chronic low back pain. Int J Rehabil Res. 2004;27(4):297-301. [pmid: 15572993].
234 Kumar S, Sharma VP, Shukla R, et al. Comparative efficacy of two multimodal treatments on male and female sub-groups with low back pain (part II). J Back Musculoskeletal Rehabil. 2010;23(1):1-9. [pmid: 20231783].
235 O'Sullivan PB, Phyty GD, Twomey LT, et al. Evaluation of specific stabilizing exercise in the treatment of chronic low back pain with radiologic diagnosis of spondylolysis or spondylolisthesis. Spine (Phila Pa 1976). 1997;22(24):2959-67. [pmid: 9431633].
236 Kumar S, Negi MPS, Sharma VP, et al. Efficacy of two multimodal treatments on physical strength of occupationally subgrouped male with low back pain. J Back Musculoskeletal Rehabil. 2009;22(3):179-88. [pmid: 20023348].
237 Koumantakis GA, Watson PJ, Oldham JA. Trunk muscle stabilization training plus general exercise versus general exercise only: randomized controlled trial of patients with recurrent low back pain. Phys Ther. 2005;85(3):209-25. [pmid: 15733046].
238 Cairns MC, Foster NE, Wright C. Randomized controlled trial of specific spinal stabilization exercises and conventional physiotherapy for recurrent low back pain. Spine (Phila Pa 1976). 2006;31(19):E670-81. [pmid: 16946640].
239 Albaladejo C, Kovacs FM, Royuela A, et al. The efficacy of a short education program and a short physiotherapy program for treating low back pain in primary care: a cluster randomized trial. Spine. 2010;35(5):483-96. [pmid: 20147875].
240 Albert HB, Manniche C. The efficacy of systematic active conservative treatment for patients with severe sciatica: a single-blind, randomized, clinical, controlled trial. Spine. 2012;37(7):531-42. [pmid: 21494193].
241 Bronfort G, Maiers MJ, Evans RL, et al. Supervised exercise, spinal manipulation, and home exercise for chronic low back pain: a randomized clinical trial. Spine J. 2011;11(7):585-98. [pmid: 21622028].
242 Garcia AN, Costa LdCM, da Silva TM, et al. Effectiveness of back school versus McKenzie exercises in patients with chronic nonspecific low back pain: a randomized controlled trial. Phys Ther. 2013;93(6):729-47. [pmid: 23431213].
243 George SZ, Zeppieri G Jr., Cere AL, et al. A randomized trial of behavioral physical therapy interventions for acute and sub-acute low back pain (NCT00373867). Pain. 2008;140(1):145-57. [pmid: 18786762].
244 Hagen EM, Odelien KH, Lie SA, et al. Adding a physical exercise programme to brief intervention for low back pain patients did not increase return to work. Scand J Public Health. 2010;38(7):731-8. [pmid: 20817653].
245 Hartvigsen J, Morso L, Bendix T, et al. Supervised and non-supervised Nordic walking in the treatment of chronic low back pain: a single blind randomized clinical trial. BMC Musculoskelet Disord. 2010;11:30. [pmid: 20146793].
246 Helmhout PH, Harts CC, Viechtbauer W, et al. Isolated lumbar extensor strengthening versus regular physical therapy in an army working population with nonacute low back pain: a randomized controlled trial. Arch Phys Med Rehabil. 2008;89(9):1675-85. [pmid: 18675396].
247 Henchoz Y, de Goumoens P, So AKL, et al. Functional multidisciplinary rehabilitation versus outpatient physiotherapy for non specific low back pain: randomized controlled trial. Swiss Med Wkly. 2010;140:w13133. [pmid: 21181567].
248 Hofstee DJ, Gijtenbeek JM, Hoogland PH, et al. Westeinde sciatica trial: randomized controlled study of bed rest and physiotherapy for acute sciatica. J Neurosurg. 2002;96(1 Suppl):45-9. [pmid: 11797655].
249 Hurley DA, Tully MA, Lonsdale C, et al. Supervised walking in comparison with fitness training for chronic back pain in physiotherapy: results of the SWIFT single-blinded randomized controlled trial (ISRCTN17592092). Pain. 2015;156(1):131-47. [pmid: 25599309].
250 Jensen RK, Leboeuf-Yde C, Wedderkopp N, et al. Rest versus exercise as treatment for patients with low back pain and Modic changes. A randomized controlled clinical trial. BMC Med. 2012;10:22. [pmid: 22376791].
251 Kell RT, Risi AD, Barden JM. The response of persons with chronic nonspecific low back pain to three different volumes of periodized musculoskeletal rehabilitation. J Strength Cond Res. 2011;25(4):1052-64. [pmid: 20647943].
252 Little P, Lewith G, Webley F, et al. Randomised controlled trial of Alexander technique lessons, exercise, and massage (ATEAM) for chronic and recurrent back pain. Br J Sports Med. 2008;42(12):965-8. [pmid: 19096019].
253 Macedo LG, Latimer J, Maher CG, et al. Effect of motor control exercises versus graded activity in patients with chronic nonspecific low back pain: a randomized controlled trial. [Erratum appears in Phys Ther. 2012 Apr;92(4):631]. Phys Ther. 2012;92(3):363-77. [pmid: 22135712].
254 Machado LAC, Maher CG, Herbert RD, et al. The effectiveness of the McKenzie method in addition to first-line care for acute low back pain: a randomized controlled trial. BMC Med. 2010;8:10. [pmid: 20102596].
255 Pengel LHM, Refshauge KM, Maher CG, et al. Physiotherapist-directed exercise, advice, or both for subacute low back pain: a randomized trial. [Summary for patients in Ann Intern Med. 2007 Jun 5;146(11):I56; PMID: 17548406]. Ann Intern Med. 2007;146(11):787-96. [pmid: 17548410].
256 Henchoz Y, de Goumoens P, Norberg M, et al. Role of physical exercise in low back pain rehabilitation: a randomized controlled trial of a three-month exercise program in patients who have completed multidisciplinary rehabilitation. Spine. 2010;35(12):1192-9. [pmid: 20098350].
257 Bi X, Zhao J, Zhao L, et al. Pelvic floor muscle exercise for chronic low back pain. J Int Med Res. 2013;41(1):146-52. [pmid: 23569140].
258 Bruce-Low S, Smith D, Burnet S, et al. One lumbar extension training session per week is sufficient for strength gains and reductions in pain in patients with chronic low back pain ergonomics. Ergonomics. 2012;55(4):500-7. [pmid: 22397454].
259 Chan CW, Mok NW, Yeung EW. Aerobic exercise training in addition to conventional physiotherapy for chronic low back pain: a randomized controlled trial. Arch Phys Med Rehabil. 2011;92(10):1681-5. [pmid: 21839983].
260 Jackson JK, Shepherd TR, Kell RT. The influence of periodized resistance training on recreationally active males with chronic nonspecific low back pain. J Strength Cond Res. 2011;25(1):242-51. [pmid: 20093971].
261 Kell RT, Asmundson GJG. A comparison of two forms of periodized exercise rehabilitation programs in the management of chronic nonspecific low-back pain. J Strength Cond Res. 2009;23(2):513-23. [pmid: 19209082].
262 Marshall P, Murphy B. Self-report measures best explain changes in disability compared with physical measures after exercise rehabilitation for chronic low back pain. Spine. 2008;33(3):326-38. [pmid: 18303467].
263 Masharawi Y, Nadaf N. The effect of non-weight bearing group-exercising on females with non-specific chronic low back pain: a randomized single blind controlled pilot study. J Back Musculoskeletal Rehabil. 2013;26(4):353-9. [pmid: 23948819].
264 McDonough SM, Tully MA, Boyd A, et al. Pedometer-driven walking for chronic low back pain: a feasibility randomized controlled trial. Clin J Pain. 2013;29(11):972-81. [pmid: 23446066].
265 Mohseni-Bandpei MA, Rahmani N, Behtash H, et al. The effect of pelvic floor muscle exercise on women with chronic non-specific low back pain. J Bodywork Mov Ther. 2011;15(1):75-81. [pmid: 21147422].
266 Nassif H, Brosset N, Guillaume M, et al. Evaluation of a randomized controlled trial in the management of chronic lower back pain in a French automotive industry: an observational study. Arch Phys Med Rehabil. 2011;92(12):1927-36.e4. [pmid: 22133239].
267 Norris C, Matthews M. The role of an integrated back stability program in patients with chronic low back pain. Complement Ther Clin Pract. 2008;14(4):255-63. [pmid: 18940712].
268 Rhee HS, Kim YH, Sung PS. A randomized controlled trial to determine the effect of spinal stabilization exercise intervention based on pain level and standing balance differences in patients with low back pain. Med Sci Monit. 2012;18(3):CR174-81. [pmid: 22367128].
269 Schenkman ML, Jordan S, Akuthota V, et al. Functional movement training for recurrent low back pain: lessons from a pilot randomized controlled trial. Pm R. 2009;1(2):137-46. [pmid: 19627887].
270 Smith D, Bissell G, Bruce-Low S, et al. The effect of lumbar extension training with and without pelvic stabilization on lumbar strength and low back pain. J Back Musculoskeletal Rehabil. 2011;24(4):241-9. [pmid: 22142713].
271 Steele J, Bruce-Low S, Smith D, et al. A randomized controlled trial of limited range of motion lumbar extension exercise in chronic low back pain. Spine. 2013;38(15):1245-52. [pmid: 23514876].
272 Tsauo J-Y, Chen W-H, Liang H-W, et al. The effectiveness of a functional training programme for patients with chronic low back pain--a pilot study. Disabil Rehabil. 2009;31(13):1100-6. [pmid: 19802926].
273 Aasa B, Berglund L, Michaelson P, et al. Individualized low-load motor control exercises and education versus a high-load lifting exercise and education to improve activity, pain intensity, and physical performance in patients with low back pain: a randomized controlled trial. J Orthop Sports Phys Ther. 2015;45(2):77-85. B1. 4. [pmid: 25641309].
274 Aluko A, DeSouza L, Peacock J. The effect of core stability exercises on variations in acceleration of trunk movement, pain, and disability during an episode of acute nonspecific low back pain: a pilot clinical trial. J Manipulative Physiol Ther. 2013;36(8):497-504.e1-3. [pmid: 23948426].
275 Bonetti F, Curti S, Mattioli S, et al. Effectiveness of a ‘Global Postural Reeducation’ program for persistent low back pain: a non-randomized controlled trial. BMC Musculoskelet Disord. 2010;11:285. [pmid: 21162726].
276 Engbert K, Weber M. The effects of therapeutic climbing in patients with chronic low back pain: a randomized controlled study. Spine. 2011;36(11):842-9. [pmid: 21192296].
277 Gatti R, Faccendini S, Tettamanti A, et al. Efficacy of trunk balance exercises for individuals with chronic low back pain: a randomized clinical trial. J Orthop Sports Phys Ther. 2011;41(8):542-52. [pmid: 21654092].
278 George SZ, Wittmer VT, Fillingim RB, et al. Comparison of graded exercise and graded exposure clinical outcomes for patients with chronic low back pain. J Orthop Sports Phys Ther. 2010;40(11):694-704. [pmid: 20972340].
279 Inani SB, Selkar SP. Effect of core stabilization exercises versus conventional exercises on pain and functional status in patients with non-specific low back pain: a randomized clinical trial. J Back Musculoskeletal Rehabil. 2013;26(1):37-43. [pmid: 23411647].
280 Javadian Y, Behtash H, Akbari M, et al. The effects of stabilizing exercises on pain and disability of patients with lumbar segmental instability. J Back Musculoskeletal Rehabil. 2012;25(3):149-55. [pmid: 22935853].
281 Mbada CE, Ayanniyi O, Ogunlade SO, et al. Influence of Mckenzie protocol and two modes of endurance exercises on health-related quality of life of patients with long-term mechanical low-back pain. Pan Afr Med J. Suppl 1. 2014;17:5. [pmid: 24624241].
282 Sertpoyraz F, Eyigor S, Karapolat H, et al. Comparison of isokinetic exercise versus standard exercise training in patients with chronic low back pain: a randomized controlled study. Clin Rehabil. 2009;23(3):238-47. [pmid: 19218298].
283 Hayden JA, van Tulder MW, Tomlinson G. Systematic Review: Strategies for Using Exercise Therapy To Improve Outcomes in Chronic Low Back Pain. Ann Intern Med. 2005;142(9):776-85. [pmid: 15867410].
284 Pua Y-H, Cai C-C, Lim K-C. Treadmill walking with body weight support is no more effective than cycling when added to an exercise program for lumbar spinal stenosis: a randomised controlled trial. Aust J Physiother. 2007;53(2):83-9. [pmid: 17535143].
285 Hall AM, Maher CG, Lam P, et al. Tai chi exercise for treatment of pain and disability in people with persistent low back pain: a randomized controlled trial. Arthritis Care Res (Hoboken). 2011;63(11):1576-83. [pmid: 22034119].
286 Wells C, Kolt GS, Marshall P, et al. The effectiveness of pilates exercise in people with chronic low back pain: a systematic review. PLoS ONE. 2014;9(7):e100402. [pmid: 24984069].
287 Borges J, Baptista AF, Santana N, et al. Pilates exercises improve low back pain and quality of life in patients with HTLV-1 virus: a randomized crossover clinical trial. J Bodyw Mov Ther. 2014;18(1):68-74. [pmid: 24411152].
288 da Fonseca JL, Magini M, de Freitas TH. Laboratory gait analysis in patients with low back pain before and after a pilates intervention. J Sport Rehabil. 2009;18(2):269-82. [pmid: 19561369].
289 MacIntyre L. The effect of Pilates on patients' chronic low back pain: A pilot study [dissertation]. 2006.
290 Miyamoto GC, Costa LO, Galvanin T, et al. Efficacy of the addition of modified Pilates exercises to a minimal intervention in patients with chronic low back pain: a randomized controlled trial. Phys Ther. 2013;93(3):310-20. [pmid: 23064732].
291 Quinn K, Barry S, Barry L. Do patients with chronic low back pain benefit from attending Pilates classes after completing conventional physiotherapy treatment?. Physiother Pract Res. 2011;32(1):5-12.
292 Rydeard R. Evaluation of a targeted exercise rehabilitation approach and its effectiveness in the treatment of pain, functional disability and muscle function in a population with longstanding unresolved low back pain [dissertation]. Kingston, Canada. Queens University. 2001.
293 Gagnon L. Efficacy of pilates exercises as therapeutic intervention in treating patients with low back pain [dissertation] [dissertation]. Knoxville. University of Tennessee. 2005.
294 Marshall PWM, Kennedy S, Brooks C, et al. Pilates exercise or stationary cycling for chronic nonspecific low back pain: does it matter? a randomized controlled trial with 6-month follow-up. Spine. 2013;38(15):E952-9. [pmid: 23615384].
295 Rajpal N, Arora M, Chauhan V. The study on efficacy of Pilates and McKenzie exercise in postural low back pain –A rehabilitative protocol. Physiotherapy and Occupational Therapy Journal. 2008;1:33-56.
296 Wajswelner H, Metcalf B, Bennell K. Clinical pilates versus general exercise for chronic low back pain: randomized trial. Med Sci Sports Exerc. 2012;44(7):1197-205. [pmid: 22246216].
297 Quinn F. Influence of Pilates-based mat exercise on chronic lower back pain [dissertation]. 2005.
298 Zeada M. Effects of Pilates on low back pain and urine catecholamine. Ovidius University Annals, Series Physiotherapy Education and Sport. 2011;(12):41-7.
299 Weifen W, Muheremu A, Chaohui C, et al. Effectiveness of tai chi practice for non-specific chronic low back pain on retired athletes: A randomized controlled study. J Musculoskelet Pain. 2013;21(1):37-45.
300 Cramer H, Lauche R, Haller H, et al. A systematic review and meta-analysis of yoga for low back pain. Clin J Pain. 2013;29(5):450-60. [pmid: 23246998].
301 Cox H, Tilbrook H, Aplin J, et al. A randomised controlled trial of yoga for the treatment of chronic low back pain: results of a pilot study. Complement Ther Clin Pract. 2010;16(4):187-93. [pmid: 20920800].
302 Pushpika Attanayake AM, Somarathna KIWK, Vyas GH, et al. Clinical evaluation of selected Yogic procedures in individuals with low back pain. Ayu. 2010;31(2):245-50. [pmid: 22131719].
303 Saper RB, Sherman KJ, Cullum-Dugan D, et al. Yoga for chronic low back pain in a predominantly minority population: a pilot randomized controlled trial. Altern Ther Health Med. 2009;15(6):18-27. [pmid: 19943573].
304 Sherman KJ, Cherkin DC, Wellman RD, et al. A randomized trial comparing yoga, stretching, and a self-care book for chronic low back pain. Arch Intern Med. 2011;171(22):2019-26. [pmid: 22025101].
305 Tilbrook HE, Cox H, Hewitt CE, et al. Yoga for chronic low back pain: a randomized trial. Ann Intern Med. 2011;155(9):569-78. [pmid: 22041945].
306 Williams K, Abildso C, Steinberg L, et al. Evaluation of the effectiveness and efficacy of Iyengar yoga therapy on chronic low back pain. Spine. 2009;34(19):2066-76. [pmid: 19701112].
307 Nambi GS, Inbasekaran D, Khuman R, et al. Changes in pain intensity and health related quality of life with Iyengar yoga in nonspecific chronic low back pain: A randomized controlled study. Int J Yoga. 2014;7(1):48-53. [pmid: 25035607].
308 Saper RB, Boah AR, Keosaian J, et al. Comparing Once- versus Twice-Weekly Yoga Classes for Chronic Low Back Pain in Predominantly Low Income Minorities: A Randomized Dosing Trial. Evid Based Complement Alternat Med. 2013;2013:658030. [pmid: 23878604].
309 Tekur P, Nagarathna R, Chametcha S, et al. A comprehensive yoga programs improves pain, anxiety and depression in chronic low back pain patients more than exercise: an RCT. Complement Ther Med. 2012;20(3):107-18. [pmid: 22500659].
310 Tekur P, Chametcha S, Hongasandra RN, et al. Effect of yoga on quality of life of clbp patients: A randomized control study. Int J Yoga. 2010;3(1):10-7. [pmid: 20948896].
311 Hoffman BM, Papas RK, Chatkoff DK, et al. Meta-analysis of psychological interventions for chronic low back pain. Health Psychol. 2007;26(1):1-9. [pmid: 17209691].
312 Ostelo RW, van Tulder MW, Vlaeyen JW, et al. Behavioural treatment for chronic low-back pain. Cochrane Database Syst Rev. 2005;(1). CD002014. [pmid: 15674889].
313 Henschke N, Ostelo WJGR, van Tulder MW, et al. Behavioural treatment for chronic low-back pain. Cochrane Database Syst Rev. 2010;(2).
314 Khan M, Akhter S, Soomro RR, et al. The effectiveness of Cognitive Behavioral Therapy (CBT) with general exercises versus general exercises alone in the management of chronic low back pain. Pak. 2014;27(4 Suppl):1113-6. [pmid: 25016276].
315 Lamb SE, Hansen Z, Lall R, et al. Group cognitive behavioural treatment for low-back pain in primary care: a randomised controlled trial and cost-effectiveness analysis. Lancet. 2010;375(9718):916-23. [pmid: 20189241].
316 Lamb SE, Mistry D, Lall R, et al. Group cognitive behavioural interventions for low back pain in primary care: extended follow-up of the Back Skills Training Trial (ISRCTN54717854). Pain. 2012;153(2):494-501. [pmid: 22226729].
317 Siemonsma PC, Stuive I, Roorda LD, et al. Cognitive treatment of illness perceptions in patients with chronic low back pain: a randomized controlled trial. Phys Ther. 2013;93(4):435-48. [pmid: 23162040].
318 Vong SK, Cheing GL, Chan F, et al. Motivational enhancement therapy in addition to physical therapy improves motivational factors and treatment outcomes in people with low back pain: a randomized controlled trial. Arch Phys Med Rehabil. 2011;92(2):176-83. [pmid: 21272712].
319 Stuckey SJ, Jacobs A, Goldfarb J. EMG biofeedback training, relaxation training, and placebo for the relief of chronic back pain. Percept Mot Skills. 1986;63(3):1023-36. [pmid: 2949196].
320 Turner JA. Comparison of group progressive-relaxation training and cognitive-behavioral group therapy for chronic low back pain. J Consult Clin Psychol. 1982;50(5):757-65. [pmid: 6216275].
321 Turner JA, Jensen MP. Efficacy of cognitive therapy for chronic low back pain. Pain. 1993;52(2):169-77. [pmid: 8455964].
322 Newton-John TR, Spence SH, Schotte D. Cognitive-behavioural therapy versus EMG biofeedback in the treatment of chronic low back pain. Behav Res Ther. 1995;33(6):691-7. [pmid: 7654161].
323 Nouwen A. EMG biofeedback used to reduce standing levels of paraspinal muscle tension in chronic low back pain. Pain. 1983;17(4):353-60. [pmid: 6229707].
324 Bush C, Ditto B, Feuerstein M. A controlled evaluation of paraspinal EMG biofeedback in the treatment of chronic low back pain. Health Psychol. 1985;4(4):307-21. [pmid: 2932330].
325 Linton SJ, Bradley LA, Jensen I, et al. The secondary prevention of low back pain: a controlled study with follow-up. Pain. 1989;36(2):197-207. [pmid: 2521930].
326 Turner JA, Clancy S. Comparison of operant behavioral and cognitive-behavioral group treatment for chronic low back pain. J Consult Clin Psychol. 1988;56(2):261-6. [pmid: 2967314].
327 Linton SJ, Boersma K, Jansson M, et al. A randomized controlled trial of exposure in vivo for patients with spinal pain reporting fear of work-related activities. Eur J Pain. 2008;12(6):722-30. [pmid: 18155934].
328 Poole H, Glenn S, Murphy P. A randomised controlled study of reflexology for the management of chronic low back pain. Eur J Pain. 2007;11(8):878-87. [pmid: 17459741].
329 Von Korff M, Balderson BH, Saunders K, et al. A trial of an activating intervention for chronic back pain in primary care and physical therapy settings. Pain. 2005;113(3):323-30. [pmid: 15661440].
330 Donaldson S, Romney D, Donaldson M, et al. Randomized study of the application of single motor unit biofeedback training to chronic low back pain. J Occup Rehabil. 1994;4(1):23-37. [pmid: 24234261].
331 McCauley JD, Thelen MH, Frank RG, et al. Hypnosis compared to relaxation in the outpatient management of chronic low back pain. Arch Phys Med Rehabil. 1983;64(11):548-52. [pmid: 6227304].
332 van der Roer N, van Tulder M, Barendse J, et al. Intensive group training protocol versus guideline physiotherapy for patients with chronic low back pain: a randomised controlled trial. Eur Spine J. 2008;17(9):1193-200. [pmid: 18663487].
333 Friedrich M, Gittler G, Halberstadt Y, et al. Combined exercise and motivation program: effect on the compliance and level of disability of patients with chronic low back pain: a randomized controlled trial. Arch Phys Med Rehabil. 1998;79(5):475-87. [pmid: 9596385].
334 Nicholas MK, Wilson PH, Goyen J. Operant-behavioural and cognitive-behavioural treatment for chronic low back pain. Behav Res Ther. 1991;29(3):225-38. [pmid: 1831972].
335 Nicholas MK, Wilson PH, Goyen J. Comparison of cognitive-behavioral group treatment and an alternative non-psychological treatment for chronic low back pain. Pain. 1992;48(3):339-47. [pmid: 1534400].
336 Strong J. Incorporating cognitive-behavioral therapy with occupational therapy: A comparative study with patients with low back pain. J Occup Rehabil. 1998;8(1):61-71.
337 Altmaier EM, Lehmann TR, Russell DW, et al. The effectiveness of psychological interventions for the rehabilitation of low back pain: a randomized controlled trial evaluation. Pain. 1992;49(3):329-35. [pmid: 1408299].
338 Schweikert B, Jacobi E, Seitz R, et al. Effectiveness and cost-effectiveness of adding a cognitive behavioral treatment to the rehabilitation of chronic low back pain. J Rheumatol. 2006;33(12):2519-26. [pmid: 17143986].
339 Johnson RE, Jones GT, Wiles NJ, et al. Active exercise, education, and cognitive behavioral therapy for persistent disabling low back pain: a randomized controlled trial. Spine. 2007;32(15):1578-85. [pmid: 17621203].
340 Kole-Snijders AM, Vlaeyen JW, Goossens ME, et al. Chronic low-back pain: what does cognitive coping skills training add to operant behavioral treatment? Results of a randomized clinical trial. J Consult Clin Psychol. 1999;67(6):931-44. [pmid: 10596514].
341 van den Hout JHC, Vlaeyen JWS, Heuts PHTG, et al. Secondary Prevention of Work-Related Disability in Nonspecific Low Back Pain: Does Problem-Solving Therapy Help? A Randomized Clinical Trial. Clin J Pain. 2003;19(2):87-96. [pmid: 12616178].
342 Rose MJ, Reilly JP, Pennie B, et al. Chronic low back pain rehabilitation programs: a study of the optimum duration of treatment and a comparison of group and individual therapy. Spine (Phila Pa 1976). 1997;22(19):2246-51. discussion 52-3. [pmid: 9346145].
343 Leeuw M, Goossens MEJB, van Breukelen GJP, et al. Exposure in vivo versus operant graded activity in chronic low back pain patients: results of a randomized controlled trial. Pain. 2008;138(1):192-207. [pmid: 18242858].
344 Guzman J, Esmail R, Karjalainen K, et al. Multidisciplinary bio-psycho-social rehabilitation for chronic low back pain. Cochrane Database Syst Rev. 2002;(1). CD000963. [pmid: 11869581].
345 Guzman J, Esmail R, Karjalainen KA, et al. Multidisciplinary rehabilitation for chronic low-back pain: systematic review. BMJ. 2001;322. [pmid: 11420271].
346 Karjalainen KA, Malmivaara A, van Tulder MW, et al. Multidisciplinary biopsychosocial rehabilitation for subacute low-back pain among working age adults. Cochrane Database Syst Rev. 2009;(4).
347 Tveito TH, Hysing M, Eriksen HR. Low back pain interventions at the workplace: a systematic literature review. Occup Med (Lond). 2004;54(1):3-13. [pmid: 14963248].
348 Kamper SJ, Apeldoorn AT, Chiarotto A, et al. Multidisciplinary biopsychosocial rehabilitation for chronic low back pain. Cochrane Database Syst Rev. 2014;9. CD000963. [pmid: 25180773].
349 Eisenberg DM, Buring JE, Hrbek AL, et al. A model of integrative care for low-back pain. J Altern Complement Med. 2012;18(4):354-62. [pmid: 22455544].
350 Gatchel RJ, Polatin PB, Noe C, et al. Treatment- and cost-effectiveness of early intervention for acute low-back pain patients: a one-year prospective study. J Occup Rehabil. 2003;13(1):1-9. [pmid: 12611026].
351 Monticone M, Ambrosini E, Rocca B, et al. A multidisciplinary rehabilitation programme improves disability, kinesiophobia and walking ability in subjects with chronic low back pain: results of a randomised controlled pilot study. Eur Spine J. 2014;23(10):2105-13. [pmid: 25064093].
352 Skouen JS, Grasdal AL, Haldorsen EM, et al. Relative cost-effectiveness of extensive and light multidisciplinary treatment programs versus treatment as usual for patients with chronic low back pain on long-term sick leave: randomized controlled study. Spine (Phila Pa 1976). 2002;27(9):901-9. discussion 9-10. [pmid: 11979157].
353 Morone G, Paolucci T, Alcuri MR, et al. Quality of life improved by multidisciplinary back school program in patients with chronic non-specific low back pain: a single blind randomized controlled trial. Eur J Phys Rehabil Med. 2011;47(4):533-41. [pmid: 21508915].
354 Tavafian SS, Jamshidi AR, Montazeri A. A randomized study of back school in women with chronic low back pain: quality of life at three, six, and twelve months follow-up. Spine. 2008;33(15):1617-21. [pmid: 18580739].
355 Kool J, Bachmann S, Oesch P, et al. Function-centered rehabilitation increases work days in patients with nonacute nonspecific low back pain: 1-year results from a randomized controlled trial. Arch Phys Med Rehabil. 2007;88(9):1089-94. [pmid: 17826451].
356 Kaapa EH, Frantsi K, Sarna S, et al. Multidisciplinary group rehabilitation versus individual physiotherapy for chronic nonspecific low back pain: a randomized trial. Spine (Phila Pa 1976). 2006;31(4):371-6. [pmid: 16481945].
357 Smeets RJ, Severens JL, Beelen S, et al. More is not always better: cost-effectiveness analysis of combined, single behavioral and single physical rehabilitation programs for chronic low back pain. Eur J Pain. 2009;13(1):71-81. [pmid: 18434221].
358 Smeets RJEM, Vlaeyen JWS, Hidding A, et al. Chronic low back pain: physical training, graded activity with problem solving training, or both? The one-year post-treatment results of a randomized controlled trial. [Reprint in Ned Tijdschr Geneeskd. 2009 Mar 21;153(12):543-9; PMID: 19368107]. Pain. 2008;134:263-76. [pmid: 17498879].
359 Mangels M, Schwarz S, Worringen U, et al. Evaluation of a behavioral-medical inpatient rehabilitation treatment including booster sessions: a randomized controlled study. Clin J Pain. 2009;25(5):356-64. [pmid: 19454868].
360 Lambeek LC, van Mechelen W, Knol DL, et al. Randomised controlled trial of integrated care to reduce disability from chronic low back pain in working and private life. BMJ. 2010;340:c1035. [pmid: 20234040].
361 Cherkin DC, Sherman KJ, Deyo RA, et al. A review of the evidence for the effectiveness, safety, and cost of acupuncture, massage therapy, and spinal manipulation for back pain. Ann Intern Med. 2003;138(11):898-906. [pmid: 12779300].
362 Furlan AD, van Tulder MW, Cherkin DC, et al. Acupuncture and dry-needling for low back pain. Cochrane Database Syst Rev. 2005;(1). CD001351. [pmid: 15674876].
363 Manheimer E, White A, Berman B, et al. Meta-analysis: acupuncture for low back pain. Ann Intern Med. 2005;142(8):651-63. [pmid: 15838072].
364 Lee J-H, Choi T-Y, Lee MS, et al. Acupuncture for acute low back pain: a systematic review. Clin J Pain. 2013;29(2):172-85. [pmid: 23269281].
365 Lam M, Galvin R, Curry P. Effectiveness of acupuncture for nonspecific chronic low back pain: a systematic review and meta-analysis. Spine. 2013;38(24):2124-38. [pmid: 24026151].
366 Gao H, Wei C. Extrapoint acupuncture treatement of 36 cases of acute lumbar sprain. [in Chinese]. J Gansu Coll Trad Cin Med. 2006;2006(23):49-50.
367 Jin M, Chen J. Acupuncture treatment for 40 cases of acute lumbar sprain. [in Chinese]. J Gansu Coll Trad Chin Med. 2008;2006(23):49-50.
368 Lan J. Analysis of application of acupuncture analgesia in acute lumbar sprain. [in Chinese]. J Community Med. 2009;(7):68-9.
369 Wu Y-c, Zhang B-m, Wang C-m, et al. Observation on short-term and long-term therapeutic effects of electroacupuncture at Houxi (SI 3) on acute lumbar sprain. Zhongguo Zhen Jiu. 2007;27(1):3-5. [pmid: 17378192].
370 Zheng Z. Observations on the therapeutic effects of treating 90 cases of acute lumbar sprain by acupunctuing Xing Jian (LR2). [in Chinese]. J Community Med. 2005;1(7):68-9.
371 Su J-t, Zhou Q-h, Li R, et al. Immediate analgesic effect of wrist-ankle acupuncture for acute lumbago: a randomized controlled trial. Zhongguo zhenjiu. 2010;30(8):617-22. [pmid: 20942274].
372 Liu J, Li N. Clinical observation of a combination of acupuncture and drug administration for non-specific acute lumbar sprain. J Acupunct Tuina Sci. 2010;8(1):47-9.
373 Chen Y. Clinical observation of electroacupuncture at SI3 in addition to drug therapy in acute lumbar sprain. [in Chinese]. J Community Med. 2010;(8):39.
374 Kennedy S, Baxter GD, Kerr DP, et al. Acupuncture for acute non-specific low back pain: a pilot randomised non-penetrating sham controlled trial. Complement Ther Med. 2008;16(3):139-46. [pmid: 18534326].
375 Araki S, Kawamura O, Mataka T. Randomized controlled trial comparing the effect of manual acupuncture with sham acupuncture for acute low back pain. [in Japanese]. J Japan Soc Acupunct Moxibustion. 2001;2001(51):382.
376 Wu D, Guo X. Is the sham acupuncture group a real sham control group? Comments on “Vas J et al. Acupuncture in patients with acute low back pain: a multicentre randomised controlled clinical trial [PAIN 2012;153(9):1883-9]”. Pain. 2013;154(11):2575-6. [pmid: 23962589].
377 Kittang G, Melvaer T, Baerheim A. Acupuncture contra antiphlogistics in acute lumbago. Tidsskr Nor Laegeforen. 2001;121(10):1207-10. [pmid: 11402745].
378 Cherkin DC, Sherman KJ, Avins AL, et al. A randomized trial comparing acupuncture, simulated acupuncture, and usual care for chronic low back pain. Arch Intern Med. 2009;169(9):858-66. [pmid: 19433697].
379 Haake M, Muller H-H, Schade-Brittinger C, et al. German Acupuncture Trials (GERAC) for chronic low back pain: randomized, multicenter, blinded, parallel-group trial with 3 groups. [Erratum appears in Arch Intern Med. 2007 Oct 22;167(19):2072]. Arch Intern Med. 2007;167(17):1892-8. [pmid: 17893311].
380 Inoue M, Hojo T, Nakajima M, et al. Comparison of the effectiveness of acupuncture treatment and local anaesthetic injection for low back pain: a randomised controlled clinical trial. Acupunct Med. 2009;27(4):174-7. [pmid: 19942724].
381 Itoh K, Itoh S, Katsumi Y, et al. A pilot study on using acupuncture and transcutaneous electrical nerve stimulation to treat chronic non-specific low back pain. Complement Ther Clin Pract. 2009;15(1):22-5. [pmid: 19161950].
382 Shankar N, Thakur M, Tandon OP, et al. Autonomic status and pain profile in patients of chronic low back pain and following electro acupuncture therapy: a randomized control trial. Indian J Physiol Pharmacol. 2011;55(1):25-36. [pmid: 22315807].
383 Yun M, Shao Y, Zhang Y, et al. Hegu acupuncture for chronic low-back pain: a randomized controlled trial. J Altern Complement Med. 2012;18(2):130-6. [pmid: 22339101].
384 Witt CM, Manheimer E, Hammerschlag R, et al. How well do randomized trials inform decision making: systematic review using comparative effectiveness research measures on acupuncture for back pain. PLoS ONE. 2012;7(2):e32399. [pmid: 22389699].
385 Kerr DP, Walsh DM, Baxter D. Acupuncture in the management of chronic low back pain: a blinded randomized controlled trial. Clin J Pain. 2003;19(6):364-70. [pmid: 14600536].
386 Thomas KJ, MacPherson H, Thorpe L, et al. Randomized controlled trial of a short course of traditional acupuncture compared with usual care for persistent non-specific low back pain. J Accupunct Assoc Chartered Phys. 2007;3:47-56.
387 Carlsson CP, Sjolund BH. Acupuncture for chronic low back pain: a randomized placebo-controlled study with long-term follow-up. Clin J Pain. 2001;17(4):296-305. [pmid: 11783809].
388 Itoh K, Katsumi Y, Hirota S, et al. Effects of trigger point acupuncture on chronic low back pain in elderly patients--a sham-controlled randomised trial. Acupunct Med. 2006;24(1):5-12. [pmid: 16618043].
389 Hasegawa TM, Baptista AS, de Souza MC, et al. Acupuncture for acute non-specific low back pain: a randomised, controlled, double-blind, placebo trial. Acupunct Med. 2014;32(2):109-15. [pmid: 24316509].
390 Vas J, Aranda JM, Modesto M, et al. Acupuncture in patients with acute low back pain: a multicentre randomised controlled clinical trial. Pain. 2012;153(9):1883-9. [pmid: 22770838].
391 Cho Y-J, Song Y-K, Cha Y-Y, et al. Acupuncture for chronic low back pain: a multicenter, randomized, patient-assessor blind, sham-controlled clinical trial. Spine. 2013;38(7):549-57. [pmid: 23026870].
392 Yun M, Xiong N, Guo M, et al. Acupuncture at the back-pain-acupoints for chronic low back pain of Peacekeepers in Lebanon: A randomized controlled trial. J Musculoskelet Pain. 2012;20(2):107-15.
393 Weiss J, Quante S, Xue F, et al. Effectiveness and acceptance of acupuncture in patients with chronic low back pain: results of a prospective, randomized, controlled trial. J Altern Complement Med. 2013;19(12):935-41. [pmid: 23738680].
394 Sator-Katzenschlager SM, Scharbert G, Kozek-Langenecker SA, et al. The short- and long-term benefit in chronic low back pain through adjuvant electrical versus manual auricular acupuncture. Anesth Analg. 2004;98(5):1359-64. table of contents. [pmid: 15105215].
395 Itoh K, Katsumi Y, Kitakoji H. Trigger point acupuncture treatment of chronic low back pain in elderly patients--a blinded RCT. Acupunct Med. 2004;22(4):170-7. [pmid: 15628774].
396 Inoue M, Kitakoji H, Ishizaki N, et al. Relief of low back pain immediately after acupuncture treatment--a randomised, placebo controlled trial. Acupunct Med. 2006;24(3):103-8. [pmid: 17013356].
397 Brinkhaus B, Witt CM, Jena S, et al. Acupuncture in patients with chronic low back pain: a randomized controlled trial. Arch Intern Med. 2006;166(4):450-7. [pmid: 16505266].
398 Leibing E, Leonhardt U, Koster G, et al. Acupuncture treatment of chronic low-back pain -- a randomized, blinded, placebo-controlled trial with 9-month follow-up. Pain. 2002;96(1-2):189-96. [pmid: 11932074].
399 Coan RM, Wong G, Ku SL, et al. The acupuncture treatment of low back pain: a randomized controlled study. Am J Chin Med. 1980;8(1-2):181-9. [pmid: 6446852].
400 Zaringhalam J, Manaheji H, Rastqar A, et al. Reduction of chronic non-specific low back pain: a randomised controlled clinical trial on acupuncture and baclofen. Chin. 2010;5:15. [pmid: 20416100].
401 Giles LG, Muller R. Chronic spinal pain: a randomized clinical trial comparing medication, acupuncture, and spinal manipulation. Spine (Phila Pa 1976). 2003;28(14):1490-502. discussion 502-3. [pmid: 12865832].
402 Muller R, Giles LG. Long-term follow-up of a randomized clinical trial assessing the efficacy of medication, acupuncture, and spinal manipulation for chronic mechanical spinal pain syndromes. J Manipulative Physiol Ther. 2005;28(1):3-11. [pmid: 15726029].
403 Cherkin DC, Eisenberg D, Sherman KJ, et al. Randomized trial comparing traditional Chinese medical acupuncture, therapeutic massage, and self-care education for chronic low back pain. Arch Intern Med. 2001;161(8):1081-8. [pmid: 11322842].
404 Furlan AD, Brosseau L, Imamura M, et al. Massage for low-back pain: a systematic review within the framework of the Cochrane Collaboration Back Review Group. Spine (Phila Pa 1976). 2002;27(17):1896-910. [pmid: 12221356].
405 Furlan AD, Imamura M, Dryden T, et al. Massage for low-back pain. Cochrane Database Syst Rev. 2010;(6).
406 Cherkin DC, Sherman KJ, Kahn J, et al. A comparison of the effects of 2 types of massage and usual care on chronic low back pain: a randomized, controlled trial. [Summary for patients in Ann Intern Med. 2011 Jul 5;155(1):I28; PMID: 21727286]. Ann Intern Med. 2011;155(1):1-9. [pmid: 21727288].
407 Kong LJ, Fang M, Zhan HS, et al. Chinese massage combined with herbal ointment for athletes with nonspecific low back pain: a randomized controlled trial. Evid Based Complement Alternat Med. 2012;2012:695726. [pmid: 23258996].
408 Romanowski M, Romanowska J, Grzeskowiak M. A comparison of the effects of deep tissue massage and therapeutic massage on chronic low back pain. Stud Health Technol Inform. 2012;176:411-4. [pmid: 22744541].
409 Sritoomma N, Moyle W, Cooke M, et al. The effectiveness of Swedish massage with aromatic ginger oil in treating chronic low back pain in older adults: a randomized controlled trial. Complement Ther Med. 2014;22(1):26-33. [pmid: 24559813].
410 Zheng Z, Wang J, Gao Q, et al. Therapeutic evaluation of lumbar tender point deep massage for chronic non-specific low back pain. J Tradit Chin Med. 2012;32(4):534-7. [pmid: 23427384].
411 Ajimsha MS, Daniel B, Chithra S. Effectiveness of myofascial release in the management of chronic low back pain in nursing professionals. J Bodywork Mov Ther. 2014;18(2):273-81. [pmid: 24725797].
412 Borges TP, Kurebayashi LFS, Silva MJPd. Occupational low back pain in nursing workers: massage versus pain. Rev Esc Enferm USP. 2014;48(4):669-75. [pmid: 25338248].
413 Zhang Y, Tang S, Chen G, et al. Chinese massage combined with core stability exercises for nonspecific low back pain: A randomized controlled trial. Complement Ther Med. 2015;23(1):1-6. [pmid: 25637146].
414 Preyde M. Effectiveness of massage therapy for subacute low-back pain: a randomized controlled trial. CMAJ. 2000;162(13):1815-20. [pmid: 10906914].
415 Farasyn A, Meeusen R, Nijs J. A pilot randomized placebo-controlled trial of roptrotherapy in patients with subacute non-specific low back pain. J Back Musculoskeletal Rehabil. 2006;19(4):111-7.
416 Mackawan S, Eungpinichpong W, Pantumethakul R, et al. Effets of traditional Thai massage versus joint mobilization on substance P and pain perception in patients with non-specific low back pain. J Bodywork Mov Ther. 2007;11(1):9-16.
417 Hernandez-Reif M, Field T, Krasnegor J, et al. Lower back pain is reduced and range of motion increased after massage therapy. Int J Neurosci. 2001;106(3-4):131-45. [pmid: 11264915].
418 Field T, Hernandez-Reif M, Diego M, et al. Lower back pain and sleep disturbance are reduced following massage therapy. J Bodywork Mov Ther. 2007;11(2):141-5.
419 Hsieh LL, Kuo CH, Lee LH, et al. Treatment of low back pain by acupressure and physical therapy: randomised controlled trial. BMJ. 2006;332(7543):696-700. [pmid: 16488895].
420 Hsieh LL, Kuo CH, Yen MF, et al. A randomized controlled clinical trial for low back pain treated by acupressure and physical therapy. Prev Med. 2004;39(1):168-76. [pmid: 15207999].
421 Franke A, Gebauer S, Franke K, et al. Acupuncture massage vs Swedish massage and individual exercise vs group exercise in low back pain sufferers--a randomized controlled clinical trial in a 2 × 2 factorial design. Forsch Komplementarmed Klass Naturheilkd. 2000;7(6):286-93. [pmid: 11155022].
422 Geisser ME, Wiggert EA, Haig AJ, et al. A randomized, controlled trial of manual therapy and specific adjuvant exercise for chronic low back pain. Clin J Pain. 2005;21(6):463-70. [pmid: 16215330].
423 Yip YB, Tse SH. The effectiveness of relaxation acupoint stimulation and acupressure with aromatic lavender essential oil for non-specific low back pain in Hong Kong: a randomised controlled trial. Complement Ther Med. 2004;12(1):28-37. [pmid: 15130569].
424 Chatchawan U, Thinkhamrop B, Kharmwan S, et al. Effectiveness of traditional Thai massage versus Swedish massage among patients with back pain associated with myofascial trigger points. J Bodywork Mov Ther. 2005;9(4):298-309.
425 Assendelft WJ, Morton SC, Yu EI, et al. Spinal manipulative therapy for low back pain. A meta-analysis of effectiveness relative to other therapies. Ann Intern Med. 2003;138(11):871-81. [pmid: 12779297].
426 Assendelft WJJ, Morton SC, Yu EI, et al. Spinal manipulative therapy for low-back pain Cochrane Database Syst Rev. 2004;(1). [pmid: 14973958].
427 Avery S, O'Driscoll M-L. Randomised Controlled Trials on the Efficacy Of Spinal Manipulation Therapy in The Treatment of Low Back Pain. Phys Ther Rev. 2004;9(3):146-52. [pmid: 15179309].
428 Bronfort G, Haas M, Evans RL, et al. Efficacy of spinal manipulation and mobilization for low back pain and neck pain: a systematic review and best evidence synthesis. Spine J. 2004;4(3):335-56. [pmid: 15125860].
429 Brown A, Angus A, Chen S, et al. Costs and outcomes of chiropractic treatment for low back pain. Ottowa, Canada. July. 2005;2005.
430 Ernst E, Canter PH. Chiropractic Spinal Manipulation Treatment for Back Pain? A Systematic Review of Randomised Clinical Trials. Phys Ther Rev. 2003;8(2):85. [pmid: 11029157].
431 Ferreira ML, Ferreira PH, Latimer J, et al. Does spinal manipulative therapy help people with chronic low back pain?. Aust J Physiother. 2002;48(4):277-84. [pmid: 12443522].
432 Ferreira ML, Ferreira PH, Latimer J, et al. Efficacy of spinal manipulative therapy for low back pain of less than three months' duration. J Manipulative Physiol Ther. 2003;26(9):593-601. [pmid: 14673408].
433 Gay RE, Bronfort G, Evans RL. Distraction manipulation of the lumbar spine: a review of the literature. J Manipulative Physiol Ther. 2005;28(4):266-73. [pmid: 15883580].
434 Licciardone JC, Brimhall AK, King LN. Osteopathic manipulative treatment for low back pain: a systematic review and meta-analysis of randomized controlled trials. BMC Musculoskelet Disord. 2005;6:43. [pmid: 16080794].
435 Vroomen PC, de Krom MC, Slofstra PD, et al. Conservative treatment of sciatica: a systematic review. J Spinal Disord. 2000;13(6):463-9. [pmid: 11132976].
436 Woodhead T, Clough A. A systematic review of the evidence for manipulation in the treatment of low back pain. J Orthop Med. 2005;27:99-120.
437 Rubinstein SM, Terwee CB, Assendelft WJJ, et al. Spinal manipulative therapy for acute low-back pain. Cochrane Database Syst Rev. 2012;9. CD008880. [pmid: 22972127].
438 Rubinstein SM, van Middelkoop M, Assendelft WJ, et al. Spinal manipulative therapy for chronic low-back pain. Cochrane Database Syst Rev. 2011;(2). CD008112. [pmid: 21328304].
439 Brennan GP, Fritz JM, Hunter SJ, et al. Identifying subgroups of patients with acute/subacute “nonspecific” low back pain: results of a randomized clinical trial. Spine (Phila Pa 1976). 2006;31(6):623-31. [pmid: 16540864].
440 Childs JD, Fritz JM, Flynn TW, et al. A clinical prediction rule to identify patients with low back pain most likely to benefit from spinal manipulation: a validation study. Ann Intern Med. 2004;141(12):920-8. [pmid: 15611489].
441 Cleland JA, Fritz JM, Kulig K, et al. Comparison of the effectiveness of three manual physical therapy techniques in a subgroup of patients with low back pain who satisfy a clinical prediction rule: a randomized clinical trial. Spine. 2009;34(25):2720-9. [pmid: 19940729].
442 Hallegraeff JM, de Greef M, Winters JC, et al. Manipulative therapy and clinical prediction criteria in treatment of acute nonspecific low back pain. [Erratum appears in Percept Mot Skills. 2009 Jun;108(3):981 Note: Hallegraeff, H J M [corrected to Hallegraeff, J M]]. Percept Mot Skills. 2009;108(1):196-208. [pmid: 19425461].
443 Hancock MJ, Maher CG, Latimer J, et al. Assessment of diclofenac or spinal manipulative therapy, or both, in addition to recommended first-line treatment for acute low back pain: a randomised controlled trial. Lancet. 2007;370(9599):1638-43. [pmid: 17993364].
444 Hoiriis KT, Pfleger B, McDuffie FC, et al. A randomized clinical trial comparing chiropractic adjustments to muscle relaxants for subacute low back pain. J Manipulative Physiol Ther. 2004;27(6):388-98. [pmid: 15319761].
445 Juni P, Battaglia M, Nuesch E, et al. A randomised controlled trial of spinal manipulative therapy in acute low back pain. Ann Rheum Dis. 2009;68(9):1420-7. [pmid: 18775942].
446 Sutlive TG, Mabry LM, Easterling EJ, et al. Comparison of short-term response to two spinal manipulation techniques for patients with low back pain in a military beneficiary population. Mil Med. 2009;174(7):750-6. [pmid: 19685848].
447 Cramer GD, Humphreys CR, Hondras MA, et al. The Hmax/Mmax ratio as an outcome measure for acute low back pain. J Manipulative Physiol Ther. 1993;16(1):7-13. [pmid: 8423429].
448 Farrell JP, Twomey LT. Acute low back pain. Comparison of two conservative treatment approaches. Med J Aust. 1982;1(4):160-4. [pmid: 6210835].
449 Hadler NM, Curtis P, Gillings DB, et al. A benefit of spinal manipulation as adjunctive therapy for acute low-back pain: a stratified controlled trial. Spine (Phila Pa 1976). 1987;12(7):702-6. [pmid: 2961085].
450 Rasmussen G. Manipulation in treatment of low back pain: a randomized clinical trial. Man Med. 1979;1:8-10.
451 Seferlis T, Nemeth G, Carlsson AM, et al. Conservative treatment in patients sick-listed for acute low-back pain: a prospective randomised study with 12 months' follow-up. Eur Spine J. 1998;7(6):461-70. [pmid: 9883955].
452 Bergquist-Ullman M, Larsson U. Acute low back pain in industry. A controlled prospective study with special reference to therapy and confounding factors. Acta Orthop Scand. 1977;(170):1-117. [pmid: 146394].
453 Cherkin DC, Deyo RA, Battie M, et al. A comparison of physical therapy, chiropractic manipulation, and provision of an educational booklet for the treatment of patients with low back pain. N Engl J Med. 1998;339(15):1021-9. [pmid: 9761803].
454 Hoehler FK, Tobis JS, Buerger AA. Spinal manipulation for low back pain. Jama. 1981;245(18):1835-8. [pmid: 6453240].
455 MacDonald RS, Bell CM. An open controlled assessment of osteopathic manipulation in nonspecific low-back pain. Spine (Phila Pa 1976). 1990;15(5):364-70. [pmid: 2141951].
456 Postacchini F, Facchini M, Palieri P. Efficacy of various forms of conservative treatment in low back pain. A comparative study. Neuro-Orthopedics. 1988;6(1):28-35.
457 Skargren EI, Oberg BE, Carlsson PG, et al. Cost and effectiveness analysis of chiropractic and physiotherapy treatment for low back and neck pain. Six-month follow-up. Spine (Phila Pa 1976). 1997;22(18):2167-77. [pmid: 9322328].
458 Chown M, Whittamore L, Rush M, et al. A prospective study of patients with chronic back pain randomised to group exercise, physiotherapy or osteopathy. Physiotherapy. 2008;94(1):21-8.
459 Ghroubi S, Elleuch H, Baklouti S, et al. Chronic low back pain and vertebral manipulation. Ann Readapt Med Phys. 2007;50(7):570-6. [pmid: 17382426].
460 Gudavalli MR, Cambron JA, McGregor M, et al. A randomized clinical trial and subgroup analysis to compare flexion-distraction with active exercise for chronic low back pain. Eur Spine J. 2006;15(7):1070-82. [pmid: 16341712].
461 Hondras MA, Long CR, Cao Y, et al. A randomized controlled trial comparing 2 types of spinal manipulation and minimal conservative medical care for adults 55 years and older with subacute or chronic low back pain. J Manipulative Physiol Ther. 2009;32(5):330-43. [pmid: 19539115].
462 Hsieh CY, Adams AH, Tobis J, et al. Effectiveness of four conservative treatments for subacute low back pain: a randomized clinical trial. Spine (Phila Pa 1976). 2002;27(11):1142-8. [pmid: 12045509].
463 Hurwitz EL, Morgenstern H, Harber P, et al. A randomized trial of medical care with and without physical therapy and chiropractic care with and without physical modalities for patients with low back pain: 6-month follow-up outcomes from the UCLA low back pain study. Spine (Phila Pa 1976). 2002;27(20):2193-204. [pmid: 12394892].
464 Licciardone JC, Stoll ST, Fulda KG, et al. Osteopathic manipulative treatment for chronic low back pain: a randomized controlled trial. Spine (Phila Pa 1976). 2003;28(13):1355-62. [pmid: 12838090].
465 Mohseni-Bandpei MA, Critchley J, Staunton T, et al. A prospective randomised controlled trial of spinal manipulation and ultrasound in the treatment of chronic low back pain. Physiotherapy. 2006;92(1):34-42.
466 Paatelma M, Kilpikoski S, Simonen R, et al. Orthopaedic manual therapy, McKenzie method or advice only for low back pain in working adults: a randomized controlled trial with one year follow-up. J Rehabil Med. 2008;40(10):858-63. [pmid: 19242624].
467 Rasmussen J, Laetgaard J, Lindecrona A-L, et al. Manipulation does not add to the effect of extension exercises in chronic low-back pain (LBP). A randomized, controlled, double blind study. Joint Bone Spine. 2008;75(6):708-13. [pmid: 19028434].
468 Rasmussen-Barr E, Nilsson-Wikmar L, Arvidsson I. Stabilizing training compared with manual treatment in sub-acute and chronic low-back pain. Man Ther. 2003;8(4):233-41. [pmid: 14559046].
469 Skillgate E, Vingard E, Alfredsson L. Naprapathic manual therapy or evidence-based care for back and neck pain: a randomized, controlled trial. Clin J Pain. 2007;23(5):431-9. [pmid: 17515742].
470 Wilkey A, Gregory M, Byfield D, et al. A comparison between chiropractic management and pain clinic management for chronic low-back pain in a national health service outpatient clinic. J Altern Complement Med. 2008;14(5):465-73. [pmid: 18564952].
471 Zaproudina N, Hietikko T, Hanninen OOP, et al. Effectiveness of traditional bone setting in treating chronic low back pain: a randomised pilot trial. Complement Ther Med. 2009;17(1):23-8. [pmid: 19114225].
472 Bronfort G, Goldsmith CH, Nelson CF, et al. Trunk exercise combined with spinal manipulative or NSAID therapy for chronic low back pain: a randomized, observer-blinded clinical trial. J Manipulative Physiol Ther. 1996;19(9):570-82. [pmid: 8976475].
473 Hemmila HM, Keinanen-Kiukaanniemi SM, Levoska S, et al. Long-term effectiveness of bone-setting, light exercise therapy, and physiotherapy for prolonged back pain: a randomized controlled trial. J Manipulative Physiol Ther. 2002;25(2):99-104. [pmid: 11896377].
474 Koes BW, Bouter LM, van Mameren H, et al. Randomised clinical trial of manipulative therapy and physiotherapy for persistent back and neck complaints: results of one year follow up. BMJ. 1992;304(6827):601-5. [pmid: 1532760].
475 Gibson T, Grahame R, Harkness J, et al. Controlled comparison of short-wave diathermy treatment with osteopathic treatment in non-specific low back pain. Lancet. 1985;1(8440):1258-61. [pmid: 2860453].
476 Balthazard P, de Goumoens P, Rivier G, et al. Manual therapy followed by specific active exercises versus a placebo followed by specific active exercises on the improvement of functional disability in patients with chronic non specific low back pain: a randomized controlled trial. BMC Musculoskelet Disord. 2012;13:162. [pmid: 22925609].
477 Bicalho E, Setti JAP, Macagnan J, et al. Immediate effects of a high-velocity spine manipulation in paraspinal muscles activity of nonspecific chronic low-back pain subjects. Manual Ther. 2010;15(5):469-75. [pmid: 20447857].
478 Cecchi F, Molino-Lova R, Chiti M, et al. Spinal manipulation compared with back school and with individually delivered physiotherapy for the treatment of chronic low back pain: a randomized trial with one-year follow-up. Clin Rehabil. 2010;24(1):26-36. [pmid: 20053720].
479 de Oliveira RF, Liebano RE, Costa LdCM, et al. Immediate effects of region-specific and non-region-specific spinal manipulative therapy in patients with chronic low back pain: a randomized controlled trial. Phys Ther. 2013;93(6):748-56. [pmid: 23431209].
480 Haas M, Vavrek D, Peterson D, et al. Dose-response and efficacy of spinal manipulation for care of chronic low back pain: a randomized controlled trial. Spine J. 2014;14(7):1106-16. [pmid: 24139233].
481 Petersen T, Larsen K, Nordsteen J, et al. The McKenzie method compared with manipulation when used adjunctive to information and advice in low back pain patients presenting with centralization or peripheralization: a randomized controlled trial. Spine. 2011;36(24):1999-2010. [pmid: 21358492].
482 Senna MK, Machaly SA. Does maintained spinal manipulation therapy for chronic nonspecific low back pain result in better long-term outcome?. Spine. 2011;36(18):1427-37. [pmid: 21245790].
483 Goertz CM, Long CR, Hondras MA, et al. Adding chiropractic manipulative therapy to standard medical care for patients with acute low back pain: results of a pragmatic randomized comparative effectiveness study. Spine. 2013;38(8):627-34. [pmid: 23060056].
484 Schneider M, Haas M, Glick R, et al. Comparison of spinal manipulation methods and usual medical care for acute and subacute low back pain: a randomized clinical trial. Spine. 2015;40(4):209-17. [pmid: 25423308].
485 von Heymann WJ, Schloemer P, Timm J, et al. Spinal high-velocity low amplitude manipulation in acute nonspecific low back pain: a double-blinded randomized controlled trial in comparison with diclofenac and placebo. Spine. 2013;38(7):540-8. [pmid: 23026869].
486 Bronfort G, Hondras MA, Schulz CA, et al. Spinal manipulation and home exercise with advice for subacute and chronic back-related leg pain: a trial with adaptive allocation. [Summary for patients in Ann Intern Med. 2014 Sep 16;161(6):I-15; PMID: 25222405]. Ann Intern Med. 2014;161(6):381-91. [pmid: 25222385].
487 Bronfort G, Evans RL, Maiers M, et al. Spinal manipulation, epidural injections, and self-care for sciatica: a pilot study for a randomized clinical trial. J Manipulative Physiol Ther. 2004;27(8):503-8. [pmid: 15510093].
488 Burton AK, Tillotson KM, Cleary J. Single-blind randomised controlled trial of chemonucleolysis and manipulation in the treatment of symptomatic lumbar disc herniation. Eur Spine J. 2000;9(3):202-7. [pmid: 10905437].
489 Santilli V, Beghi E, Finucci S. Chiropractic manipulation in the treatment of acute back pain and sciatica with disc protrusion: a randomized double-blind clinical trial of active and simulated spinal manipulations. Spine J. 2006;6(2):131-7. [pmid: 16517383].
490 Waagen GN, Haldeman S, Cook G, et al. Short term trial of chiropractic adjustments for the relief of chronic low back pain. Manual Med. 1986;(2):63-7.
491 Glover JR, Morris JG, Khosla T. Back pain: a randomized clinical trial of rotational manipulation of the trunk. Br J Ind Med. 1974;31(1):59-64. [pmid: 4274488].
492 Pope MH, Phillips RB, Haugh LD, et al. A prospective randomized three-week trial of spinal manipulation, transcutaneous muscle stimulation, massage and corset in the treatment of subacute low back pain. Spine (Phila Pa 1976). 1994;19(22):2571-7. [pmid: 7855683].
493 Evans DP, Burke MS, Lloyd KN, et al. Lumbar spinal manipulation on trial. Part I--clinical assessment. Rheumatol Rehabil. 1978;17(1):46-53. [pmid: 153574].
494 Ansari NN, Ebadi S, Talebian S, et al. A randomized, single blind placebo controlled clinical trial on the effect of continuous ultrasound on low back pain. Electromyogr Clin Neurophysiol. 2006;46(6):329-36. [pmid: 17147074].
495 Nwuga VC. Ultrasound in treatment of back pain resulting from prolapsed intervertebral disc. Arch Phys Med Rehabil. 1983;64(2):88-9. [pmid: 6218793].
496 Roman MP. A clinical evaluation of ultrasound by use of a placebo technic. Phys Ther Rev. 1960;40:649-52. [pmid: 13742988].
497 Ebadi S, Henschke N, Nakhostin Ansari N, et al. Therapeutic ultrasound for chronic low-back pain. Cochrane Database Syst Rev. 2014;3. CD009169. [pmid: 24627326].
498 Durmuş D, Akyol Y, Cengiz K, et al. Effects of therapeutic ultrasound on pain, disability, walking performance, quality of life, and depression in patients with chronic low back pain: A randomized, placebo controlled trial. Turk J Rheumatol. 2010;25(2):82-7.
499 Durmus D, Durmaz Y, Canturk F. Effects of therapeutic ultrasound and electrical stimulation program on pain, trunk muscle strength, disability, walking performance, quality of life, and depression in patients with low back pain: a randomized-controlled trial. Rheumatol Int. 2010;30(7):901-10. [pmid: 19644691].
500 Durmus D, Alayli G, Goktepe AS, et al. Is phonophoresis effective in the treatment of chronic low back pain? A single-blind randomized controlled trial. Rheumatol Int. 2013;33(7):1737-44. [pmid: 23283539].
501 Ebadi S, Ansari NN, Naghdi S, et al. The effect of continuous ultrasound on chronic non-specific low back pain: a single blind placebo-controlled randomized trial. BMC Musculoskelet Disord. 2012;13:192. [pmid: 23031570].
502 Grubisic F, Grazio S, Jajic Z, et al. Therapeutic ultrasound in chronic low back pain treatment. Reumatizam. 2006;53(1):18-21. [pmid: 17580544].
503 Licciardone JC, Minotti DE, Gatchel RJ, et al. Osteopathic manual treatment and ultrasound therapy for chronic low back pain: a randomized controlled trial. Ann Fam Med. 2013;11(2):122-9. [pmid: 23508598].
504 Fiore P, Panza F, Cassatella G, et al. Short-term effects of high-intensity laser therapy versus ultrasound therapy in the treatment of low back pain: a randomized controlled trial. Eur J Phys Rehabil Med. 2011;47(3):367-73. [pmid: 21654616].
505 Goren A, Yildiz N, Topuz O, et al. Efficacy of exercise and ultrasound in patients with lumbar spinal stenosis: a prospective randomized controlled trial. Clin Rehabil. 2010;24(7):623-31. [pmid: 20530650].
506 Unlu Z, Tasci S, Tarhan S, et al. Comparison of 3 physical therapy modalities for acute pain in lumbar disc herniation measured by clinical evaluation and magnetic resonance imaging. J Manipulative Physiol Ther. 2008;31(3):191-8. [pmid: 18394495].
507 Khadilkar A, Milne A, Brosseau L, et al. Transcutaneous electrical nerve stimulation (TENS) for chronic low-back pain Cochrane Database Syst Rev. 2005;(3). Art. No.: CD003008. [pmid: 16034883].
508 Deyo RA, Walsh NE, Martin DC, et al. A controlled trial of transcutaneous electrical nerve stimulation (TENS) and exercise for chronic low back pain. N Engl J Med. 1990;322:1627-34. [pmid: 2140432].
509 Cheing GL, Hui-Chan CW. Transcutaneous electrical nerve stimulation: nonparallel antinociceptive effects on chronic clinical pain and acute experimental pain. Arch Phys Med Rehabil. 1999;80(3):305-12. [pmid: 10084439].
510 Furlan AD, Brosseau L, Imamura M, et al. Massage for low-back pain Cochrane Database Syst Rev. 2002;(2). Art. No.: CD001929. [pmid: 12076429].
511 French S, Cameron M, Walker B, et al. Superficial heat or cold for low back pain. Cochrane Database Syst Rev. 2006;(1). Art. No.: CD004750.
512 van Middelkoop M, Rubinstein SM, Kuijpers T, et al. A systematic review on the effectiveness of physical and rehabilitation interventions for chronic non-specific low back pain. European Spine Journal. 2011;20:19-39. [pmid: 20640863].
513 Ghoname EA, Craig WF, White PF, et al. Percutaneous electrical nerve stimulation for low back pain: a randomized crossover study. Jama. 1999;281(9):818-23. [pmid: 10071003].
514 Jarzem PF, Harvey EJ, Arcaro N, et al. Transcutaneous electrical nerve stimulation [TENS] for chronic low back pain. J Musculoskelet Pain. 2005;13(2):3-9.
515 Jarzem PF, Harvey EJ, Arcaro N, et al. Transcutaneous electrical nerve stimulation [TENS] for short-term treatment of low back pain - Randomized double blind crossover study of sham versus conventional TENS. J Musculoskelet Pain. 2005;13(2):11-7.
516 Topuz O, Ozfidan E, Ozgen M, et al. Efficacy of transcutaneous electrical nerve stimulation and percutaneous neuromodulation therapy in chronic low back pain. J Back Musculoskeletal Rehabil. 2004;17(3-4):127-33.
517 Buchmuller A, Navez M, Milletre-Bernardin M, et al. Value of TENS for relief of chronic low back pain with or without radicular pain. Eur J Pain. 2012;16(5):656-65. [pmid: 22337531].
518 Shimoji K, Takahashi N, Nishio Y, et al. Pain relief by transcutaneous electric nerve stimulation with bidirectional modulated sine waves in patients with chronic back pain: a randomized, double-blind, sham-controlled study. Neuromodulation. 2007;10(1):42-51. [pmid: 22151811].
519 Facci LM, Nowotny JP, Tormem F, et al. Effects of transcutaneous electrical nerve stimulation (TENS) and interferential currents (IFC) in patients with nonspecific chronic low back pain: randomized clinical trial. Sao Paulo Med J. 2011;129(4):206-16. [pmid: 21971895].
520 Tsukayama H, Yamashita H, Amagai H, et al. Randomised controlled trial comparing the effectiveness of electroacupuncture and TENS for low back pain: a preliminary study for a pragmatic trial. Acupunct Med. 2002;20(4):175-80. [pmid: 12512791].
521 Melzack R, Jeans ME, Stratford JG, et al. Ice massage and transcutaneous electrical stimulation: comparison of treatment for low-back pain. Pain. 1980;9(2):209-17. [pmid: 6450393].
522 Sherry E, Kitchener P, Smart R. A prospective randomized controlled study of VAX-D and TENS for the treatment of chronic low back pain. Neurol Res. 2001;23(7):780-4. [pmid: 11680522].
523 Melzack R, Vetere P, Finch M. Transcutaneous electrical nerve stimulation for low back pain. A comparison of TENS and massage for pain and range of motion. Phys Ther. 1983;63:489-93. [pmid: 6220415].
524 Durmus D, Akyol Y, Alayli G, et al. Effects of electrical stimulation program on trunk muscle strength, functional capacity, quality of life, and depression in the patients with low back pain: a randomized controlled trial. Rheumatol Int. 2009;29(8):947-54. [pmid: 19099308].
525 Glaser JA, Baltz MA, Nietert PJ, et al. Electrical muscle stimulation as an adjunct to exercise therapy in the treatment of nonacute low back pain: a randomized trial. J Pain. 2001;2(5):295-300. [pmid: 14622808].
526 Moore SR, Shurman J. Combined neuromuscular electrical stimulation and transcutaneous electrical nerve stimulation for treatment of chronic back pain: a double-blind, repeated measures comparison. Arch Phys Med Rehabil. 1997;78(1):55-60. [pmid: 9014958].
527 Ghoname EA, White PF, Ahmed HE, et al. Percutaneous electrical nerve stimulation: an alternative to TENS in the management of sciatica. Pain. 1999;83(2):193-9. [pmid: 10534590].
528 Weiner DK, Rudy TE, Glick RM, et al. Efficacy of percutaneous electrical nerve stimulation for the treatment of chronic low back pain in older adults. J Am Geriatr Soc. 2003;51(5):599-608. [pmid: 12752833].
529 Yokoyama M, Sun X, Oku S, et al. Comparison of percutaneous electrical nerve stimulation with transcutaneous electrical nerve stimulation for long-term pain relief in patients with chronic low back pain. Anesth Analg. 2004;98(6):1552-6. table of contents. [pmid: 15155304].
530 Perez-Palomares S, Olivan-Blazquez B, Magallon-Botaya R, et al. Percutaneous electrical nerve stimulation versus dry needling: effectiveness in the treatment of chronic low back pain. J Musculoskelet Pain. 2010;18(1):23-30.
531 Hamza MA, Ghoname EA, White PF, et al. Effect of the duration of electrical stimulation on the analgesic response in patients with low back pain. Anesthesiology. 1999;91(6):1622-7. [pmid: 10598602].
532 Weiner DK, Perera S, Rudy TE, et al. Efficacy of percutaneous electrical nerve stimulation and therapeutic exercise for older adults with chronic low back pain: a randomized controlled trial. Pain. 2008;140(2):344-57. [pmid: 18930352].
533 Hurley DA, McDonough SM, Dempster M, et al. A randomized clinical trial of manipulative therapy and interferential therapy for acute low back pain. Spine (Phila Pa 1976). 2004;29(20):2207-16. [pmid: 15480130].
534 Hurley DA, Minder PM, McDonough SM, et al. Interferential therapy electrode placement technique in acute low back pain: a preliminary investigation. Arch Phys Med Rehabil. 2001;82(4):485-93. [pmid: 11295009].
535 Werners R, Pynsent PB, Bulstrode CJ. Randomized trial comparing interferential therapy with motorized lumbar traction and massage in the management of low back pain in a primary care setting. Spine (Phila Pa 1976). 1999;24(15):1579-84. [pmid: 10457578].
536 Lara-Palomo IC, Aguilar-Ferrandiz ME, Mataran-Penarrocha GA, et al. Short-term effects of interferential current electro-massage in adults with chronic non-specific low back pain: a randomized controlled trial. Clin Rehabil. 2013;27(5):439-49. [pmid: 23035006].
537 French SD, Cameron M, Walker BF, et al. Superficial heat or cold for low back pain. Cochrane Database Syst Rev. 2011;(2). [pmid: 16437495].
538 Mayer JM, Ralph L, Look M, et al. Treating acute low back pain with continuous low-level heat wrap therapy and/or exercise: a randomized controlled trial. Spine J. 2005;5(4):395-403. [pmid: 15996609].
539 Nadler SF, Steiner DJ, Erasala GN, et al. Continuous low-level heatwrap therapy for treating acute nonspecific low back pain. Arch Phys Med Rehabil. 2003;84(3):329-34. [pmid: 12638099].
540 Nadler SF, Steiner DJ, Petty SR, et al. Overnight use of continuous low-level heatwrap therapy for relief of low back pain. Arch Phys Med Rehabil. 2003;84(3):335-42. [pmid: 12638100].
541 Nuhr M, Hoerauf K, Bertalanffy A, et al. Active warming during emergency transport relieves acute low back pain. Spine (Phila Pa 1976). 2004;29(14):1499-503. [pmid: 15247569].
542 Landen BR. Heat or cold for the relief of low back pain?. Phys Ther. 1967;47(12):1126-8. [pmid: 4229712].
543 Roberts D, Walls C, Carlile J, et al. Relief of chronic low back pain: heat versus cold. 2nd edition ed. Baltimore. Urban & Schwarzenberg. 1992;1992.
544 St John Dixon A, Owen-Smith BD, Harrison RA. Cold-sensitive, non-specific low back pain: a comparative trial of treatment. Clinical Trials Journal. 1972;4:16-21.
545 van Tulder M, Furlan A, Bombardier C, et al. Updated method guidelines for systematic reviews in the cochrane collaboration back review group. Spine (Phila Pa 1976). 2003;28(12):1290-9. [pmid: 12811274].
546 Kettenmann B, Wille C, Lurie-Luke E, et al. Impact of continuous low level heatwrap therapy in acute low back pain patients: subjective and objective measurements. Clin J Pain. 2007;23(8):663-8. [pmid: 17885344].
547 Stark J, Petrofsky J, Berk L, et al. Continuous low-level heatwrap therapy relieves low back pain and reduces muscle stiffness. Phys Sportsmed. 2014;42(4):39-48. [pmid: 25419887].
548 Dehghan M, Farahbod F. The efficacy of thermotherapy and cryotherapy on pain relief in patients with acute low back pain, a clinical trial study. J Clin Diagn Res. 2014;8(9):LC01-4. [pmid: 25386469].
549 Tao XG, Bernacki EJ. A randomized clinical trial of continuous low-level heat therapy for acute muscular low back pain in the workplace. J Occup Environ Med. 2005;47(12):1298-306. [pmid: 16340712].
550 Basford JR, Sheffield CG, Harmsen WS. Laser therapy: a randomized, controlled trial of the effects of low-intensity Nd:YAG laser irradiation on musculoskeletal back pain. Arch Phys Med Rehabil. 1999;80(6):647-52. [pmid: 10378490].
551 Klein RG, Eek BC. Low-energy laser treatment and exercise for chronic low back pain: double-blind controlled trial. Arch Phys Med Rehabil. 1990;71(1):34-7. [pmid: 2136991].
552 Soriano F, Rios R. Gallium Arsenide laser treatment of chronic low back pain: a prospective, randomized and double blind study. Laser Ther. 1998;10:175-80.
553 Toya S, Motegi M, Inomata K, et al. Report on a computer-randomized double blind clinical trial to determine the effectiveness of the GaAlAs (830 nm) diode laser for pain attenuation in selected pain groups. Laser Ther. 1994;6:143.
554 Gur A, Karakoc M, Cevik R, et al. Efficacy of low power laser therapy and exercise on pain and functions in chronic low back pain. Lasers Surg Med. 2003;32(3):233-8. [pmid: 12605431].
555 Longo L, Tamburini A, Monti A, et al. Treatment with 904 nm and 10 600 nm laser of acute lumbago: double blind control. Laser Clin Res. 1988;3:16-20.
556 Monticone M, Barbarino A, Testi C, et al. Symptomatic efficacy of stabilizing treatment versus laser therapy for sub-acute low back pain with positive tests for sacroiliac dysfunction: A randomised clinical controlled trial with 1 year follow-up. Eur. 2004;40(4):263-8. [pmid: 16175148].
557 Yousefi-Nooraie R, Schonstein E, Heidari K, et al. Low level laser therapy for nonspecific low-back pain. Cochrane Database Syst Rev. 2011;(2).
558 Djavid GE, Mehrdad R, Ghasemi M, et al. In chronic low back pain, low level laser therapy combined with exercise is more beneficial than exercise alone in the long term: a randomised trial. [Erratum appears in Aust J Physiother. 2007;53(4):216]. Aust J Physiother. 2007;53(3):155-60. [pmid: 17725472].
559 Hsieh RL, Lee WC. Short-term therapeutic effects of 890-nanometer light therapy for chronic low back pain: a double-blind randomized placebo-controlled study. Lasers Med Sci. 2014;29(2):671-9. [pmid: 23820974].
560 Konstantinovic LM, Kanjuh ZM, Milovanovic AN, et al. Acute low back pain with radiculopathy: a double-blind, randomized, placebo-controlled study. Photomed Laser Surg. 2010;28(4):553-60. [pmid: 20001318].
561 Ay S, Dogan SK, Evcik D. Is low-level laser therapy effective in acute or chronic low back pain?. [Erratum appears in Clin Rheumatol. 2010 Aug;29(8):911]. Clin Rheumatol. 2010;29(8):905-10. [pmid: 20414695].
562 Jovicic M, Konstantinovic L, Lazovic M, et al. Clinical and functional evaluation of patients with acute low back pain and radiculopathy treated with different energy doses of low level laser therapy. Vojnosanit Pregl. 2012;69(8):656-62. [pmid: 22924260].
563 Vallone F, Benedicenti S, Sorrenti E, et al. Effect of diode laser in the treatment of patients with nonspecific chronic low back pain: a randomized controlled trial. Photomed Laser Surg. 2014;32(9):490-4. [pmid: 25141218].
564 Gallagher EJ, Liebman M, Bijur PE. Prospective validation of clinically important changes in pain severity measured on a visual analog scale. Ann Emerg Med. 2001;38(6):633-8. [pmid: 11719741].
565 Sweetman BJ, Heinrich I, Anderson JAD. A randomized controlled trial of exercises, short wave diathermy, and traction for low back pain, with evidence of diagnosis-related response to treatment. J Orthop Rheumatol. 1993;6(4):159-66.
566 Ahmed MS, Shakoor MA, Khan AA. Evaluation of the effects of shortwave diathermy in patients with chronic low back pain. Bangladesh Med Res Counc Bull. 2009;35(1):18-20. [pmid: 19637541].
567 Shakoor MA, Rahman MS, Moyeenuzzaman M. Effects of deep heat therapy on the patients with chronic low back pain. Mymensingh Med J. 2008;17(2 Suppl):S32-8. [pmid: 18946448].
568 Coxhead CE, Inskip H, Meade TW, et al. Multi-centre trial of physiotherapy in the management of sciatic symptoms. Lancet. 1981;1(8229):1065-8. [pmid: 6112444].
569 Hsieh CY, Phillips RB, Adams AH, et al. Functional outcomes of low back pain: Comparison of four treatment groups in a randomized controlled trial. J Manipulative Physiol Ther. 1992;15(1):4-9. [pmid: 1531488].
570 Million R, Nilsen K, Jayson M, et al. Evaluation of low back pain and assessment of lumbar corsets with and without back supports. Ann Rheum Dis. 1981;40(5):449-54. [pmid: 6458250].
571 Penrose KW, Chook K, Stump JL. Acute and chronic effects of pneumatic lumbar suppor on muscular strength, flexibility, and functional impairment index. Sports Training Med Rehab. 1991;2:121-9.
572 Valle-Jones J, Walsh H, O'Hara J, et al. Controlled trial of a back support (‘Lumbotrain’) in patients with non-specific low back pain. Curr Med Res Opin. 1992;12(9):604-13. [pmid: 1533832].
573 van Duijvenbode I, Jellema P, van Poppel M, et al. Lumbar supports for prevention and treatment of low back pain. Cochrane Database Syst Rev. 2011;(2).
574 Dalichau S, Scheele K. Auswirkungen elastischer lumbalstutzgurte auf den effect eines muskeltrainingsprogrammes fur patienten mit chronischen ruckenschmerzen. Z Orthop. 2000;138:8-16. [pmid: 10730357].
575 Gibson JNA, Ahmed M. The effectiveness of flexible an dridig supports in patients with lumbar backache. J Orthop Med. 2002;24:86-9.
576 Calmels P, Queneau P, Hamonet C, et al. Effectiveness of a lumbar belt in subacute low back pain: an open, multicentric, and randomized clinical study. Spine. 2009;34(3):215-20. [pmid: 19179915].
577 Sato N, Sekiguchi M, Kikuchi S, et al. Effects of long-term corset wearing on chronic low back pain. Fukushima J Med Sci. 2012;58(1):60-5. [pmid: 22790893].
578 Morrisette DC, Cholewicki J, Logan S, et al. A randomized clinical trial comparing extensible and inextensible lumbosacral orthoses and standard care alone in the management of lower back pain. Spine (Phila Pa 1976). 2014;39(21):1733-42. [pmid: 25054648].
579 Oleske DM, Lavender SA, Andersson GBJ, et al. Are back supports plus education more effective than education alone in promoting recovery from low back pain?: Results from a randomized clinical trial. Spine. 2007;32(19):2050-7. [pmid: 17762804].
580 Clarke JA, van Tulder MW, Blomberg SEI, et al. Traction for low-back pain with or without sciatica. Cochrane Database Syst Rev. 2007;(2). CD003010. [pmid: 17443521].
581 Wegner I, Widyahening IS, van Tulder MW, et al. Traction for low-back pain with or without sciatica. Cochrane Database Syst Rev. 2013;8. CD003010. [pmid: 23959683].
582 Konrad K, Tatrai T, Hunka A, et al. Controlled trial of balneotherapy in treatment of low back pain. Ann Rheum Dis. 1992;51(6):820-2. [pmid: 1535495].
583 Mathews W, Morkel M, Mathews J. Manipulation and traction for lumbago and sciatica: Physiotherapeutic techniques used in two controlled trials. Physiother Pract. 1988;4(4):201-6.
584 Diab AA, Moustafa IM. Lumbar lordosis rehabilitation for pain and lumbar segmental motion in chronic mechanical low back pain: a randomized trial. J Manipulative Physiol Ther. 2012;35(4):246-53. [pmid: 22632584].
585 Diab AAM, Moustafa IM. The efficacy of lumbar extension traction for sagittal alignment in mechanical low back pain: a randomized trial. J Back Musculoskeletal Rehabil. 2013;26(2):213-20. [pmid: 23640324].
586 Moustafa IM, Diab AA. Extension traction treatment for patients with discogenic lumbosacral radiculopathy: a randomized controlled trial. Clin Rehabil. 2013;27(1):51-62. [pmid: 22684211].
587 Prasad KSM, Gregson BA, Hargreaves G, et al. Inversion therapy in patients with pure single level lumbar discogenic disease: a pilot randomized trial. Disabil Rehabil. 2012;34(17):1473-80. [pmid: 22263648].
588 Beurskens AJP, de Vet HCP, Koke AJPT, et al. Efficacy of traction for nonspecific low back pain: 12-week and 6-month results of a randomized clinical trial. Spine. 1997;22(23):2756-62. [pmid: 9431610].
589 van der Heijden G, Beurskens A, Dirx M, et al. Efficacy of lumbar traction: a randomised clinical trial. Physiotherapy. 1995;81(1):29-35.
590 Letchuman R, Deusinger R. Comparison of sacrospinalis myoelectric activity and pain levels in patients undergoing static and intermittent lumbar traction. Spine. 1993;18(10):1361-5. [pmid: 8211369].
591 Tesio L, Merlo A. Autotraction versus passive traction: an open controlled study in lumbar disc herniation. Arch Phys Med Rehabil. 1993;74(8):871-6. [pmid: 8347073].
592 Bae SH, Lee JH, Oh KA, et al. The effects of kinesio taping on potential in chronic low back pain patients anticipatory postural control and cerebral cortex. J Phys Ther Sci. 2013;25(11):1367-71. [pmid: 24396190].
593 Castro-Sanchez AM, Lara-Palomo IC, Mataran-Penarrocha GA, et al. Kinesio Taping reduces disability and pain slightly in chronic non-specific low back pain: a randomised trial. [Erratum appears in J Physiother. 2012;58(3):143]. J Physiother. 2012;58(2):89-95. [pmid: 22613238].
594 Chen S-M, Alexander R, Lo SK, et al. Effects of Functional Fascial Taping on pain and function in patients with non-specific low back pain: a pilot randomized controlled trial. Clin Rehabil. 2012;26(10):924-33. [pmid: 22492922].
595 Kachanathu SJ, Alenazi AM, Seif HE, et al. Comparison between Kinesio Taping and a Traditional Physical Therapy Program in Treatment of Nonspecific Low Back Pain. J Phys Ther Sci. 2014;26(8):1185-8. [pmid: 25202177].
596 Paoloni M, Bernetti A, Fratocchi G, et al. Kinesio Taping applied to lumbar muscles influences clinical and electromyographic characteristics in chronic low back pain patients. Eur J Phys Rehabil Med. 2011;47(2):237-44. [pmid: 21430611].
597 Silva Parreira PdC, Costa LC, Takahashi R, et al. Kinesio Taping to generate skin convolutions is not better than sham taping for people with chronic non-speci fi c low back pain: a randomised trial. J Physiother. 2014;60(2):90-6. [pmid: 24952836].
598 Chaparro LE, Furlan AD, Deshpande A, et al. Opioids compared to placebo or other treatments for chronic low-back pain. Cochrane Database Syst Rev. 2013;8. CD004959. [pmid: 23983011].
599 Chou R, Deyo R, Devine B, et al. The Effectiveness and Risks of Long-Term Opioid Treatment of Chronic Pain. Evidence Report/Technology Assessment No. 218. (Prepared by the Pacific Northwest Evidence-gased Practice Center under Contract 290-212-00014-I.) AHRQ Publication 14-E005-EF. 2014.
600 Machado LAC, Kamper SJ, Herbert RD, et al. Analgesic effects of treatments for non-specific low back pain: a meta-analysis of placebo-controlled randomized trials. Rheumatology (Oxford). 2009;48(5):520-7. [pmid: 19109315].
601 Kuijpers T, van Middelkoop M, Rubinstein SM, et al. A systematic review on the effectiveness of pharmacological interventions for chronic non-specific low-back pain. Eur Spine J. 2011;20(1):40-50. [pmid: 20680369].
602 Martell BA, O'Connor PG, Kerns RD, et al. Systematic review: opioid treatment for chronic back pain: prevalence, efficacy, and association with addiction. Ann Intern Med. 2007;146(2):116-27. [pmid: 17227935].
603 Chou R, Turner JA, Devine EB, et al. The Effectiveness and Risks of Long-Term Opioid Therapy for Chronic Pain: A Systematic Review for a National Institutes of Health Pathways to Prevention WorkshopEffectiveness and Risks of Long-Term Opioid Therapy for Chronic Pain. Ann Intern Med. 2015;162(4):276-86. [pmid: 25581257].
604 Morasco BJ, Duckart JP, Carr TP, et al. Clinical characteristics of veterans prescribed high doses of opioid medications for chronic non-cancer pain. Pain. 2010;151(3):625-32. [pmid: 20801580].
605 Weisner CM, Campbell CI, Ray GT, et al. Trends in prescribed opioid therapy for non-cancer pain for individuals with prior substance use disorders. Pain. 2009;145(3):287-93. [pmid: 19581051].
606 Richards MC, Ford JJ, Slater SL, et al. The effectiveness of physiotherapy functional restoration for post-acute low back pain: a systematic review. Manual Ther. 2013;18(1):4-25. [pmid: 22796390].
607 Davies RA, Maher CG, Hancock MJ. A systematic review of paracetamol for non-specific low back pain. Eur Spine J. 2008;17(11):1423-30. [pmid: 18797937].
608 Machado GC, Maher CG, Ferreira PH, et al. Efficacy and safety of paracetamol for spinal pain and osteoarthritis: systematic review and meta-analysis of randomised placebo controlled trials. BMJ. 2015;350:h1225. [pmid: 25828856].
609 Ward N. Tricyclic antidepressants for chronic low-back pain. Mechanisms of ation and predictors of response. Spine (Phila Pa 1976). 1986;11(7):661-5. [pmid: 2947334].
610 U.S. Food and Drug Administration. FDA clears Cymbalta to treat chronic musculoskeletal pain. FDA News Release. [Press Release]. 2010. March 10th, 2015. 2015.
611 Cawston H, Davie A, Paget M-A, et al. Efficacy of duloxetine versus alternative oral therapies: an indirect comparison of randomised clinical trials in chronic low back pain. Eur Spine J. 2013;22(9):1996-2009. [pmid: 23686477].
612 Goertz CM, Pohlman KA, Vining RD, et al. Patient-centered outcomes of high-velocity, low-amplitude spinal manipulation for low back pain: a systematic review. J Electromyogr Kinesiol. 2012;22(5):670-91. [pmid: 22534288].
613 Brosseau L, Wells GA, Poitras S, et al. Ottawa Panel evidence-based clinical practice guidelines on therapeutic massage for low back pain. J Bodywork Mov Ther. 2012;16(4):424-55. [pmid: 23036876].
614 Hutchinson AJP, Ball S, Andrews JCH, et al. The effectiveness of acupuncture in treating chronic non-specific low back pain: a systematic review of the literature. J Orthop Surgery. 2012;7:36. [pmid: 23111099].
615 Xu M, Yan S, Yin X, et al. Acupuncture for chronic low back pain in long-term follow-up: a meta-analysis of 13 randomized controlled trials. Am J Chin Med. 2013;41(1):1-19. [pmid: 23336503].
616 Furlan AD, Yazdi F, Tsertsvadze A, et al. Complementary and alternative therapies for back pain II. Evid rep/technol assess. 2010;(194):1-764. [pmid: 23126534].
617 Netchanok S, Wendy M, Marie C, et al. The effectiveness of Swedish massage and traditional Thai massage in treating chronic low back pain: a review of the literature. Complement Ther Clin Pract. 2012;18(4):227-34. [pmid: 23059437].
618 Hidalgo B, Detrembleur C, Hall T, et al. The efficacy of manual therapy and exercise for different stages of non-specific low back pain: an update of systematic reviews. J Manual Manipulative Ther. 2014;22(2):59-74. [pmid: 24976749].
619 Ferreira ML, Smeets RJEM, Kamper SJ, et al. Can we explain heterogeneity among randomized clinical trials of exercise for chronic back pain? A meta-regression analysis of randomized controlled trials. Phys Ther. 2010;90(10):1383-403. [pmid: 20671101].
620 Searle A, Spink M, Ho A, et al. Exercise interventions for the treatment of chronic low back pain: A systematic review and meta-analysis of randomised controlled trials. Clin Rehabil. 2015. [pmid: 25681408].
621 Waller B, Lambeck J, Daly D. Therapeutic aquatic exercise in the treatment of low back pain: a systematic review. Clin Rehabil. 2009;23(1):3-14. [pmid: 19114433].
622 Yue Y-S, Wang X-D, Xie B, et al. Sling exercise for chronic low back pain: a systematic review and meta-analysis. PLoS ONE. 2014;9(6):e99307. [pmid: 24919119].
623 O'Connor SR, Tully MA, Ryan B, et al. Walking exercise for chronic musculoskeletal pain: systematic review and meta-analysis. Arch Phys Med Rehabil. 2015;96(4):724-34 e3. [pmid: 25529265].
624 Wang X-Q, Zheng J-J, Yu Z-W, et al. A meta-analysis of core stability exercise versus general exercise for chronic low back pain. PLoS ONE. 2012;7(12):e52082. [pmid: 23284879].
625 Laird RA, Kent P, Keating JL. Modifying patterns of movement in people with low back pain-does it help? A systematic review. BMC Musculoskelet Disord. 2012;13:169. [pmid: 22958597].
626 Ward L, Stebbings S, Cherkin D, et al. Yoga for functional ability, pain and psychosocial outcomes in musculoskeletal conditions: a systematic review and meta-analysis. Musculoskelet. 2013;11(4):203-17. [pmid: 23300142].
627 Holtzman S, Beggs RT. Yoga for chronic low back pain: a meta-analysis of randomized controlled trials. Pain Res Manag. 2013;18(5):267-72. [pmid: 23894731].
628 van Geen J-W, Edelaar MJA, Janssen M, et al. The long-term effect of multidisciplinary back training: a systematic review. Spine. 2007;32(2):249-55. [pmid: 17224822].
629 Bunzli S, Gillham D, Esterman A. Physiotherapy-provided operant conditioning in the management of low back pain disability: A systematic review. Physiother Res Int. 2011;16(1):4-19. [pmid: 20310071].
630 Schonstein E, Kenny DT, Keating J, et al. Work conditioning, work hardening and functional restoration for workers with back and neck pain. Cochrane Database Syst Rev. 2003;(1). CD001822. [pmid: 12535416].
631 Hill JC, Whitehurst DG, Lewis M, et al. Comparison of stratified primary care management for low back pain with current best practice (STarT Back): a randomised controlled trial. Lancet. 2011;378(9802):1560-71. [pmid: 21963002].
632 Dubinsky RM, Miyasaki J. Assessment: Efficacy of transcutaneous electric nerve stimulation in the treatment of pain in neurologic disorders (an evidence-based review): Report of the Therapeutics and Technology Assessment Subcommittee of the American Academy of Neurology. Neurology. 2010;74(2):173-6. [pmid: 20042705].
633 Luijsterburg PAJ, Verhagen AP, Ostelo RWJG, et al. Effectiveness of conservative treatments for the lumbosacral radicular syndrome: a systematic review. Eur Spine J. 2007;16(7):881-99. [pmid: 17415595].
634 Johnson M, Neher JO, St Anna L. Clinical inquiries. How effective--and safe--are systemic steroids for acute low back pain?. J Fam Pract. 2011;60(5):297-8. [pmid: 21544281].
635 Lewis RA, Williams NH, Sutton AJ, et al. Comparative clinical effectiveness of management strategies for sciatica: systematic review and network meta-analyses. Spine J. 2013. [pmid: 24412033].
636 Kalauokalani D, Cherkin DC, Sherman KJ, et al. Lessons from a trial of acupuncture and massage for low back pain: Patient expectations and treatment effects. Spine. 2001;26(13):1418-24. [pmid: 11458142].
637 Linde K, Witt CM, Streng A, et al. The impact of patient expectations on outcomes in four randomized controlled trials of acupuncture in patients with chronic pain. Pain. 2007;128(3):264-71. [pmid: 17257756].
638 Licciardone JC, Kearns CM, Minotti DE. Outcomes of osteopathic manual treatment for chronic low back pain according to baseline pain severity: results from the OSTEOPATHIC Trial. Manual Ther. 2013;18(6):533-40. [pmid: 23759340].
639 National Institute for Health and Care Excellence. Low back pain: Early management of persistent non-specific low back pain. NICE guidelines [CG88]. 2009. www.nice.org.uk/guidance/cg88. March, 10th, 2015.
640 Koes BW, Enthoven WT. Do patients with acute low-back pain need paracetamol?. Lancet. 2014;384(9954):1556-7. [pmid: 25064595].
641 Chou R, Fanciullo GJ, Fine PG, et al. Clinical guidelines for the use of chronic opioid therapy in chronic noncancer pain. J Pain. 2009;10(2):113-30. [pmid: 19187889].
642 Cleary-Guida MB, Okvat HA, Oz MC, et al. A regional survey of health insurance coverage for complementary and alternative medicine: current status and future ramifications. J Altern Complement Med. 2001;7(3):269-73. [pmid: 11439848].
643 Gatchel RJ, McGeary DD, McGeary CA, et al. Interdisciplinary chronic pain management: past, present, and future. Am Psychol. 2014;69(2):119-30. [pmid: 24547798].
644 Whitlock EP, Lin JS, Chou R, et al. Using Existing Systematic Reviews in Complex Systematic Reviews. Ann Intern Med. 2008;148(10):776-82. [pmid: 18490690].
645 Gagnier JJ, van Tulder M, Berman B, et al. Herbal medicine for low back pain. Cochrane Database Syst Rev. 2006;(2). CD004504. [pmid: 16625605].
646 Abdel Shaheed C, Maher CG, Williams KA, et al. Interventions available over the counter and advice for acute low back pain: systematic review and meta-analysis. J Pain. 2014;15(1):2-15. [pmid: 24373568].
647 Dupeyron A, Ribinik P, Gelis A, et al. Education in the management of low back pain: literature review and recall of key recommendations for practice. Ann Phys Rehabil Med. 2011;54(5):319-35. [pmid: 21782541].
648 Dahm KT, Brurberg KG, Jamtvedt G, et al. Advice to rest in bed versus advice to stay active for acute low-back pain and sciatica. Cochrane Database Syst Rev. 2010;(6). CD007612. [pmid: 20556780].
649 Chuter V, Spink M, Searle A, et al. The effectiveness of shoe insoles for the prevention and treatment of low back pain: a systematic review and meta-analysis of randomised controlled trials. BMC Musculoskelet Disord. 2014;15:140. [pmid: 24775807].
650 Huang C-Y, Choong M-Y, Li T-S. Effectiveness of cupping therapy for low back pain: a systematic review. Acupunct Med. 2013;31(3):336-7. [pmid: 23886511].
651 Oliveira VC, Ferreira PH, Maher CG, et al. Effectiveness of self-management of low back pain: systematic review with meta-analysis. Arthritis Care Res (Hoboken). 2012;64(11):1739-48. [pmid: 22623349].
652 Moore RA, Derry S, Wiffen PJ. Challenges in design and interpretation of chronic pain trials. Br J Anaesth. 2013;111(1):38-45. [pmid: 23794643].
653 van der Windt DA, Dunn KM. Low back pain research--future directions. Best Pract Res Clin Rheumatol. 2013;27(5):699-708. [pmid: 24315150].
654 Henschke N, Kuijpers T, Rubinstein SM, et al. Trends over time in the size and quality of randomised controlled trials of interventions for chronic low-back pain. Eur Spine J. 2012;21(3):375-81. [pmid: 22037844].
655 Pereira LM, Obara K, Dias JM, et al. Comparing the Pilates method with no exercise or lumbar stabilization for pain and functionality in patients with chronic low back pain: systematic review and meta-analysis. Clin Rehabil. 2012;26(1):10-20. [pmid: 21856719].
656 Seco J, Kovacs FM, Urrutia G. The efficacy, safety, effectiveness, and cost-effectiveness of ultrasound and shock wave therapies for low back pain: a systematic review. Spine J. 2011;11(10):966-77. [pmid: 21482199].
657 National Institute of Arthritis and Musculoskeletal and Skin Diseases (NIAMS). Effectiveness of Oral Prednisone in Improving Physical Functioning and Decreasing Pain in People with Sciatica (ACT FAST). Kaiser Permanente. 2008.
658 Pincus T, McCracken LM. Psychological factors and treatment opportunities in low back pain. Baillieres Best Pract Res Clin Rheumatol. 2013;27(5):625-35. [pmid: 24315144].
659 Patel S, Friede T, Froud R, et al. Systematic review of randomized controlled trials of clinical prediction rules for physical therapy in low back pain. Spine (Phila Pa 1976). 2013;38(9):762-9. [pmid: 23132535].
660 Kent P, Kjaer P. The efficacy of targeted interventions for modifiable psychosocial risk factors of persistent nonspecific low back pain - a systematic review. Manual Ther. 2012;17(5):385-401. [pmid: 22421188].
661 van der Giessen RN, Speksnijder CM, Helders PJM. The effectiveness of graded activity in patients with non-specific low-back pain: a systematic review. Disabil Rehabil. 2012;34(13):1070-6. [pmid: 22148906].
662 Balague F, Piguet V, Dudler J. Steroids for LBP - from rationale to inconvenient truth. Swiss Med Wkly. 2012;142:w13566. [pmid: 22495738].
663 Group Health Cooperative. Matching Appropriate Treatments to Consumers' Healthcare Needs, MATCH2014.
664 Delitto A. Targeted interventions to Prevent Chronic Low Back Pain in High Risk Patients: A Multi-Site Pragmatic RCT. Research & Results. 2015. www.pcori.org/research-results/2015/targeted-interventions-prevent-chronic-low-back-pain-high-risk-patients-multi. March 10th, 2015.
665 Foster NE, Hill JC, O'Sullivan P, et al. Stratified models of care. Best Pract Res Clin Rheumatol. 2013;27(5):649-61. [pmid: 24315146].