# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who provided input to this report follows:

- Daniel Cherkin, M.S., Ph.D.^*^
  * Provided comments on draft report.
  Group Health Research Institute
  Seattle, WA
- Julie M. Fritz, Ph.D., P.T., A.T.C.
  Research College of Health
  University of Utah
  Salt Lake City, UT
- Lee Glass, M.D.^*^
  Washington Department of Labor and Industries
  Olympia, WA
- Christine Goertz, D.C., Ph.D.^*^
  Patient-Centered Outcomes Research Institute
  Washington, DC
- Rowland G. Hazard, M.D., FACP^*^
  Professor of Orthopedics and Medicine
  Giesel School of Medicine at Dartmouth
  Lebanon, NH
- W. Michael Hooten, M.D.
  Mayo Clinic
  Rochester, MN
- Partap S. Khalsa, D.C., Ph.D.^*^
  National Center for Complementary and Integrative Health
  National Institutes of Health
  Bethesda, MD
- Kurt Kroenke, M.D., M.A.C.P.
  Indiana University Center for Health Services and Outcomes Research
  Indianapolis, IN
- Robert McLean, M.D.
  Hospital of Saint Raphael
  New Haven, CT
- Gavril Pasternak, M.D., Ph.D.^*^
  Memorial Sloan Kettering Cancer Center
  New York, NY
- Judith Turner, Ph.D.^*^
  University of Washington
  Seattle, WA
- Timothy Wilt, M.D., M.P.H.^*^
  VA Medical Center
  Minneapolis, MN