# Key Informants

In designing the study questions, the EPC consulted several Key Informants who represent the end-users of research. The EPC sought the Key Informant input on the priority areas for research and synthesis. Key Informants are not involved in the analysis of the evidence or the writing of the report. Therefore, in the end, study questions, design, methodological approaches, and/or conclusions do not necessarily represent the views of individual Key Informants.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any conflicts of interest.

The list of Key Informants who provided input to this report follows:

- Thiru Annaswamy, M.D.
  Department of Physical Medicine & Rehabilitation
  University of Texas Southwestern Medical Center
  Dallas, TX
- Gert Bronfort, D.C., Ph.D.
  Neck and Back Research Program
  Northwestern Health Sciences University
  Bloomington, MN
- Richard Deyo, M.D., M.P.H.
  Department of Family MedicineOregon Health & Science University
  Portland, OR
- Julie M. Fritz, Ph.D., P.T., A.T.C.
  Research College of Health
  University of Utah
  Salt Lake City, UT
- Scott Haldeman, M.D., Ph.D., D.C.
  Neurology
  University of California at Irvine
  Santa Ana, CA
- Michael Jabbour, M.S., LAc
  New York State Acupuncture Coalition
  Forest Hills, NY
- Peter Marshall, M.D.
  Minneapolis VA Medical Center
  Minneapolis, MN