# Investigator Affiliations

- Roger Chou, M.D., FACP
  Department of Medical Informatics & Clinical Epidemiology
  Oregon Health & Science University
- Richard Deyo, M.D., M.P.H.
  Department of Family Medicine
  Oregon Health & Science University
- Janna Friedly, M.D.
  Physical Medicine and Rehabilitation
  University of Washington
- Andrea Skelly, Ph.D., M.P.H.
  Spectrum Research
- Robin Hashimoto, Ph.D.
  Spectrum Research
- Melissa Weimer, D.O., M.C.R.
  Department of Medicine
  Oregon Health & Science University
- Rochelle Fu, Ph.D.
  Department of Public Health & Preventive Medicine
  Oregon Health & Science University
- Tracy Dana, M.L.S.
  Department of Medical Informatics & Clinical Epidemiology
  Oregon Health & Science University
- Paul Kraegel, M.S.W
  Department of Pharmacy
  University of Washington
- Jessica Griffin, M.S.
  Department of Medical Informatics & Clinical Epidemiology
  Oregon Health & Science University
- Sara Grusing, B.A.
  Department of Medical Informatics & Clinical Epidemiology
  Oregon Health & Science University
- Erika Brodt, B.S.
  Spectrum Research