# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Leah Williams, B.S., for editorial support; our Task Order Officer, Suchitra Iyer, Ph.D., for her support and guidance in developing this report; and our Associate Editor, Timothy Carey, M.D., M.P.H., for his review of this report.