# Discussion

## Key Findings and Strength of Evidence

The key findings or this review, including strength of evidence ratings are summarized in the summary of evidence table (Table 30); the factors used to determine the overall strength of evidence are summarized in Appendix H. This report updates a previous review that we conducted15, 16 for the American College of Physicians and American Pain Society, expanding upon it with new evidence and evaluation of several additional interventions (e.g., tai chi, taping, electrical muscle stimulation). This report also incorporates evidence on new drugs within previously reviewed classes (e.g., the antidepressant duloxetine and the antiseizure medication pregabalin). Because of the large number of interventions addressed in this review, reviewing all of the primary literature was not feasible. Therefore, we used relevant, well-conducted systematic reviews when available, including updates of systematic reviews included in our prior report, and supplemented prior reviews with additional trials that were published subsequent to the reviews or not included for other reasons. All conclusions are based on the totality of evidence (i.e., studies included in systematic reviews plus additional primary studies). Across interventions, pain intensity was the most commonly reported outcome, followed by back-specific function (typically measured using the Roland-Morris Disability Questionnaire [RDQ] or the Oswestry Disability Index [ODI]). When present, observed benefits were generally in the small (5 to 10 points on a 100-point visual analogue scale [VAS] or equivalent or standardized mean difference [SMD] of 0.2 to 0.5) to moderate (10 to 20 points, or SMD of 0.5 to 0.8) range for pain. Effects on function were typically smaller than effects on pain; in some cases there were positive effects on pain but not on function, and fewer studies measured function than pain. Other outcomes (such as quality of life, mood, work, analgesic use, or utilization of resources) were generally reported inconsistently and data were too sparse to reach reliable conclusions.

Table 30 Summary of evidence

Key Question | Intervention | Outcome | Strength of Evidence | Conclusion
Key Question 1. Pharmacological therapies | Acetaminophen | Acetaminophen vs. placebo, acute LBP: Pain and function | Low | One good-quality trial found no difference between acetaminophen vs. placebo in pain intensity or function through 3 weeks.
Key Question 1. Pharmacological therapies | Acetaminophen | Acetaminophen vs. NSAID, acute LBP: Pain and global improvement | Insufficient | A systematic review found no difference between acetaminophen vs. NSAIDs in pain intensity (3 trials; pooled SMD, 0.21; 95% CI, −0.02 to 0.43) or likelihood of experiencing global improvement (3 trials; RR, 0.81; 95% CI, 0.58 to 1.14) at ≤3 weeks, although estimates favored NSAIDs.
Key Question 1. Pharmacological therapies | Acetaminophen | Acetaminophen vs. placebo, chronic LBP | Insufficient | No study evaluated acetaminophen vs. placebo.
Key Question 1. Pharmacological therapies | Acetaminophen | Acetaminophen vs. NSAID, chronic LBP | Insufficient | There was insufficient evidence from 1 trial to determine effects of acetaminophen vs. NSAIDs.
Key Question 1. Pharmacological therapies | Acetaminophen | Acetaminophen vs. other interventions, acute LBP | Insufficient | There was insufficient evidence from 4 trials to determine effects of acetaminophen vs. other interventions.
Key Question 1. Pharmacological therapies | Acetaminophen | Acetaminophen vs. placebo: Adverse events (serious adverse events) | Moderate | One trial found no difference between scheduled acetaminophen, as-needed acetaminophen, or placebo in risk of serious adverse events (~1% in each group).
Key Question 1. Pharmacological therapies | Acetaminophen | Acetaminophen vs. NSAIDs: Adverse events | Moderate | A systematic review found that acetaminophen was associated with lower risk of side effects vs. NSAIDs.
Key Question 1. Pharmacological therapies | Acetaminophen | Acetaminophen vs placebo, NSAID, or other intervention, radicular LBP | Insufficient | No study evaluated acetaminophen for radicular low back pain.
Key Question 1. Pharmacological therapies | NSAIDs | NSAIDs vs. placebo, acute LBP: Pain and function | Moderate for pain, low for function | A systematic review found NSAIDs to be associated with greater improvement in pain intensity vs. placebo (4 studies; WMD, −8.39; 95% CI, −12.68 to −4.10; chi-square, 3.47; p >0.1), but 4 trials found no clear effects on the likelihood of achieving significant pain relief. One subsequent trial also found lower pain intensity after the first dose vs. placebo. One trial found NSAIDs to be associated with better function vs. placebo.
Key Question 1. Pharmacological therapies | NSAIDs | NSAIDs vs. placebo, chronic LBP: Pain and function | Moderate for pain, low for function | A systematic review found NSAIDs to be associated with greater improvement in pain vs. placebo (4 trials; WMD, −12.40; 95% CI, −15.53 to −9.26; chi-square, 1.82; p >0.5); 2 trials found NSAIDs to be associated with greater improvement in function.
Key Question 1. Pharmacological therapies | NSAIDs | NSAIDs vs. placebo, radicular LBP: Pain | Low | A systematic review found no difference in pain intensity between NSAIDs vs. placebo (2 trials; WMD, −0.16; 95% CI, −11.92 to 11.59; chi-square, 7.25; p <0.01).
Key Question 1. Pharmacological therapies | NSAIDs | NSAID plus another intervention vs. other intervention alone | Insufficient | There was insufficient evidence from 2 trials of an NSAID plus another intervention vs. the other intervention alone to determine effectiveness.
Key Question 1. Pharmacological therapies | NSAIDs | NSAIDs vs. interventions other than acetaminophen and opioids | Insufficient | There was insufficient evidence from 2 trials to determine the effects of NSAIDs vs. interventions other than acetaminophen and opioids.
Key Question 1. Pharmacological therapies | NSAIDs | NSAID vs. NSAID, acute or chronic LBP: Pain | Moderate | A systematic review found that most trials of 1 NSAID vs. another found no differences in pain relief in patients with acute LBP (15 of 21 trials) or chronic LBP (6 of 6 trials).
Key Question 1. Pharmacological therapies | NSAIDs | NSAIDs vs. placebo: Adverse events | Moderate | A systematic review found NSAIDs to be associated with more side effects vs. placebo (10 trials; RR, 1.35; 95% CI, 1.09 to 1.68).
Key Question 1. Pharmacological therapies | NSAIDs | COX-2-selective NSAIDs vs. nonselective NSAIDs: Adverse events | Moderate | COX-2-selective NSAIDs were associated with lower risk of side effects vs. nonselective NSAIDs (4 trials; RR, 0.83; 95% CI, 0.70 to 0.99).
Key Question 1. Pharmacological therapies | Opioids, tramadol, and tapentadol | Opioids vs. placebo, chronic LBP: Pain and function | Moderate | A systematic review found opioids to be associated with greater short-term improvement vs. placebo in pain scores (6 trials; SMD, −0.43; 95% CI, −0.52 to −0.33; I^2^ = 0.0%, for a mean difference of ~1 point on a 0–10 pain scale) and function (4 trials; SMD, −0.26; 95% CI, −0.37 to −0.15; I^2^ = 0.0%, for a mean difference of ~1 point on the RDQ); 3 additional trials reported results consistent with the systematic review.
Key Question 1. Pharmacological therapies | Opioids, tramadol, and tapentadol | Tramadol vs. placebo, chronic LBP: Pain and function | Moderate | A systematic review found tramadol to be associated with greater short-term pain relief vs. placebo (5 trials; SMD, −0.55; 95% CI, −0.66 to −0.44; I^2^ = 86%, for a mean difference of 1 point or less on a 0–10 pain scale) and function (5 trials; SMD, −0.18; 95% CI, −0.29 to −0.07; I^2^ = 0%, for a mean difference of ~1 point on the RDQ); 2 trials not included in the systematic review reported results consistent with the systematic review findings.
Key Question 1. Pharmacological therapies | Opioids, tramadol, and tapentadol | Buprenorphine patch vs. placebo, subacute or chronic LBP: Pain and function | Low for pain, insufficient for function | A systematic review included 2 trials that found buprenorphine patches to be associated with greater short-term improvement in pain vs. placebo patches; effects on function showed no clear effect or were unclearly reported.
Key Question 1. Pharmacological therapies | Opioids, tramadol, and tapentadol | Opioids vs. NSAIDs, chronic LBP: Pain relief, function | Insufficient | Three trials reported inconsistent effects of opioids vs. NSAIDs for pain relief; 1 trial found no difference in function.
Key Question 1. Pharmacological therapies | Opioids, tramadol, and tapentadol | Opioids vs. acetaminophen, acute LBP: Days to return to work, pain | Insufficient | One trial found no significant differences between opioids vs. acetaminophen in days to return to work; pain was not reported.
Key Question 1. Pharmacological therapies | Opioids, tramadol, and tapentadol | Long acting opioids vs. long-acting opioids: Pain and function | Moderate | Four trials found no clear differences among different long-acting opioids in pain or function.
Key Question 1. Pharmacological therapies | Opioids, tramadol, and tapentadol | LongL-acting opioids vs. short-acting opioids: Pain | Low | Six trials found no clear differences between long-acting vs. short-acting opioids in pain relief. Although some trials found long-acting opioids to be associated with greater pain relief, patients randomized to long-acting opioids also received higher doses of opioids.
Key Question 1. Pharmacological therapies | Opioids, tramadol, and tapentadol | Opioids vs. placebo: Adverse events | Moderate | Short-term use of opioids was associated with higher risk vs. placebo of nausea, dizziness, constipation, vomiting, somnolence, and dry mouth; risks of opioids were higher in trials that did not use an enriched enrollment and withdrawal design.
Key Question 1. Pharmacological therapies | Skeletal muscle relaxants | SMRs vs. placebo, acute LBP: Pain | Moderate | A systematic review found SMRs to be superior to placebo for short-term pain relief (≥2-point or 30% improvement on a 0–10 VAS pain scale) after 2 to 4 days (4 trials; RR, 1.25; 95% CI, 1.12 to 1.41; I^2^ = 0%) and 5 to 7 days (3 trials; RR, 1.72; 95% CI, 1.32 to 2.22; I^2^ = 0%); a more recent large (n = 562) trial was consistent with the systematic review.
Key Question 1. Pharmacological therapies | Skeletal muscle relaxants | SMR plus NSAID vs. NSAID alone, acute LBP: Pain | Low | A systematic review found no difference between an SMR plus an NSAID vs. the NSAID alone in the likelihood of experiencing pain relief, although the estimate favored combination therapy (2 trials; RR, 1.56; 95% CI, 0.92 to 2.70; I^2^ = 84%); 1 other trial (n = 197) also reported results that favored combination therapy.
Key Question 1. Pharmacological therapies | Skeletal muscle relaxants | SMR vs. placebo, chronic LBP: Pain | Insufficient | Evidence from 3 placebo-controlled trials was insufficient to determine effects due to imprecision and inconsistent results.
Key Question 1. Pharmacological therapies | Skeletal muscle relaxants | SMR vs. SMR, acute or chronic LBP: Pain | Low | Three trials in a systematic review found no differences in any outcome among different SMRs for acute or chronic low back pain.
Key Question 1. Pharmacological therapies | Skeletal muscle relaxants | SMR vs. placebo, acute LBP: Adverse events | Moderate | A systematic review found skeletal muscle relaxants for acute LBP to be associated with increased risk of any adverse event vs. placebo (8 trials; RR, 1.50; 95% CI, 1.14 to 1.98) and increased risk of central nervous system events, primarily sedation (8 trials; RR, 2.04; 95% CI, 1.23 to 3.37; I^2^ = 50%); 1 additional placebo-controlled trial was consistent with these findings.
Key Question 1. Pharmacological therapies | Benzodiazepines | Benzodiazepines vs. placebo, acute LBP: Pain and function | Insufficient | There was insufficient evidence from 2 trials with inconsistent results to determine effectiveness of benzodiazepines vs. placebo.
Key Question 1. Pharmacological therapies | Benzodiazepines | Tetrazepam vs. placebo, chronic LBP: Pain, overall improvement | Low | A systematic review included 2 trials that found tetrazepam to be associated with lower likelihood of no improvement in pain at 5–7 days (RR, 0.82; 95% CI, 0.72 to 0.94) and at 10–14 days (RR, 0.71; 95% CI, 0.54 to 0.93) vs. placebo, and lower likelihood of no overall improvement at 10–14 days (RR, 0.63; 95% CI, 0.42 to 0.97).
Key Question 1. Pharmacological therapies | Benzodiazepines | Diazepam vs. placebo, acute or subacute radicular pain: Pain and function | Low | One trial found no difference between diazepam 5 mg twice daily for 5 days vs. placebo in function at 1 week through 1 year or in other outcomes, including analgesic use, return to work, or likelihood of surgery through 1 year of followup. Diazepam was associated with lower likelihood of experiencing ≥50% improvement in pain at 1 week (41% vs. 79%; RR, 0.5; 95% CI, 0.3 to 0.8).
Key Question 1. Pharmacological therapies | Benzodiazepines | Benzodiazepines vs. SMRs, chronic LBP: Pain and function | Insufficient | There was insufficient evidence from 2 trials with inconsistent results to determine effects of benzodiazepines vs. SMRs.
Key Question 1. Pharmacological therapies | Benzodiazepines | Diazepam vs. cyclobenzaprine, chronic LBP: Muscle spasms | Low | One trial found no difference between diazepam vs. cyclobenzaprine in outcomes related to muscle spasm.
Key Question 1. Pharmacological therapies | Benzodiazepines | Benzodiazepines vs. placebo: Adverse events | Low | A systematic review found that central nervous system adverse events such as somnolence, fatigue, and lightheadedness were reported more frequently with benzodiazepines vs. placebo, although harms were not reported well; no trial was designed to evaluate risks with long-term use of benzodiazepines such as addiction, abuse, or overdose.
Key Question 1. Pharmacological therapies | Antidepressants | Tricyclic antidepressants or SSRIs vs. placebo, chronic LBP: Pain and function | Moderate for pain, low for function | A systematic review found no differences in pain between tricyclic antidepressants vs. placebo (4 trials; SMD, −0.10; 95% CI, −0.51 to 0.31; I^2^ = 32%) or SSRIs vs. placebo (3 trials; SMD, 0.11; 95% CI, −0.17 to 0.39; I^2^ = 0%); there was also no difference between antidepressants vs. placebo in function (2 trials; SMD, −0.06; 95% CI, −0.40 to 0.29; I^2^ = 0%).
Key Question 1. Pharmacological therapies | Antidepressants | Duloxetine vs. placebo, chronic LBP: Pain and function | Moderate | Three trials found duloxetine to be associated with lower pain intensity (differences, 0.58 to 0.74 on a 0 to 10 scale) and better function (differences, 0.58 to 0.74 on the Brief Pain Inventory-Interference scale) vs. placebo.
Key Question 1. Pharmacological therapies | Antidepressants | Duloxetine vs. tricyclic antidepressants | Insufficient | No study compared duloxetine vs. a tricyclic antidepressant.
Key Question 1. Pharmacological therapies | Antidepressants | Antidepressants vs. placebo: Adverse events, serious adverse events | Moderate | Antidepressants were associated with higher risk of any adverse events compared with placebo, with no difference in risk of serious adverse events.
Key Question 1. Pharmacological therapies | Antiseizure medications | Antiseizure medications, acute nonradicular LBP | Insufficient | No trial evaluated antiseizure medications for acute nonradicular LBP.
Key Question 1. Pharmacological therapies | Antiseizure medications | Gabapentin vs. placebo, chronic nonradicular LBP | Insufficient | One trial found no difference between gabapentin (up to 3600 mg/day) vs. placebo but did not meet inclusion criteria because it was published only as an abstract.
Key Question 1. Pharmacological therapies | Antiseizure medications | Gabapentin vs. placebo, chronic radicular LBP: Pain and function | Insufficient | There was insufficient evidence from 3 poor-quality trials with inconsistent findings to determine effects of gabapentin vs. placebo.
Key Question 1. Pharmacological therapies | Antiseizure medications | Topiramate vs. placebo, chronic radicular or mixed radicular and nonradicular LBP: Pain | Insufficient | Two trials reported inconsistent results for effects of topiramate vs. placebo.
Key Question 1. Pharmacological therapies | Antiseizure medications | Pregabalin vs. placebo, chronic radicular LBP: Pain and function | Insufficient | Two trials reported inconsistent effects of pregabalin vs. placebo for pain or function.
Key Question 1. Pharmacological therapies | Antiseizure medications | Pregabalin vs. amitriptyline: Pain | Insufficient | There was insufficient evidence from 1 poor-quality trial to determine effects of pregabalin vs. amitriptyline.
Key Question 1. Pharmacological therapies | Antiseizure medications | Pregabalin plus transdermal buprenorphine vs. transdermal buprenorphine, chronic nonradicular LBP: Pain | Insufficient | One small trial found that the addition of pregabalin 300 mg/day to transdermal buprenorphine was associated with substantially lower pain scores than transdermal buprenorphine alone at 3 weeks (difference, ~26 points on a 0 to 100 scale; p <0.05), but the estimate was very imprecise.
Key Question 1. Pharmacological therapies | Antiseizure medications | Pregabalin plus another analgesic vs. the other analgesic alone: Pain | Insufficient | One trial found pregabalin (mean, 2.1 mg/kg/day) plus celecoxib to be associated with lower pain scores than celecoxib alone (difference, 11 points on a 0–100 scale; p = 0.001) after 4 weeks, and 1 trial found no effects of adding pregabalin (titrated to 300 mg/day) to tapentadol prolonged release vs. tapentadol prolonged release alone on pain or the SF-12 after 8 weeks.
Key Question 1. Pharmacological therapies | Antiseizure medications | Gabapentin vs. placebo: Adverse events | Low | Two trials of gabapentin vs. placebo reported no clear differences in risk of adverse events.
Key Question 1. Pharmacological therapies | Antiseizure medications | Topiramate vs. placebo: Withdrawal due to adverse events, sedation, diarrhea | Insufficient | Two trials of topiramate vs. placebo reported inconsistent effects on risk of withdrawal due to adverse events; 1 of the trials found topiramate to be associated with higher risk of sedation and diarrhea.
Key Question 1. Pharmacological therapies | Antiseizure medications | Pregabalin vs. placebo: Withdrawal due to adverse events, somnolence, dizziness | Insufficient | Two trials of pregabalin vs. placebo reported inconsistent effects on risk of withdrawal due to adverse events, somnolence, and dizziness; 1 of the trials used an enrichment/withdrawal design.
Key Question 1. Pharmacological therapies | Corticosteroids | Systemic corticosteroids vs. placebo, acute nonradicular LBP: Pain and function | Low | Two trials found no differences between a single intramuscular injection or a 5-day course of systemic corticosteroids vs. placebo for pain or function.
Key Question 1. Pharmacological therapies | Corticosteroids | Systemic corticosteroids vs. placebo, radicular LBP: Pain and function | Moderate | Five trials consistently found no differences between systemic corticosteroids (administered as a single bolus or as a short taper) vs. placebo in pain or function for acute or unspecified-duration LBP; 1 trial found no effect on need for spine surgery.
Key Question 1. Pharmacological therapies | Corticosteroids | Systemic corticosteroids vs. placebo, spinal stenosis: Pain and function | Low | One trial found no differences through 12 weeks of followup between a 3-week course of prednisone vs. placebo in pain intensity, the RDQ, or any SF-36 subscale.
Key Question 1. Pharmacological therapies | Corticosteroids | Systemic corticosteroids: Adverse events | Low | Trials of systemic corticosteroids did not report serious adverse events, including hyperglycemia requiring medical treatment, but adverse events were not reported well in some trials.
Key Question 2. Nonpharmacological noninvasive therapies | Exercise | Exercise vs. no exercise, acute to subacute LBP: Pain and function | Low | A systematic review found no differences between exercise therapy vs. no exercise in pain (3 trials; WMD, 0.59 at intermediate term on a 0 to 100 scale; 95% CI, −11.51 to 12.69) or function (3 trials; WMD at short term, −2.82; 95% CI, −15.35 to 9.71; WMD at intermediate term, 2.47; 95% CI, −0.26 to 5.21). For subacute LBP, there were also no differences in pain (5 trials; WMD, 1.89 on a 100-point scale; 95% CI, −1.13 to 4.91) or function (4 trials; WMD, 1.07; 95% CI, −3.18 to 5.32). Three subsequent trials for acute to subacute LBP reported inconsistent effects of exercise vs. usual care on pain and function.
Key Question 2. Nonpharmacological noninvasive therapies | Exercise | Exercise vs. no exercise, chronic LBP: Pain and function | Moderate | A systematic review found exercise to be associated with greater pain relief vs. no exercise (19 trials; WMD, 10 on a 0 to 100 scale; 95% CI, 1.31 to 19.09), although the effect on function was small and not statistically significant (17 trials; WMD, 3.00 on a 0 to 100 scale; 95% CI, −0.53 to 6.48). Results from a more recent systematic review using more restrictive criteria and from additional trials not included in the systematic reviews were generally consistent with these findings.
Key Question 2. Nonpharmacological noninvasive therapies | Exercise | MCE vs. minimal intervention, chronic LBP: Pain and function | Low | A systematic review included 2 trials that found MCE to be associated with lower pain scores in the short term (WMD, −12.48 on a 0 to 100 scale; 95% CI, −19.04 to −5.93), intermediate term (WMD, −10.18; 95% CI, −16.64 to −3.72), and long term (WMD, −13.32; 95% CI, −19.75 to −6.90) vs. a minimal intervention. MCE was also associated with better function at short term (3 trials; WMD, −9.00 on 0 to 100 scale; 95% CI, −15.28 to −2.73), intermediate term (2 trials; WMD, −5.62; 95% CI, −10.46 to −0.77), and long term (2 trials; WMD, −6.64; 95% CI, −11.72 to −1.57).
Key Question 2. Nonpharmacological noninvasive therapies | Exercise | Exercise vs. usual care, nonacute LBP: Work disability | Moderate | A systematic review found no clear effects of exercise therapy versus usual care on likelihood of short- or intermediate-term (~6 months) disability, but exercise was associated with lower likelihood of work disability at long term (~12 months) followup (10 comparisons in 8 trials; OR, 0.66; 95% CI, 0.48 to 0.92).
Key Question 2. Nonpharmacological noninvasive therapies | Exercise | Exercise vs. usual care, radicular LBP: Pain and function | Low | Three trials not included in the systematic reviews found effects that favored exercise vs. usual care or no exercise in pain and function, although effects were small.
Key Question 2. Nonpharmacological noninvasive therapies | Exercise | MCE vs. general exercise, chronic LBP: Pain and function | Low | A systematic review found MCE to be associated with lower pain intensity at short term (6 trials; WMD, −7.80 on 0 to 100 scale; 95% CI, −10.95 to −4.65) and intermediate term (3 trials; WMD, −6.06; 95% CI, −10.94 to −1.18) vs. general exercise, but effects were smaller and no longer statistically significant at long term (4 trials; WMD, −3.10; 95% CI, −7.03 to 0.83). MCE was also associated with better function in the short term (6 trials; WMD, −4.65 on 0 to 100 scale; 95% CI, −6.20 to −3.11) and long term (3 trials; WMD, −4.72; 95% CI, −8.81 to −0.63). One of 2 subsequent trials found no effect on pain, although effects on function were consistent with the systematic review.
Key Question 2. Nonpharmacological noninvasive therapies | Exercise | Exercise vs. exercise, acute or chronic LBP | Moderate | For comparisons involving other types of exercise techniques, there were no clear differences in >20 head-to-head trials of patients with acute or chronic LBP.
Key Question 2. Nonpharmacological noninvasive therapies | Exercise | Exercise: Adverse events | Low | Harms were poorly reported in trials of exercise. When reported, harms were typically related to muscle soreness and increased pain, or no harms were reported; no serious harms were reported.
Key Question 2. Nonpharmacological noninvasive therapies | Pilates | Pilates vs. usual care plus physical activity, chronic LBP: Pain and function | Low | A systematic review included 7 trials that found Pilates to be associated with small (mean difference, −1.6 to −4.1 points) or no clear effects on pain at the end of treatment vs. usual care plus physical activity and no clear effects on function.
Key Question 2. Nonpharmacological noninvasive therapies | Pilates | Pilates vs. other exercise, chronic LBP: Pain and function | Low | Three trials found no clear differences between Pilates vs. other types of exercise in pain or function.
Key Question 2. Nonpharmacological noninvasive therapies | Tai chi | Tai chi vs. wait list or no tai chi, chronic LBP: Pain and function | Low | Two trials found tai chi to be associated with improved pain-related outcomes vs. wait list or no tai chi (mean differences, 0.9 and 1.3 on a 0 to 10 scale); 1 trial also found tai chi to be associated with better function (mean difference, 2.6 on the RDQ; 95% CI, 1.1 to 3.7).
Key Question 2. Nonpharmacological noninvasive therapies | Tai chi | Tai chi vs. other exercise, chronic LBP: Pain | Low | One trial found tai chi to be associated with lower pain intensity vs. backward walking or jogging through 6 months (mean differences, −0.7 and −0.8), but there were no differences vs. swimming.
Key Question 2. Nonpharmacological noninvasive therapies | Tai chi | Tai chi: Adverse events | Low | One trial of tai chi reported a small temporary increase in back pain symptoms, and 1 trial reported no harms.
Key Question 2. Nonpharmacological noninvasive therapies | Yoga | Yoga vs. usual care, chronic LBP: Pain and function | Low | One trial found Iyengar yoga to be associated with lower pain scores (24 vs. 37 on a 0–100 VAS; p <0.001) and better function (18 vs. 21 on the 0 to 100 ODI; p <0.01, on a 0 to 100 scale) vs. usual care at 24 weeks.
Key Question 2. Nonpharmacological noninvasive therapies | Yoga | Yoga vs. exercise, chronic LBP: Pain and function | Low | A systematic review found yoga to be associated with lower pain intensity and better function vs. exercise in most trials, although effects were small and differences were not always statistically significant (5 trials).
Key Question 2. Nonpharmacological noninvasive therapies | Yoga | Yoga vs. education, chronic LBP: Pain and function | Moderate | Yoga was associated with lower short-term pain intensity vs. education (5 trials; SMD, −0.45; 95% CI, −0.63 to −0.26; I^2^ = 0%), but effects were smaller and not statistically significant at long term followup (4 trials; SMD, −0.28; 95% CI, −0.58 to −0.02; I^2^ = 47%); yoga was also associated with better function at short-term (5 trials; SMD, 0.45; 95% CI, −0.65 to −0.25; I^2^ = 8%) and long-term followup (4 trials; SMD, 0.39; 95% CI, −0.66 to −0.11; I^2^ = 40%).
Key Question 2. Nonpharmacological noninvasive therapies | Yoga | Yoga: Adverse events | Low | Reporting of harms was suboptimal, but adverse events, when reported, were almost all classified as mild to moderate.
Key Question 2. Nonpharmacological noninvasive therapies | Psychological therapies | Progressive relaxation vs. wait-list control, chronic LBP: Pain and function | Low | A systematic review found progressive relaxation superior to wait-list control for post-treatment pain intensity (3 trials; mean difference, −19.77 on 0 to 100 VAS; 95% CI, −34 to −5.20; I^2^ = 57%) and functional status (3 trials; SMD, −0.88; 95% CI, −1.36 to −0.39; I^2^ = 0%).
Key Question 2. Nonpharmacological noninvasive therapies | Psychological therapies | EMG biofeedback, chronic LBP: Pain and function | Low | A systematic review found EMG biofeedback to be associated with lower pain intensity at the end of treatment (3 trials; SMD, −0.80; 95% CI, −1.32 to −0.28; I^2^ = 0%), with no clear effect on function (3 trials).
Key Question 2. Nonpharmacological noninvasive therapies | Psychological therapies | Operant therapy, chronic LBP: Pain and function | Low | A systematic review found operant therapy to be associated with lower pain intensity at the end of treatment (3 trials; SMD, −0.43; 95% CI, −0.75 to −0.1; I^2^ = 0%), with no clear effect on function (2 trials).
Key Question 2. Nonpharmacological noninvasive therapies | Psychological therapies | Cognitive therapy vs. wait-list control, chronic LBP | Insufficient | There was insufficient evidence from 2 trials to determine effects of cognitive therapy vs. wait-list control due to inconsistency and imprecision.
Key Question 2. Nonpharmacological noninvasive therapies | Psychological therapies | Cognitive-behavioral and other combined therapy vs. wait-list control, chronic LBP: Pain and function | Low | A systematic review found cognitive-behavioral and other combined psychological therapy to be associated with greater improvements in post-treatment pain intensity compared with wait-list control (5 trials; SMD, −0.60; 95% CI, −0.97 to −0.22; I^2^ = 40%), but effects on function were smaller and not statistically significant (4 trials; SMD, −0.37; 95% CI, −0.87 to 0.13; I^2^ = 50%).
Key Question 2. Nonpharmacological noninvasive therapies | Psychological therapies | Psychological therapies vs. exercise or physical therapy, chronic LBP: Pain and function | Low | A systematic review found no clear differences between psychological therapies vs. exercise therapy in pain intensity (2 trials) or between psychological therapies plus physiotherapy vs. physiotherapy alone (6 trials) in pain or function, although 1 small subsequent trial found combination therapy to be associated with greater improvements in pain and function immediately after treatment.
Key Question 2. Nonpharmacological noninvasive therapies | Psychological therapies | Psychological therapies vs. psychological therapies: Pain and function | Moderate | Ten trials found no clear differences among different psychological therapies in pain or function.
Key Question 2. Nonpharmacological noninvasive therapies | Psychological therapies | Psychological therapies: Adverse events | Low | Harms were not well reported, but no included trial reported any adverse events associated with psychological therapies.
Key Question 2. Nonpharmacological noninvasive therapies | Multidisciplinary rehabilitation | Multidisciplinary rehabilitation vs. usual care, chronic LBP: Pain, function, return to work | Moderate | A systematic review found multidisciplinary rehabilitation, compared with usual care, to be associated with lower short-term pain intensity (9 trials; SMD, −0.55; 95% CI, −0.83 to −0.28; I^2^ = 72%, or ~1.4-point mean difference on a 0 to 10 point numeric rating scale) and disability (9 trials; SMD, −0.41; 95% CI, −0.62 to −0.19; I^2^ = 58%, or ~2.5-point mean difference on the RDQ); effects on long-term pain intensity and disability also favored multidisciplinary rehabilitation but were smaller (7 trials; SMD, −0.21; 95% CI, −0.37 to −0.04; I^2^ = 25% and 6 trials; SMD,−0.23; 95% CI, −0.40 to −0.06; I^2^ = 19%, respectively), with no difference in likelihood of return to work (7 trials; OR, 1.04; 95% CI, 0.73 to 1.47; I^2^ = 31%).
Key Question 2. Nonpharmacological noninvasive therapies | Multidisciplinary rehabilitation | Multidisciplinary rehabilitation vs. no multidisciplinary rehabilitation, chronic LBP: Pain and function | Low | A systematic review found multidisciplinary rehabilitation, compared with no multidisciplinary rehabilitation, to be associated with lower short-term pain intensity (3 trials; SMD, −0.73; 95% CI, −1.22 to −0.24; I^2^ = 64%, or ~1.7-point mean difference on a 0 to 10 numeric rating scale) and disability (3 trials; pooled SMD, −0.49; 95% CI, −0.76 to −0.22; I^2^ = 0%, or ~2.9-point mean difference on the RDQ); there was insufficient evidence to assess effects on long-term outcomes.
Key Question 2. Nonpharmacological noninvasive therapies | Multidisciplinary rehabilitation | Multidisciplinary rehabilitation vs. physical therapy, chronic LBP: Pain and function | Moderate | A systematic review found multidisciplinary rehabilitation, compared with nonmultidisciplinary physical therapy, to be associated with lower short-term pain intensity (12 trials; SMD, −0.30; 95% CI, −0.54 to −0.06; I^2^ = 80%, or an approximate 0.6-point mean difference on a 0 to 10 point numeric rating scale) and disability (13 trials; SMD, −0.39; 95% CI, −0.68 to −0.10; I^2^ = 88%, or an approximate 1.2-point mean difference on the RDQ); multidisciplinary rehabilitation was also associated with lower long-term pain intensity (9 trials; SMD, −0.51; 95% CI, −1.04 to 0.01; I^2^ = 92%) and function (10 trials; SMD, −0.68; 95% CI, −1.19 to −0.16; I^2^ = 94%) and greater likelihood for return to work (8 trials; OR, 1.87; 95% CI, 1.39 to 2.53; I^2^ = 0%).
Key Question 2. Nonpharmacological noninvasive therapies | Multidisciplinary rehabilitation | Multidisciplinary rehabilitation, acute LBP, radicular LBP | Insufficient | No study evaluated the effectiveness of multidisciplinary rehabilitation for acute LBP or for radicular LBP.
Key Question 2. Nonpharmacological noninvasive therapies | Multidisciplinary rehabilitation | Multidisciplinary rehabilitation: Adverse events | Low | Harms were poorly reported in trials of multidisciplinary rehabilitation, although no serious harms were reported.
Key Question 2. Nonpharmacological noninvasive therapies | Acupuncture | Acupuncture vs. sham acupuncture, subacute LBP: Pain | Low | A systematic review found acupuncture to be associated with lower pain intensity vs. sham acupuncture using nonpenetrating needles (2 trials; mean difference, 9.38 on a 0 to 100 VAS; 95% CI, 1.76 to 17.0; I^2^ = 27%); 3 other trials reported effects consistent with these findings. One trial of sham acupuncture using penetrating needles to nonacupuncture points found no effect on pain. There were no clear effects on function in 5 trials.
Key Question 2. Nonpharmacological noninvasive therapies | Acupuncture | Acupuncture vs. sham acupuncture, chronic LBP: Pain and function | Moderate | A systematic review found acupuncture to be associated with lower pain intensity vs. sham acupuncture (superficial needling at acupuncture or nonacupuncture points or nonpenetrating pressure at acupuncture points) immediately at the end of treatment (4 trials; WMD, −16.76; 95% CI, −33.3 to −0.19; I^2^ = 90%) and at up to 12 weeks (3 trials; WMD, −9.55; 95% CI, −16.5 to −2.58; I^2^ = 40%), but there were no differences in function. Four additional trials reported results consistent with these findings.
Key Question 2. Nonpharmacological noninvasive therapies | Acupuncture | Acupuncture vs. no acupuncture, chronic LBP | Moderate | A systematic review found acupuncture to be associated with lower pain intensity (4 trials; SMD, −0.72; 95% CI, −0.94 to −0.49; I^2^ = 51%) and better function (3 trials; SMD, −0.94; 95% CI, −1.41 to −0.47; I^2^ = 78%) immediately after treatment vs. no acupuncture. Mean effects on pain ranged from 7 to 24 points on a 0 to 100 point scale; for function, 1 trial reported a difference of 8 points on a 0 to 100 scale and the other 2 trials showed small or no clear differences at long-term followup.
Key Question 2. Nonpharmacological noninvasive therapies | Acupuncture | Acupuncture vs. NSAIDs, acute LBP: Overall improvement | Low | A systematic review found acupuncture to be associated with slightly greater likelihood of overall improvement vs. NSAIDs at the end of treatment (5 trials; RR, 1.11; 95% CI, 1.06 to 1.16; I^2^ = 0%).
Key Question 2. Nonpharmacological noninvasive therapies | Acupuncture | Acupuncture vs. medications (NSAIDs, muscle relaxants and analgesics), chronic LBP: Pain and function | Low | A systematic review found acupuncture to be associated with better pain relief (3 trials; WMD, −10.56 on a 0 to 100 scale; 95% CI, −20.34 to −0.78; I ^2^ = 0%) and improvement in function (3 trials; SMD, −0.36; 95% CI, −0.67 to −0.04; I^2^ = 7%) immediately postintervention.
Key Question 2. Nonpharmacological noninvasive therapies | Acupuncture | Acupuncture: Adverse events | Low | Harms of acupuncture were poorly reported in the trials, although no serious adverse events were reported.
Key Question 2. Nonpharmacological noninvasive therapies | Massage | Massage vs. sham massage, acute LBP: Pain and function | Low | A systematic review included 2 trials that found massage to be associated with greater short-term (1 week) improvement in pain (SMD, −0.92; 95% CI, −1.35 to −0.48) and function (SMD, −1.76; 95% CI, −3.19 to −0.32) vs. sham therapy, but there was no difference in pain or function at 5 weeks in 1 trial.
Key Question 2. Nonpharmacological noninvasive therapies | Massage | Massage vs. usual care, chronic LBP: Pain and function | Low | One trial found no difference between foot reflexology vs. usual care in pain or function, and 1 trial found structural or relaxation massage to be associated with better function (mean, 2.5 to 2.9 points on the RDQ) vs. usual care at 10 weeks; effects were less pronounced at 52 weeks.
Key Question 2. Nonpharmacological noninvasive therapies | Massage | Massage vs. other interventions, subacute to chronic LBP: Pain and function | Moderate | A systematic review found massage to be associated with better effects on short-term pain in 7 of 9 trials (mean differences, −0.6 to −0.94 points on a 0 to 10 scale) and better effects on short-term function in 3 of 4 trials.
Key Question 2. Nonpharmacological noninvasive therapies | Massage | Massage plus another active intervention vs. the other intervention alone, subacute to chronic LBP: Pain and function | Low | A systematic review included 5 trials that generally found massage plus another intervention to be superior to the other intervention without massage for short-term pain, with effects somewhat stronger in trials in which massage was combined with exercise; few differences were observed for function or long-term pain. Two subsequent trials of massage plus exercise reported findings generally consistent with these findings.
Key Question 2. Nonpharmacological noninvasive therapies | Massage | Massage vs. massage: Pain and function | Insufficient | Comparisons of different massage techniques were too heterogeneous and effects were too small from 6 trials to determine effects on pain and function.
Key Question 2. Nonpharmacological noninvasive therapies | Massage | Massage: Adverse events | Low | Harms were not well reported in trials of massage, although no serious adverse events were reported; 2 trials reported soreness during or shortly after the treatment.
Key Question 2. Nonpharmacological noninvasive therapies | Spinal manipulation | Spinal manipulation, acute LBP: Pain and function | Low for function, insufficient for pain | Two trials (1 included in a systematic review) found spinal manipulation to be associated with better effects on function vs. sham manipulation (statistically significant in 1 trial); in 1 trial, effects on pain favored manipulation but were small and not statistically significant (mean difference, −0.50; 95% CI, −1.39 to 0.39).
Key Question 2. Nonpharmacological noninvasive therapies | Spinal manipulation | Spinal manipulation vs. sham manipulation, chronic LBP: Pain and function | Low for pain, insufficient for function | A systematic review found spinal manipulation to be associated with small, statistically nonsignificant effects vs. sham manipulation on pain at 1 month (3 trials; WMD, −3.24; 95% CI, −13.62 to 7.15 on a 0 to 100 scale; I^2^ = 53%); 1 trial reported similar results for function (SMD, −0.45; 95% CI, −0.97 to 0.06); 1 trial not included in the systematic review reported generally consistent results.
Key Question 2. Nonpharmacological noninvasive therapies | Spinal manipulation | Spinal manipulation vs. inert treatment, acute LBP: Pain and function | Low | A systematic review found no differences between spinal manipulation vs. inert treatment in pain relief at 1 week (3 trials; WMD, 0.14 on a 0 to 10 scale; 95% CI, −0.69 to 0.96; I^2^ = 27%), although 1 trial found spinal manipulation to be associated with better long term pain relief (mean difference, −1.20 at 3 months; 95% CI, 2.11 to −0.29); there were no differences in function at 1 week (2 trials; SMD, −0.08; 95% CI, −0.37 to 0.21; I^2^ = 0%) or at 3 months (1 trial; SMD, −0.28; 95% CI, −0.59 to 0.02).
Key Question 2. Nonpharmacological noninvasive therapies | Spinal manipulation | Spinal manipulation vs. inert treatment, chronic LBP | Low | One trial with low risk of bias found spinal manipulation to be associated with greater improvement in the “main complaint” vs. an inert treatment (mean difference, 0.9 on a 0 to 10 scale; 95% CI, 0.1 to 1.7); results from 3 trials with high risk of bias and 3 additional trials not included in the systematic review were somewhat inconsistent, although some trials reported effects that favored manipulation.
Key Question 2. Nonpharmacological noninvasive therapies | Spinal manipulation | Spinal manipulation vs. other active interventions, acute LBP: Pain and function | Moderate | A systematic review found no difference between spinal manipulation vs. other active interventions in pain relief at 1 week (3 trials; WMD, 0.06 on a 0 to 10 scale; 95% CI, −0.53 to 0.65; I^2^ = 0%), 1 month (3 trials; WMD, −0.15; 95% CI, −0.49 to 0.18; I^2^ = 0%), 3 to 6 months (2 trials; WMD, −0.20; 95% CI, −1.13 to 0.73; I^2^ = 81%), or 1 year (1 trial; mean difference, 0.40; 95% CI, −0.08 to 0.88). Findings were similar for function, with no differences observed at any timepoint. A subsequent trial of patients with acute or subacute LBP found that spinal manipulation was associated with moderate effects vs. usual care on pain and small effects on function at short-term followup, but effects were smaller and no longer statistically significant at 3 and 6 months
Key Question 2. Nonpharmacological noninvasive therapies | Spinal manipulation | Spinal manipulation vs. other interventions, chronic LBP: Pain and function | Moderate | A systematic review found spinal manipulation to be associated with better short-term pain relief vs. other active interventions at 1 month (10 comparisons from 6 trials; WMD, −2.76 on a 0 to 100 scale; 95% CI, −5.19 to −0.32; I^2^ = 27%) and 6 months (7 comparisons from 4 trials; WMD, −3.07; 95% CI, −5.42 to −0.71; I^2^ = 0%), although the magnitude of effects was below the small/slight threshold. There was no difference at 12 months (3 trials; WMD, −0.76; 95% CI, −3.19 to 1.66; I^2^ = 0%). Manipulation was also associated with greater improvement in function vs. other active interventions at 1 month (10 comparisons from 6 trials; SMD, −0.17; 95% CI, −0.29 to −0.06; I^2^ = 3%); effects were smaller and no longer statistically significant at 6 and 12 months. Three trials not included in the systematic reviews reported results consistent with these findings.
Key Question 2. Nonpharmacological noninvasive therapies | Spinal manipulation | Spinal manipulation plus exercise or advice vs. exercise or advice alone, acute LBP: Function | Low | Four trials in a systematic review found spinal manipulation plus either exercise or advice to be associated with greater improvement in function at 1 week (SMD, −0.41; 95% CI, −0.73 to −0.10; I^2^ = 18%) vs. exercise or advice alone, but there were no differences at 1 month (3 trials; SMD, −0.09; 95% CI, −0.39 to 0.21; I^2^ = 37%) or 3 months (2 trials; SMD, −0.22; 95% CI, −0.61 to 0.16; I^2^ = 41%).
Key Question 2. Nonpharmacological noninvasive therapies | Spinal manipulation | Spinal manipulation plus another active treatment, chronic LBP: Pain and function | Low | A systematic review found spinal manipulation plus another active treatment to be associated with greater pain relief at 1 month (3 trials; WMD, −5.88 on a 0 to 100 scale; 95% CI, −10.85 to −0.90; I^2^ = 0%), 3 months (2 trials; mean difference, −7.23; 95% CI, −11.72 to −2.74; I^2^ = 43%), and 12 months (2 trials; mean difference, −3.31; 95% CI, −6.60 to −0.02; I^2^ = 12%) vs. the other treatment alone. Combination therapy was also associated with better function at 1 month, (2 trials; SMD, −0.40; 95% CI, −0.73 to −0.07; I^2^ = 0%), 3 months (2 trials; SMD, −0.22; 95% CI, −0.38 to −0.06; I^2^ = 33%), and 12 months (2 trials; SMD, −0.21; 95% CI, −0.34 to −0.09; I^2^ = 0%). One trial not included in the systematic review reported results consistent with these findings.
Key Question 2. Nonpharmacological noninvasive therapies | Spinal manipulation | Spinal manipulation plus home exercise and advice, radicular LBP | Low | One good-quality trial found spinal manipulation plus home exercise and advice to be associated with greater improvement in leg and back pain at 12 weeks vs. home exercise and advice alone (mean differences about 1 point on a 0 to 10 scale), but effects were smaller (0.3 to 0.7 points) and no longer statistically significant at 52 weeks.
Key Question 2. Nonpharmacological noninvasive therapies | Spinal manipulation | Spinal manipulation: Adverse events | Low | Harms were not reported well in most trials of spinal manipulation. No serious adverse events were reported, and most adverse events were related to muscle soreness or transient increases in pain.
Key Question 2. Nonpharmacological noninvasive therapies | Ultrasound | Ultrasound vs. sham ultrasound, chronic LBP: Pain and function | Low for pain, insufficient for function | A systematic review found no difference between ultrasound vs. sham ultrasound in pain at the end of treatment (3 trials; mean difference, −7.12 on 0 to 100 scale; 95% CI, −18.0 to 3.75; I^2^ = 77%), and 2 trials found no effects on pain 4 weeks after the end of treatment. Evidence from 5 trials was too inconsistent to determine effects on function, although a larger good-quality trial found no effect on the RDQ.
Key Question 2. Nonpharmacological noninvasive therapies | Ultrasound | Ultrasound vs. no ultrasound, chronic LBP: Pain and function | Low | A systematic review found no differences between ultrasound vs. no ultrasound in pain (2 trials; mean difference, −2.16; 95% CI, −4.66 to 0.34; I^2^ = 0%) or back-specific function (2 trials; mean difference, −0.41; 95% CI, −3.14 to 2.32), but estimates were imprecise.
Key Question 2. Nonpharmacological noninvasive therapies | Ultrasound | Ultrasound plus exercise vs. exercise, chronic LBP: Pain and function | Insufficient | Evidence from 3 trials was insufficient to determine effects of ultrasound plus exercise vs. exercise alone on pain or function due to imprecision and methodological shortcomings.
Key Question 2. Nonpharmacological noninvasive therapies | Ultrasound | Ultrasound plus exercise vs. exercise, radicular LBP: Back pain, leg pain | Insufficient | A small trial found no differences between ultrasound plus exercise vs. sham ultrasound plus exercise in back pain, leg pain, or the ODI after 3 weeks of therapy.
Key Question 2. Nonpharmacological noninvasive therapies | Ultrasound | Ultrasound vs. other interventions | Insufficient | There was insufficient evidence from 3 small trials with methodological shortcomings to determine effects of ultrasound vs. other interventions.
Key Question 2. Nonpharmacological noninvasive therapies | Ultrasound | Ultrasound vs. other interventions, radiculopathy | Insufficient | There was insufficient evidence from 2 small trials with methodological shortcomings to determine effects of ultrasound vs. other interventions.
Key Question 2. Nonpharmacological noninvasive therapies | Ultrasound | Ultrasound, acute nonradicular LBP | Insufficient | No study evaluated the effectiveness of ultrasound for acute nonradicular LBP.
Key Question 2. Nonpharmacological noninvasive therapies | Ultrasound | Ultrasound vs. sham ultrasound: Adverse events | Low | One trial found no differences between ultrasound vs. sham ultrasound in risk of any adverse event (6.0% vs. 5.9%; RR, 1.03; 95% CI, 0.49 to 2.13) or serious adverse events (1.3% vs. 2.7%; RR, 0.48; 95% CI, 0.12 to 1.88).
Key Question 2. Nonpharmacological noninvasive therapies | Transcutaneous electrical nerve stimulation | TENS vs. sham TENS, acute or subacute LBP: Pain and function | Insufficient | Evidence from single trials with methodological shortcomings was too limited to permit reliable conclusions regarding effectiveness.
Key Question 2. Nonpharmacological noninvasive therapies | Transcutaneous electrical nerve stimulation | TENS vs. sham TENS, chronic LBP: Pain and function | Low | A systematic review found no differences between TENS vs. sham TENS in pain intensity (4 trials; WMD, −4.47 on a 0 to 100 scale; 95% CI, −12.84 to 3.89) or function (2 trials; WMD, −1.36 on a 0 to 100 scale; 95% CI, −4.38 to 1.66) at short-term followup; most trials found no effect on pain or function at the end of a course of treatment.
Key Question 2. Nonpharmacological noninvasive therapies | Transcutaneous electrical nerve stimulation | TENS vs. acupuncture, chronic LBP: Pain | Low | A systematic review found no differences between TENS vs. acupuncture for short- (4 trials; SMD, 0.15; 95% CI, −0.33 to 0.63) or long-term pain (2 trials; SMD, 0.32; 95% CI, −0.33 to 0.96). Evidence for TENS vs. other interventions was too limited to permit reliable conclusions.
Key Question 2. Nonpharmacological noninvasive therapies | Transcutaneous electrical nerve stimulation | TENS: Adverse events | Low | Evidence on harms associated with TENS was limited but suggests an increased risk of skin-site reactions without an increased risk of serious adverse events.
Key Question 2. Nonpharmacological noninvasive therapies | Electrical muscle stimulation | EMS plus exercise vs. exercise, EMS vs. other interventions, acute or chronic LBP: Pain and function | Insufficient | There was insufficient evidence from 5 RCTs to determine effects of EMS plus exercise vs. exercise alone or vs. other interventions due to methodological limitations and imprecision.
Key Question 2. Nonpharmacological noninvasive therapies | Electrical muscle stimulation | EMS: Adverse events | Insufficient | There was insufficient evidence to determine harms of EMS.
Key Question 2. Nonpharmacological noninvasive therapies | Percutaneous electrical nerve stimulation | PENS vs. sham PENS, PENS plus exercise vs. exercise, PENS vs. other interventions, chronic LBP (with or without radiculopathy) | Insufficient | There was insufficient evidence from 7 trials to determine effects of PENS vs. sham, PENS plus exercise vs. exercise alone, or PENS vs. other interventions due to methodological limitations, inconsistency, and imprecision.
Key Question 2. Nonpharmacological noninvasive therapies | Percutaneous electrical nerve stimulation | PENS: Adverse events | Insufficient | Harms were poorly reported in trials of PENS.
Key Question 2. Nonpharmacological noninvasive therapies | Interferential therapy | IFT vs. other interventions, IFT plus another intervention vs. the other intervention, subacute to chronic LBP: Pain and function | Insufficient | There was insufficient evidence from 4 trials to determine effects of IFT vs. other interventions or IFT plus another intervention vs. the other intervention alone, due to methodological limitations and imprecision.
Key Question 2. Nonpharmacological noninvasive therapies | Interferential therapy | IFT: Adverse events | Insufficient | No study evaluated harms of IFT.
Key Question 2. Nonpharmacological noninvasive therapies | Superficial heat or cold | Heat wrap vs. placebo, acute or subacute LBP: Pain and function | Moderate | A systematic review found a heat wrap to be more effective than placebo for pain relief at 5 days (2 trials; mean difference, 1.06 on a 0 to 5 scale; 95% CI, 0.68 to 1.45) and disability at 4 days (mean difference, −2.10 on the RDQ; 95% CI, −3.19 to −1.01). Two subsequent trials also found a heat wrap to be associated with decreased pain intensity at 3 to 4 days (differences, 16 to 20 points on a 0 to 100 point VAS) or increased pain relief at 8 hours (difference, ~1.5 points on a 0 to 5 scale). Another trial found a heat wrap during emergency transport to be associated with substantially lower pain intensity vs, an unheated blanket on arrival to the hospital.
Key Question 2. Nonpharmacological noninvasive therapies | Superficial heat or cold | Heat plus exercise vs. exercise alone, acute LBP: Pain and function | Low | One higher quality trial found heat plus exercise to be associated with greater pain relief (mean difference, 1.40 on 0 to 10 scale; 95% CI, 0.69 to 2.11) and higher function (mean RDQ difference, −3.20; 95% CI, −5.42 to −0) vs. exercise without heat at day 7.
Key Question 2. Nonpharmacological noninvasive therapies | Superficial heat or cold | Heat plus NSAID vs. NSAID alone, acute LBP: Pain | Insufficient | One fair-quality trial found heat plus an NSAID to be associated with better pain scores versus an NSAID without heat at day 15 based on the McGill Pain Questionnaire (scoring methods unclear).
Key Question 2. Nonpharmacological noninvasive therapies | Superficial heat or cold | Heat vs. simple analgesics, acute or subacute LBP: Pain and function | Low | A systematic review included 1 trial that found heat to be more effective for pain relief than acetaminophen (mean difference, 0.90 on a 0 to 10 scale; 95% CI, 0.50 to 1.30) or ibuprofen (0.65; 95% CI, 0.25 to 1.05) after 1 to 2 days of treatment; the heat wrap was also associated with greater improvement on the RDQ (mean differences, 2.00 on a 0 to 24 scale; 95% CI, 0.86 to 3.14, and 2.20; 95% CI, 1.11 to 3.29, respectively).
Key Question 2. Nonpharmacological noninvasive therapies | Superficial heat or cold | Heat vs. exercise, acute LBP: Pain and function | Low | A systematic review included 1 trial that found no clear differences between heat vs. exercise in pain relief or function.
Key Question 2. Nonpharmacological noninvasive therapies | Superficial heat or cold | Superficial cold vs. placebo | Insufficient | No study compared superficial cold vs. placebo or no cold treatment.
Key Question 2. Nonpharmacological noninvasive therapies | Superficial heat or cold | Cold plus naproxen vs. naproxen alone, acute LBP: Pain | Insufficient | One small trial with methodological shortcomings found cold plus naproxen to be associated with better pain scores vs. naproxen alone based on the McGill Pain Questionnaire (scoring methods unclear)
Key Question 2. Nonpharmacological noninvasive therapies | Superficial heat or cold | Heat vs. cold | Insufficient | There was insufficient evidence from 3 trials to determine effects of heat vs. cold due to methodological limitations and imprecision.
Key Question 2. Nonpharmacological noninvasive therapies | Superficial heat or cold | Heat vs. no heat or placebo: Adverse events, flushing | Low | Heat was not associated with increased risk of skin flushing vs. no heat or placebo in 2 trials; no serious adverse events were reported with use of heat.
Key Question 2. Nonpharmacological noninvasive therapies | Low- level laser therapy | LLLT vs. sham laser, acute LBP | Insufficient | There was insufficient evidence from 1 trial to determine effectiveness of LLLT vs. sham laser due to serious methodological shortcomings and imprecision.
Key Question 2. Nonpharmacological noninvasive therapies | Low- level laser therapy | LLLT vs. sham laser, chronic LBP: Pain and function | Low | Three of 4 trials found LLLT to be more effective than sham laser for pain, although methods for assessing pain and duration of followup varied; 2 trials found LLLT to be more effective than sham laser for function, with small magnitude of effect.
Key Question 2. Nonpharmacological noninvasive therapies | Low- level laser therapy | LLLT plus NSAID vs. sham plus NSAID, acute or subacute LBP: Pain and function | Low | One trial found LLLT plus an NSAID to be associated with lower pain intensity vs. sham laser plus an NSAID or the NSAID alone (mean differences, 9 to 14 points on a 0 to 100 VAS); effects on the ODI also favored combination treatment but were smaller (differences <6 points).
Key Question 2. Nonpharmacological noninvasive therapies | Low- level laser therapy | LLLT plus another intervention vs. the other intervention alone, chronic LBP: Pain and function | Insufficient | There was insufficient evidence from 3 trials to determine effects of LLLT plus exercise vs. sham laser plus exercise alone due to methodological shortcomings and inconsistency.
Key Question 2. Nonpharmacological noninvasive therapies | Low- level laser therapy | LLLT vs. another intervention: Pain and function | Insufficient | There was insufficient evidence to determine effects of LLLT vs. another intervention due to methodological shortcomings and imprecision.
Key Question 2. Nonpharmacological noninvasive therapies | Low- level laser therapy | LLLT, differing wavelengths or doses | Insufficient | There was insufficient evidence to determine effects of different wavelengths or doses of LLLT due to methodological limitations and imprecision.
Key Question 2. Nonpharmacological noninvasive therapies | Low- level laser therapy | LLLT: Adverse events | Low | Harms were not well reported in trials of LLLT, but no serious adverse events and no harms were reported.
Key Question 2. Nonpharmacological noninvasive therapies | Short-wave diathermy | Short-wave diathermy vs. sham diathermy, mixed-duration LBP: Effectiveness and adverse events | Insufficient | There was insufficient evidence from 5 RCTs to determine effects of short-wave diathermy vs. sham diathermy due to methodological limitations and imprecision.
Key Question 2. Nonpharmacological noninvasive therapies | Short-wave diathermy | Short-wave diathermy: Adverse events | Insufficient | No study evaluated harms of short-wave diathermy.
Key Question 2. Nonpharmacological noninvasive therapies | Lumbar supports | Lumbar supports vs. no lumbar supports or an inactive treatment, acute or subacute LBP: Pain and function | Insufficient | There was insufficient evidence from 5 trials to determine effects of lumbar supports vs. no lumbar supports or an inactive treatment due to methodological shortcomings and inconsistent results.
Key Question 2. Nonpharmacological noninvasive therapies | Lumbar supports | Lumbar supports vs. no lumbar supports, chronic LBP | Insufficient | There was insufficient evidence from 2 trials to determine effects of lumbar supports vs. no lumbar supports due to methodological shortcomings and inconsistent results.
Key Question 2. Nonpharmacological noninvasive therapies | Lumbar supports | Lumbar supports vs. no lumbar supports, mixed-duration LBP: Pain and function | Low | One trial found an inextensible, but not an extensible, lumbar supports to be associated with greater improvement in function vs. no lumbar support, but effects were small. There was no clear effect on function.
Key Question 2. Nonpharmacological noninvasive therapies | Lumbar supports | Lumbar support plus education vs. education, acute or subacute LBP: Pain and function | Low | One trial found no differences between a lumbar support plus an education program vs. an education program alone in pain or function after 1 year.
Key Question 2. Nonpharmacological noninvasive therapies | Lumbar supports | Lumbar support plus exercise vs. exercise alone, chronic LBP: Pain and function | Low | One trial found no difference between a lumbar support plus exercise (muscle strengthening) vs. exercise alone in short-term (8 week) or long-term (6 month) pain or function.
Key Question 2. Nonpharmacological noninvasive therapies | Lumbar supports | Lumbar support vs. other active treatments: Pain and function | Low | Three trials found no clear differences between lumbar supports vs. other active treatments in pain or function.
Key Question 2. Nonpharmacological noninvasive therapies | Lumbar supports | Lumbar supports vs. lumbar supports: Pain and function | Insufficient | There was insufficient evidence from 2 trials to determine comparative effects of different types of lumbar supports for chronic LBP or back pain of mixed duration due to heterogeneous comparisons, methodological shortcomings, and imprecision.
Key Question 2. Nonpharmacological noninvasive therapies | Lumbar supports | Lumbar supports: Adverse events | Low | Trials reported no harms associated with use of lumbar supports.
Key Question 2. Nonpharmacological noninvasive therapies | Traction | Traction vs. placebo, sham, or no treatment, LBP with or without radicular symptoms: Pain, function, other outcomes | Insufficient | A systematic review included 13 trials that found no clear differences and inconsistent effects of traction vs. placebo, sham, or no treatment in pain, function, or other outcomes, although 2 trials reported favorable effects on pain in patients with radicular back pain.
Key Question 2. Nonpharmacological noninvasive therapies | Traction | Traction vs. physiotherapy, LBP with or without radicular symptoms | Low | A systematic review included 5 trials that found no clear differences between traction plus physiotherapy vs. physiotherapy alone.
Key Question 2. Nonpharmacological noninvasive therapies | Traction | Traction vs. other interventions, LBP with or without radicular symptoms: Pain and function | Low | A systematic review included 15 trials of traction vs. other interventions that found no clear between traction vs. other active interventions in pain or function.
Key Question 2. Nonpharmacological noninvasive therapies | Traction | Traction vs. traction | Low | A systematic review included 5 trials that found no clear differences among different types of traction.
Key Question 2. Nonpharmacological noninvasive therapies | Traction | Traction: Adverse events | Low | Eleven trials of traction in a systematic review reported no adverse events or no difference in risk of adverse events vs. placebo or other interventions. Three subsequent trials reported findings consistent with the systematic review.
Key Question 2. Nonpharmacological noninvasive therapies | Taping | Kinesio Taping^®^ vs. sham taping, chronic LBP: Pain and function | Insufficient for pain, low for function | Two trials found no differences between Kinesio Taping vs. sham taping in back-specific function after 5 to 12 weeks; effects on pain were inconsistent.
Key Question 2. Nonpharmacological noninvasive therapies | Taping | Functional Fascial Taping^®^ plus exercise vs. sham taping plus exercise, chronic LBP: Pain and function | Insufficient | There was insufficient evidence from 1 trial to determine effects of Functional Fascial Taping plus exercise vs. sham taping plus exercise due to methodological limitations and imprecision.
Key Question 2. Nonpharmacological noninvasive therapies | Taping | Kinesio Taping vs. exercise therapy, chronic LBP: Pain and function | Low | Two trials found no differences between Kinesio Taping vs. exercise therapy in pain or function.
Key Question 2. Nonpharmacological noninvasive therapies | Taping | Taping: Adverse events | Insufficient | No trial of taping reported harms.

New evidence affected conclusions for several classes of medications. For acetaminophen, the prior review concluded that acetaminophen was effective for acute low back pain, primarily based on indirect evidence from trials of acetaminophen for other conditions and trials of acetaminophen versus other analgesics. However, a recent, well-conducted trial—the first placebo-controlled trial in patients with acute low back pain—found acetaminophen to be no more than effective than placebo (strength of evidence [SOE]: low).43 For antidepressant drugs, no studies in the prior review evaluated drugs in the serotonin norepinephrine reuptake inhibitor class. Evidence from several trials indicates that duloxetine is more effective than placebo for pain and function in patients with chronic low back pain (SOE: moderate).152-154 However, effects were small (less than 1 point on a 0 to 10 scale) and all trials were funded by the manufacturer of duloxetine and led by the same researcher. For antiseizure medications, new evidence is available on pregabalin for radicular low back pain, but the studies had methodological shortcomings and were too inconsistent to reliably estimate effects (SOE: insufficient).160, 163 The prior review found no studies on the effects of benzodiazepines for radiculopathy; one recent trial found that benzodiazepines were no more effective than placebo in for this condition (SOE: low).135 The trial also found that for some outcomes, such as return to work, benzodiazepines were associated with worse outcomes versus placebo.

Main conclusions regarding the benefits and harms of pharmacological therapies for low back pain were otherwise relatively unchanged from the prior review. One area in which conclusions did change was related to effectiveness of tricyclic antidepressants. In our prior review, tricyclic antidepressants were found to be associated with small beneficial effects for chronic low back pain. However, evidence reviewed for this report suggests that tricyclic antidepressants are not effective versus placebo (4 trials; SMD −0.10, 95% CI −0.51 to 0.31; I^2^=32%) (SOE: moderate).139 As noted above, duloxetine, a serotonin norepinephrine reuptake inhibitor that is not associated with the anticholinergic and cardiac side effects of tricyclics, is now available as a potential alternative antidepressant. Skeletal muscle relaxants appear to be effective for short-term pain relief in patients with acute low back pain, but are also associated with an increased risk of central nervous system adverse events (in particular, sedation) (SOE: moderate). Systemic corticosteroids do not appear to be effective versus placebo for either radicular or nonradicular low back pain (SOE: moderate) and evidence on the effectiveness of benzodiazepines versus placebo for nonradicular low back pain remains sparse (SOE: insufficient).34

Evidence on the effectiveness of opioids for low back pain remains limited to short-term trials showing modest effects versus placebo on short-term pain and function69 (SOE: moderate). Almost all trials of opioids enrolled patients with chronic low back pain, and no trial focused on patients with radicular symptoms. There remain no clear differences among different long-acting opioids or among long- versus short-acting opioids. Findings regarding the increased risk of opioids versus placebo for harms such as constipation, nausea, sedation, and dry mouth are also unchanged. Most trials of opioids used an enriched enrollment and withdrawal design; evidence from studies of chronic pain in general (not restricted to low back pain) suggest that estimates of harms are larger in trials that did not use such a design.92 Trials of opioids for low back pain were not designed to assess risk of serious adverse events such as overdose, abuse or addiction, or accidental injuries, due to their relatively small samples and short duration of followup. In addition, trials of opioids typically excluded patients with risk factors for overdose, abuse, or addiction. Observational studies have shown an association between use of opioids for chronic pain and serious harms such as overdose that appears to be dose-dependent.599 However, such studies did not meet inclusion criteria for this report because they were not restricted to patients with low back pain.

Relatively few studies directly compared the effectiveness of different medications for low back pain, or the effectiveness of a combination of medications versus one of the component medications of the combination alone. We found no clear differences between opioids versus nonsteroidal anti-inflammatory drugs (NSAIDs) in pain relief or function, and no clear differences between benzodiazepines versus skeletal muscle relaxants. As described above, there were no clear differences between acetaminophen versus NSAIDs in patients with chronic low back pain.

Serious harms were generally not observed in trials of nonopioid medications, though harms were generally not reported well. Like trials of opioids, trials of nonopioid medications were not designed to assess risk of serious, uncommon harms (e.g., liver toxicity with acetaminophen, bleeding with NSAIDs, fracture or infection with corticosteroids, or abuse or addiction with benzodiazepines).

The current report addresses several nonpharmacological therapies not addressed in the prior APS/ACP review. Evidence on taping (using techniques to increase skin tension) did not clearly show beneficial effects versus sham taping comparisons, though findings were limited by methodological shortcomings and inconsistency (SOE: insufficient to low). There was insufficient evidence to determine the effects of electrical muscle stimulation, due to methodological shortcomings in the trials and imprecision (SOE: insufficient). Two trials found that tai chi was more effective versus wait list control for pain intensity and function285 (SOE: low); effects appeared similar to those observed for other types of exercise and related interventions.

As in the APS/ACP review, we found little evidence to support the use of most passive physical modalities for low back pain. An exception was superficial heat, which was found to be more effective than a nonheated control for acute or subacute low back pain (SOE: moderate). There remains insufficient evidence to determine effects of superficial cold. There also remains insufficient evidence to determine the effectiveness of percutaneous electrical nerve stimulation, interferential therapy, short-wave diathermy, traction and lumbar supports versus sham or no treatment. Although evidence on effectiveness of ultrasound and transcutaneous electrical nerve stimulation (TENS) was previously classified as insufficient, additional evidence now supports the findings that ultrasound is not effective versus sham ultrasound497 and that TENS is not effective versus sham TENS,512 though the strength of evidence remains low due to methodological limitations in the trials and imprecision. Based on three trials,550, 552, 553 low-level laser therapy was more effective than sham laser for pain, though methods for assessing pain and duration of followup varied; there was insufficient evidence from one trial to determine effects on function. Evidence to compare effects of one physical modality versus another, or a physical modality versus another active intervention, was generally too limited to reach reliable conclusions.

As in the APS/ACP review, we found evidence that psychological therapies (progressive relaxation, electromyography (EMG) biofeedback, operant therapy, combined psychological therapy [e.g., cognitive-behavioral therapy]) are associated with lower pain intensity (effects small to moderate) versus wait list control; effects of function were observed for progressive relaxation and combined psychological therapy only (SOE: low).313 Multidisciplinary rehabilitation (consisting at a minimum of exercise therapy plus psychological therapy, with some coordination) was associated with moderately lower pain intensity versus usual care, with smaller effects on function and no clear effect on return to work (SOE: moderate).348 Psychological therapies and multidisciplinary rehabilitation were primarily evaluated for chronic low back pain, with insufficient evidence to determine effects in patients with acute low back pain or in those with radicular symptoms. Unlike the prior review, a stratified analysis reported in a systematic review found no association between the intensity of multidisciplinary rehabilitation and estimates of effectiveness,313 though head-to-head comparisons of different intensities of multidisciplinary rehabilitation are not available. In head-to-head comparisons, there were no clear differences between psychological therapies versus exercise therapy, though multidisciplinary rehabilitation was moderately more effective than physical therapy not administered as part of a multidisciplinary program.

Our findings regarding the effectiveness of massage, acupuncture, and manipulation were generally consistent with the APS/ACP review in showing some beneficial, primarily short-term effects. These interventions were primarily evaluated for chronic low back pain, with few trials of patients with acute low back pain or specifically with radicular symptoms. Evidence was generally stronger for acupuncture364, 365 and spinal manipulation437, 438 than for massage,405 which was evaluated in fewer trials, though the strength of evidence varied depending on the specific comparison evaluated (no SOE was rated above moderate). For all of these therapies, the evidence was characterized by marked heterogeneity in the interventions evaluated as well as in the intensity and number of sessions. Although some evidence suggested that massage is more effective versus other interventions considered active, it was not possible to draw strong conclusions due to methodological limitations and imprecision.405 Although acupuncture was more effective than sham acupuncture for chronic low back pain,365 sham acupuncture techniques varied among trials (superficial needling at acupuncture points, superficial needling at nonacupuncture points, nonpenetrating needles or pressure at acupuncture points) and there was inconsistency, with some trials showing no differences between acupuncture versus sham and effects were primarily observed immediately after treatment, with limited evidence of no effects at longer-term followup. Spinal manipulation was no more effective than sham manipulation for chronic low back pain, but manipulation was as effective as other interventions thought to be effective.438 Therefore, there remains some uncertainty regarding the specific effects of these interventions, versus nonspecific effects related to needling, mobilization or manipulation, or other aspects of administering these treatments (e.g., attentional or placebo effects). Head-to-head trials that directly compared different massage, acupuncture, or spinal manipulation techniques generally found no clear differences.

Findings regarding the effectiveness of exercise therapies and related interventions were also consistent with the APS/ACP review. Most trials evaluated patients with chronic nonradicular low back pain. For yoga, newer trials strengthen conclusions regarding effectiveness, particularly for yoga versus educational interventions (SOE: moderate). Evidence on motor control exercises, which were not addressed in the APS/ACP review, was generally consistent with evidence for other types of exercise in showing small to moderate effects (SOE: low). Head-to-head trials of exercise programs generally found no clear differences in estimates of effectiveness.

Harms were not well-reported in trials of nonpharmacological therapies, though serious adverse events appear rare. For physical modalities, harms when reported were mostly related to superficial effects at the application site. Severe neurological complications were not reported in trials of lumbar spinal manipulation and serious infections, bleeding, or other complications were not reported in trials of acupuncture.

## Findings in Relationship to What Is Already Known

Our findings are generally consistent with prior systematic reviews on noninvasive treatments for low back pain, in part because our report builds upon a prior review and used previously published, high-quality systematic reviews to inform its findings. However, our findings were also generally consistent with other recent systematic reviews that were not used in this report that found NSAIDs and opioids associated with small to moderate effects versus placebo for chronic low back pain, and tricyclic antidepressants associated with small effects that were not statistically significant.600, 601 Like other reviews, we only found evidence supporting short-term benefits of opioids. Although another review found no differences between opioids versus placebo for low back pain, searches were conducted through 2005 and its findings were based on only four trials, with a pooled estimate that slightly favored opioids (SMD −0.18, 95% CI −0.49 to 0.11).602 As in other reviews, we found no randomized trials to determine long-term effectiveness of opioids for low back pain. In a recent review that we conducted on opioids for chronic pain in general, we also found no cohort studies to determine the long-term effectiveness of opioids versus no opioid therapy.603 In that review, we found insufficient evidence from randomized trials to determine the risk of serious harms associated with opioids, due to small samples, inadequate length of followup, poorly standardized methods for assessing harms, and suboptimal harms reporting. In addition, trials typically excluded patients at higher risk for abuse or overdose, though evidence604, 605 indicates that such patients are more likely to be prescribed opioids in clinical practice than people without risk factors.600, 606

Our finding that acetaminophen is not effective for acute low back pain is based on a recent, well-conducted randomized controlled trial (RCT)43 and differs from our prior review, which concluded that there was good evidence of moderate effects. However, the prior conclusion was based on indirect evidence of acetaminophen for other pain conditions and effects of acetaminophen versus NSAIDs, which showed few differences. Another systematic review, noting the absence of placebo-controlled trials at the time and imprecision and methodological shortcomings in the available studies, rated the same evidence as insufficient.607 Like our review, a recent systematic review found that acetaminophen was ineffective for low back pain, primarily based on the results of the new trial.608

Our prior report and other previous systematic reviews137, 138 found tricyclic antidepressants associated with small beneficial effects for low back pain. However, the evidence reviewed for this report suggests that they are not effective versus placebo for pain relief (4 trials; SMD −0.10, 95% CI −0.51 to 0.31; I^2^=32%) or function.139 One potential reason for the discrepancy between this finding and prior reviews are that some of the prior reviews did not conduct a meta-analysis.136, 138 One positive review137 did base findings on a meta-analysis. However, the study in the meta-analysis that reported the largest effect in favor of antidepressants did not report being randomized,609 it did not include relevant studies that were in the more current review,141, 146, 149 and it did not report methods for data imputation for two trials included in the meta-analysis.140, 148

Our findings regarding the small to moderate effectiveness of the antidepressant duloxetine are consistent with its recent approval by the US Food and Drug Administration for chronic musculoskeletal pain, including chronic low back pain.610 Our conclusions were based on trials of duloxetine versus placebo. Although a systematic review found no differences between duloxetine versus other oral medications, its findings were based on a network analysis based on indirect comparisons.611

For nonpharmacological treatments, our findings are also generally consistent with other systematic reviews. Like other reviews, we found some evidence to support use of complementary and alternative medicine therapies such as acupuncture, spinal manipulation, and massage.600, 612-616 Although acupuncture was no more effective than sham acupuncture in some trials, other reviews have also found that the overall evidence (including pooled estimates) suggest beneficial effects on pain.364, 365 As in prior reviews, we found no clear evidence to support one specific type of massage, manipulation, or acupuncture over another.362, 404, 426, 617

Findings regarding the effectiveness of exercise are similar to our prior review and other reviews.618-620 Our findings are also consistent with more specific reviews that focused on specific types of exercise such as aquatic exercise,621 sling exercise,622 walking,623 stability exercises,624 and modifying patterns of movement.625 Additional evidence published since our prior review strengthens conclusions that yoga is effective for low back pain,626, 627 a finding consistent with other recent systematic reviews, and newer evidence supports the effectiveness of motor control exercises. Evidence on tai chi was previously unavailable, but recent randomized trials support its effectiveness. As in our prior review, evidence does not clearly demonstrate that one type of exercise therapy is superior to another. This is consistent with other systematic reviews that have evaluated specific exercise therapy comparisons (e.g., McKenzie versus other exercise methods).183

Our findings that psychological therapies and multidisciplinary rehabilitation were both effective are consistent with our prior review and other reviews.628 Other reviews that focused on related interventions such as functional restoration or cognitive-behaviorally based physical therapy (in which the literature overlaps with that on multidisciplinary rehabilitation) have also reached positive conclusions.606, 629, 630 Although there was insufficient evidence to determine which patients are most likely to benefit from psychological therapies and multidisciplinary rehabilitation, a recent randomized trial631 found that a stratified approach in which patients are assessed for risk factors for chronicity, and higher-risk patients receive more intensive cognitive-behavioral based physical therapy, is more effective than usual care without a stratified approach, suggesting that these therapies may be most effective in higher-risk people. Unlike our prior report, which found that higher-intensity multidisciplinary rehabilitation appeared more effective than lower-intensity programs, a stratified analysis based on currently available evidence348 indicated no clear difference in effects.

Like our prior review, we found that for most physical modalities, evidence was too weak to determine effectiveness. Although we previously found insufficient evidence to conclude that ultrasound and TENS are not effective, albeit with low strength of evidence. A recent assessment of TENS came to a similar conclusion.632

As in other reviews, we found that evidence the effectiveness of therapies for radicular low back pain was quite limited.435, 633 Like other reviews, including our prior report, we found that systematic corticosteroids are not effective for radicular low back pain.633, 634 Although duloxetine and other serotonin norepinephrine reuptake inhibitors and antiseizure medications such as gabapentin and pregabalin are increasingly being prescribed for low back pain, particularly when associated with radicular symptoms, evidence on the effectiveness of nonduloxetine serotonin norepinephrine reuptake inhibitors is not available and results of trials of pregabalin and gabapentin have been inconsistent or have not shown clear effects. Although a network meta-analysis has been performed on various treatments for radicular low back pain, the most commonly evaluated treatments were surgical and interventional, findings for noninvasive therapies were primarily based on indirect comparisons, and many estimates were imprecise.635

## Applicability

A number of issues could impact the applicability of our findings. Some studies did not specifically enroll patients with acute, subacute, or chronic low back pain, but rather enrolled mixed populations or did not clearly describe the duration of symptoms, which could make it difficult to apply findings if benefits differ according to duration of symptoms. Relatively few studies enrolled patients specifically with radicular symptoms, and many studies did not specifically describe whether patients with radicular symptoms were excluded. Therefore, the degree to which it is possible to extrapolate evidence from studies of patients with primarily nonradicular symptoms to patients with radicular symptoms is uncertain. In addition, studies that focused on radicular pain evaluated clinically diverse populations. Some studies required imaging findings of disc herniation (typically involving younger individuals) or spinal stenosis (typically affecting older individuals), while others did not require imaging confirmation of radicular symptoms. Among studies of patients with nonradicular symptoms, most studies did not attempt to evaluate whether effectiveness varied in subgroups of patients defined by clinical, demographic, imaging, or other characteristics. It is not possible to determine whether effectiveness varies among groups with nonradicular pain based on these factors. For example, most trials of antidepressants excluded patients with depression or only included a small minority of such patients,139 such that it is unclear whether antidepressants might have additional effects on mood in patients with low back pain and depression. Across interventions, few studies enrolled any or many older adults. Although trials of motor control exercise (MCE) generally selected patients on the basis of tests showing deficits in motor control, specific testing methods and criteria for inclusion varied, and it is unclear whether effects of MCE vary according to findings on motor control tests.186

For nonpharmacological treatments, the applicability of our findings is affected by the variability among trials in the interventions and comparators evaluated. For example, trials of acupuncture varied in the sites in which needles were applied, the length of acupuncture sessions, the number of sessions, and the time period over which the sessions were performed.364, 365 In trials that evaluated “usual care” comparators, the components of usual care were often not well described or standardized, making it difficult to apply findings to clinical practice. Other factors that could impact the applicability of our findings regarding nonpharmacological interventions includes differences related to the setting in which the intervention was performed (e.g., United States versus another country, specialist versus primary care setting) or due to the training or skill of the person performing the intervention. For acupuncture, for example, some evidence suggests that patient expectations have an important influence on the effectiveness of treatment,636, 637 such that results from countries in which acupuncture is widely practiced may not be applicable to settings in which it is considered an alternative practice. Another factor that could impact the effectiveness of interventions is the use of cointerventions, which varied across trials and was frequently not reported well. We separately analyzed comparisons that specifically involved the use of one intervention plus another intervention versus the other intervention alone. For example, spinal manipulation plus another intervention was more effective than the other intervention alone, suggesting potential additive effects.

To help interpret the results of the trials, we categorized the magnitude of effects for pain and function using the system in the APS/ACP review. Based on these categories, beneficial effects when present were in the small or moderate range. However, effects that we classified as small (e.g., 5-10 points on a 0 to 100 scale for pain or function) are below some proposed thresholds for minimum clinically important differences (e.g., 15 points on a 0 to 100 VAS for pain, 2 points on a 0 to 10 NRS for pain or function, 5 points on the RDQ, and 10 points on the ODI; or a 30% change from baseline).28 Nonetheless, our classification system provides some objective bench marks for assessing magnitude of effects, including the smaller effects typically observed in low back pain trials. We also evaluated the proportion of patients who experienced a clinically important improvement in pain or function (e.g., 50% improvement in pain or on the RDQ). However, many studies did not report such dichotomous outcomes, and among those that did, definitions for clinically important improvements varied. A factor that complicates interpretation of findings is that the magnitude of effects might vary depending on the baseline severity, with some evidence suggesting that treatment may be more effective in people with higher baseline symptom severity.638 Also, the clinical relevance of the same absolute improvement in an outcome measure might differ in individual patients depending on the baseline score (e.g., a 1 point change on a 0- to 10-point NRS for pain might differ for someone with a baseline pain score of 4 versus 9). Most trials enrolled patients with pain symptoms of at least moderate intensity (e.g., >5 on a 0- to 10-point NRS for pain). When present, most beneficial effects were observed at shorter-term (e.g., <3 months) followup, with outcomes often assessed only through the end of the active treatment period, such that it was difficult to determine whether there were sustained benefits. When evidence on longer-term followup was available, effects were typically attenuated or no longer observed. Understanding long-term outcomes is particularly critical for chronic low back pain, given the persistent nature of symptoms.

## Implications for Clinical and Policy Decisionmaking

Our findings have implications for clinical and policy decisionmaking. A number of pharmacological and nonpharmacological therapies are supported by some evidence of effectiveness in patients with acute (Tables 31, 32, 33, and 34) or chronic low back pain (Tables 35, 36, 37, and 38). Although clinical practice guidelines recommend acetaminophen as a first-line pharmacological therapy for acute and chronic low back pain,14, 639 new evidence43 that acetaminophen is ineffective for acute low back pain call into question its appropriateness as a recommended therapy, though findings are based on a single trial and other factors such as low cost, favorable side-effect profile, and effectiveness for other acute pain conditions could also impact decisions regarding its use.640 Although tricyclic antidepressants have long been recommended as a secondary treatment option for chronic low back pain, duloxetine has specifically been approved by the US Food and Drug Administration for this condition and appears to be more effective than tricyclic antidepressants as well as associated with a more favorable safety profile, which could impact the selection of drugs within the antidepressant class.

Table 31 Pharmacological therapies versus placebo for acute low back pain

Drug | Pain: Magnitude of Effect | Pain: Evidence | Pain: SOE | Function: Magnitude of Effect | Function: Evidence | Function: SOE
Acetaminophen | No effect | 1 RCT | Low | No effect | 1 RCT | Low
NSAIDs | Small (pain intensity); no effect (pain relief) | 1 SR (4 RCTs) | Moderate | Small | 2 RCTs | Low
Opioids (buprenorphine patch) | Small | 2 RCTs | Low | No evidence | -- | --
Skeletal muscle relaxants | Pain relief: RR, 1.72 (95% CI 1.32 to 2.22) at 5–7 days | 1 SR (3 RCTs) + 1 RCT | Moderate | No evidence | -- | --
Benzodiazepines | Unable to estimate | 2 RCTs | Insufficient | Unable to estimate | 2 RCTs | Insufficient
Antiseizure medications | No evidence | -- | -- | No evidence | -- | --
Systemic corticosteroids | No effect | 2 RCTs | Low | No effect | 2 RCTs | Low

CI= confidence interval; NSAID = nonsteroidal anti-inflammatory drug; RCT = randomized controlled trial; RR = relative risk; SOE = strength of evidence; SR = systematic review.

Table 32 Pharmacological therapies versus active comparators for acute low back pain

Drug | Pain: Magnitude of Effect | Pain: Evidence | Pain: SOE
Acetaminophen vs. NSAID | No effect | 1 SR (3 RCTs) + 1 RCT | Low
NSAID vs. NSAID | No effect in 15 of 21 RCTs | 1 SR (21 RCTs) | Moderate
COX-2 selective NSAID vs. traditional NSAID | No effect | 1 SR (3 RCTs) | Low
Skeletal muscle relaxant + NSAID vs. NSAID alone | RR, 1.56 (95% CI, 0.92 to 2.70) | 1 SR (2 RCTs) + 1 RCT | Low
Skeletal muscle relaxant vs. skeletal muscle relaxant | No effect | 1 SR (2 RCTs) | Low

CI = confidence interval; NSAID = nonsteroidal anti-inflammatory drug; RCT = randomized controlled trial; RR = relative risk; SOE = strength of evidence; SR = systematic review.

Table 33 Nonpharmacological treatments versus sham, no treatment, or usual care for acute or subacute low back pain

Intervention | Pain: Magnitude of Effect | Pain: Evidence | Pain: SOE | Function: Magnitude of Effect | Function: Evidence | Function: SOE
Exercise vs. usual care | Moderate | 1 SR (3 RCTs) + 3 RCTs | Low | Moderate | 1 SR (3 RCTs) + 3 RCTs | Low
Acupuncture vs. sham | Small | 2 RCTs | Low | No effect | 5 RCTs | Low
Massage vs. sham | Moderate | 1 SR (2 RCTs) | Low | Moderate | 1 SR (2 RCTs) | Low
Massage vs. usual care | Small to no effect | 2 RCTs | Low | Small to no effect | 2 RCTs | Low
Spinal manipulation vs. sham | Small | 2 RCTs | Low | No effect | 1 SR (3 RCTs) | Low
Heat wrap vs. placebo | Moderate | 1 SR (2 RCTs) + 2 RCTs | Moderate | Moderate | 1 SR (2 RCTs) | Moderate
Low-level laser therapy plus NSAID vs. sham plus NSAID | Moderate | 1 RCT | Low | Small | 1 RCT | Low
Lumbar supports vs. no lumbar supports or inactive treatment | Unable to determine | 5 RCTs | Insufficient | Unable to determine | 5 RCTs | Insufficient

NSAID=nonsteroidal anti-inflammatory drug, RCT=randomized controlled trial, SOE=strength of evidence

Table 34 Nonpharmacological treatments versus active comparators for acute or subacute low back pain

Intervention | Pain: Magnitude of Effect | Pain: Evidence | Pain: SOE | Function: Magnitude of Effect | Function: Evidence | Function: SOE
Exercise vs. exercise | No clear differences | > 20 RCTs | Moderate | -- | -- | --
Spinal manipulation vs. other active interventions | No clear differences at 1 week, 1 month, 3- 6 months, 1 year | 1 SR (3 RCTs) | Moderate | No clear differences | 1 SR (3 RCTs) | Moderate
Spinal manipulation plus exercise or advice vs. exercise or advice alone | -- | -- | -- | Small, favors spinal manipulation at 1 week | 1 SR (4 RCTs) | Low
Spinal manipulation plus exercise or advice vs. exercise or advice alone | -- | -- | -- | No clear differences at 1, 3 months | 1 SR (3 RCTs) | Low
Heat plus exercise vs. exercise alone | Moderate, favors heat | 1 SR | Low | -- | -- | --
Heat vs. simple analgesics | Moderate, favors heat | 1 SR | Low | -- | -- | --
Heat vs. exercise | No clear differences | 1 RCT | Low | No clear differences | 1 RCT | Low
Lumbar support plus education vs. education | No clear differences | 1 RCT | Low | No clear differences | 1 RCT | Low

RCT=randomized controlled trial, SOE=strength of evidence

Table 35 Pharmacological therapies versus placebo for chronic low back pain

Drug | Pain: Magnitude of Effect | Pain: Evidence | Pain: SOE | Function: Magnitude of Effect | Function: Evidence | Function: SOE
Acetaminophen | No evidence | -- | -- | No evidence | -- | --
NSAIDs | Moderate | 1 SR (4 RCTs) | Moderate | Small | 1 SR (2 RCTs) | Low
Opioids | Small | 1 SR (6 RCTs) | Moderate | Small | 1 SR (4 RCTs) | Moderate
Skeletal muscle relaxants | Unable to estimate | 3 RCTs | Insufficient | -- | -- | --
Tramadol | Moderate | 1 SR (5 RCTs) + 2 RCTs | Moderate | Small | 1 SR (5 RCTs) + 2 RCTs | Moderate
Benzodiazepines: tetrazepam | Failure to improve at 10–14 days: RR, 0.71 (95% CI, 0.54 to 0.93) | 1 SR (2 RCTs) | Low | -- | -- | --
Tricyclic antidepressants | No effect | 1 SR (4 RCTs) | Moderate | No effect | 1 SR (2 RCTs) | Low
Antidepressants: SSRI | No effect | 1 SR (3 RCTs) | Moderate | -- | -- | --
Antidepressants: duloxetine | Small | 3 RCTs | Moderate | Small | 3 RCTs | Moderate
Gabapentin/pregabalin | Unable to estimate | 2 RCTs | Insufficient | Unable to estimate | 2 RCTs | Insufficient

NSAID=nonsteroidal anti-inflammatory drug, RCT=randomized controlled trial, SOE=strength of evidence, SSRI=selective serotonin reuptake inhibitor

Table 36 Pharmacological therapies versus active comparators for chronic low back pain

Drug | Pain: Magnitude of Effect | Pain: Evidence | Pain: SOE | Function: Magnitude of Effect | Function: Evidence | Function: SOE
Acetaminophen vs. NSAID | Unable to estimate | 1 RCT | Insufficient | Unable to estimate | 1 RCT | Insufficient
NSAID vs. NSAID | No difference | 6 RCTs | Moderate | -- | -- | --
Opioid vs. NSAID | Unable to estimate (inconsistent) | 3 RCTs | Insufficient | No difference | 1 RCT | Insufficient
Long-acting opioid vs. long-acting opioid | No clear difference | 4 RCTs | Moderate | No clear difference | 4 RCTs | Moderate
Long-acting opioid vs. short-acting opioid | No clear difference^*^ | 6 RCTs | Low | -- | -- | --
Benzodiazepine (diazepam) vs. skeletal muscle relaxant | No difference | 1 RCT | Low | -- | -- | --
Skeletal muscle relaxant vs. skeletal muscle relaxant | No clear difference | 1 SR (2 RCTs) | Low | -- | -- | --

NSAID=nonsteroidal anti-inflammatory drug, RCT=randomized controlled trial, SOE=strength of evidence

* Although some RCTs found long-acting opioids associated with greater pain relief, patients randomized to long-acting opioids also received higher doses of opioids

Table 37 Nonpharmacological treatments versus sham, no treatment, or usual care for chronic low back pain

Intervention | Pain: Magnitude of Effect | Pain: Evidence | Pain: SOE | Function: Magnitude of Effect | Function: Evidence | Function: SOE
Exercise vs. usual care | Small | 1 SR (19 RCTs) + 1 SR | Moderate | Small | 1 SR (17 RCTs) + 1 SR | Moderate
Motor control exercises vs. minimal intervention | Moderate (short to long term) | 1 SR (2 RCTs) | Low | Small (short to long term) | 1 SR (3 RCTs) | Low
Tai chi vs. wait list or no tai chi | Moderate | 2 RCTs | Low | Small | 1 RCT | Low
Yoga vs. usual care | Moderate | 1 RCT | Low | Moderate | 1 RCT | Low
Yoga vs. education | Small (short term) and no effect (long term) | 5 RCTs (short term) + 4 RCTs (long term) | Low | Small (short term) and no effect (long term) | 5 RCTs (short term) + 4 RCTs (long term) | Low
Progressive relaxation vs. wait-list control | Moderate | 1 SR (3 RCTs) | Low | Moderate | 1 SR (3 RCTs) | Low
EMG biofeedback vs. wait list or placebo | Moderate | 1 SR (3 RCTs) | Low | No effect | 1 SR (3 RCTs) | Low
Operant therapy vs. wait-list control | Small | 1 SR (3 RCTs) | Low | No effect | 1 SR (2 RCTs) | Low
Cognitive-behavioral therapy vs. wait-list control | Moderate | 1 SR (5 RCTs) | Low | No effect | 1 SR (4 RCTs) | Low
Multidisciplinary rehabilitation vs. no multidisciplinary rehabilitation | Moderate | 1 SR (3 RCTs) | Low | Small | 1 SR (3 RCTs) | Low
Multidisciplinary rehabilitation vs. usual care | Moderate (short term), small (long term), favors rehabilitation | 1 SR (9 RCTs) (short term) + 1 SR (7 RCTs) (long term) | Moderate | Small (short and long term) | 1 SR (9 RCTs) (short term) + 1 SR (7 RCTs) (long term) | Moderate
Acupuncture vs. sham acupuncture | Moderate | 1 SR (4 RCTs) + 4 RCTs | Low | No effect | 1 SR (4 RCTs) + 4 RCTs | Low
Acupuncture vs. no acupuncture | Moderate | 1 SR (4 RCTs) | Moderate | Moderate | 1 SR (3 RCTs) | Moderate
Spinal manipulation vs. sham manipulation | No effect | 1 SR (3 RCTs) + 1 RCT | Low | Unable to estimate | 1 RCT | --
Spinal manipulation vs. inert treatment | Small | 7 RCTs | Low | -- | -- | --
Massage vs. usual care | No effect | 1 RCT | Low | Unable to estimate | 2 RCTs | Insufficient
Ultrasound vs. sham ultrasound | No effect | 1 SR (3 RCTs) | Low | Unable to estimate | 5 RCTs | Insufficient
Ultrasound vs. no ultrasound | No effect | 1 SR (2 RCTs) | Low | No effect | 1 SR (2 RCTs) | Low
TENS vs. sham TENS | No effect | 1 SR (4 RCTs) | Low | No effect | 1 SR (2 RCTs) | Low
PENS vs. sham PENS | Unable to estimate | 2 RCTs | Insufficient | Unable to estimate | 2 RCTs | Insufficient
Electrical muscle stimulation vs. sham, no stimulation, or usual care | No evidence | -- | -- | No evidence | -- | --
Low-level laser therapy vs. sham laser | Small | 3 RCTs | Low | Small | 3 RCTs | Low
Lumbar supports vs. no lumbar supports | Unable to estimate | 2 RCTs | Insufficient | Unable to estimate | 2 RCTs | Insufficient
Traction vs. placebo, sham, or no traction | Unable to estimate | 1 SR (13 RCTs) | Insufficient | Unable to estimate | 1 SR (13 RCTs) | Insufficient
Kinesio taping^®^ vs. sham taping | No effect | 2 RCTs | Low | No effects | 2 RCTs | Low

NSAID=nonsteroidal anti-inflammatory drug, PENS=percutaneous electrical nerve stimulation, RCT=randomized controlled trial, SOE=strength of evidence, TENS= transcutaneous electrical nerve stimulation

Table 38 Nonpharmacological treatments versus active comparators for chronic low back pain

Intervention | Pain: Magnitude of Effect | Pain: Evidence | Pain: SOE | Function: Magnitude of Effect | Function: Evidence | Function: SOE
MCE vs. general exercise (short term) | Small, favors MCE for short term | 1 SR (6 RCTs) | Low | Small, favors MCE | 1 SR (6 RCTs) | Low
MCE vs. general exercise (intermediate term) | Small, favors MCE for intermediate term | 1 SR (3 RCTs) | Low | -- | -- | --
MCE vs. general exercise (long term) | Small, favors MCE for long term | 1 SR (4 RCTs) | Low | Small, favors MCE | 1 SR (3 RCTs) | Low
MCE vs. multimodal physical therapy (intermediate term) | Moderate, favors MCE | 1 SR (4 RCTs) | Low | Moderate, favors MCE | 1 SR (3 RCTs) | Low
MCE + exercise vs. exercise alone | No clear difference | 2 RCTs | Low | -- | -- | --
Pilates vs. usual care + physical activity | No effect to small effect, favors Pilates | 7 RCTs | Low | No clear difference | 7 RCTs | Low
Pilates vs. other exercise | No clear difference | 3 RCTs | Low | No clear difference | 3 RCTs | Low
Tai chi vs. other exercise | Moderate, favors tai chi | 1 RCT | Low | -- | -- | --
Yoga vs. exercise | Small, favors yoga | 1 SR (5 RCTs) | Low | -- | -- | --
Psychological therapies vs. exercise or physical therapy | No clear difference | 1 SR (6 RCTs) | Low | -- | -- | --
Psychological therapies vs. psychological therapies | No clear difference | 10 RCTs | Moderate | No clear difference | 10 RCTs | Moderate
Multidisciplinary rehabilitation vs. physical therapy (short term) | Small, favors multidisciplinary rehabilitation | 1 SR (12 RCTs) | Moderate | Small, favors multidisciplinary rehabilitation | 1 SR (13 RCTs) | Moderate
Multidisciplinary rehabilitation vs. physical therapy (long term) | Moderate, favors multidisciplinary rehabilitation | 1 SR (9 RCTs) | Moderate | Moderate, favors multidisciplinary rehabilitation | 1 SR (10 RCTs) | Moderate
Spinal manipulation vs. other active interventions (exercise, usual care, medications, massage) | No clear difference | 1 SR (6 RCTs) | Moderate | No clear difference | 1 SR (6 RCTs) | Moderate
Acupuncture vs. medications | Small, favors acupuncture | 1 SR (3 RCTs) | Low | Small, favors acupuncture | 1 SR (3 RCTs) | Low

MCE=motor control exercise, RCT=randomized controlled trial, SOE=strength of evidence

The use of opioids for chronic pain has become an area of increasing concern, due to uncertain long-term effectiveness and marked increases in the number of accidental overdoses, as well as other harms related to their abuse potential.603 Patients with low back pain are frequently prescribed opioids and account for a high proportion of the patients prescribed opioids. Decisions regarding the appropriate use of opioids for low back pain must weigh short-term, relatively modest benefits against potential harms. Guidelines recommend risk assessment, careful patient selection, and close monitoring and followup in patients prescribed opioids.641

The continued paucity of evidence to determine effective treatments for radicular low back pain (Tables 39, 40, and 41) necessitates that most decisions are based on extrapolation of evidence on the effectiveness of treatments for nonradicular low back pain or other nonback-related neuropathic pain conditions. This could explain why antiseizure medications such as gabapentin and pregabalin are being prescribed more for radicular low back pain, despite the lack of evidence showing that they are effective. Systemic corticosteroids continue to be used for treatment of radicular back pain, despite trials showing that they are ineffective, presumably based upon their known anti-inflammatory properties and use in epidural injections.

Table 39 Pharmacological therapies versus placebo for radicular low back pain

Drug | Pain: Magnitude of Effect | Pain: Evidence | Pain: SOE | Function: Magnitude of Effect | Function: Evidence | Function: SOE
NSAIDs | Small | 1 SR (2 RCTs) | Low | -- | -- | --
Benzodiazepines: diazepam | RR, 0.5 (95% CI, 0.3 to 0.8) | 1 RCT | Low | No effect | 1 RCT | Low
Systemic corticosteroids | No effect | 5 RCTs | Moderate | No effect | 5 RCTs | Moderate
Gabapentin/pregabalin | Unable to estimate | 5 RCTs | Insufficient | Unable to estimate | 5 RCTs | Insufficient

NSAID=nonsteroidal anti-inflammatory drug, RCT=randomized controlled trial, SOE=strength of evidence

Table 40 Nonpharmacological treatments versus sham, no treatment, or usual care for radicular low back pain

Intervention | Pain: Magnitude of Effect | Pain: Evidence | Pain: SOE | Function: Magnitude of effect | Function: Evidence | Function: SOE
Exercise vs. usual care | Small, favors exercise | 3 RCTs | Low | Small, favors exercise | 3 RCTs | Low
Traction vs. placebo, sham, or no treatment (includes radicular and nonradicular patients) | Unable to estimate | 1 SR (13 RCTs) | Insufficient | Unable to estimate | 1 SR (13 RCTs) | Insufficient

RCT=randomized controlled trial, SOE=strength of evidence

Table 41 Nonpharmacological treatments versus active comparators for radicular low back pain

Intervention | Pain: Magnitude of Effect | Pain: Evidence | Pain: SOE | Function: Magnitude of Effect | Function: Evidence | Function: SOE
Traction vs. physiotherapy (includes radicular and nonradicular pain patients) | No clear difference | 1 SR (5 RCTs) | Low | -- | -- | --

RCT=randomized controlled trial, SOE=strength of evidence

Our review support clinical practice guidelines that found insufficient evidence to recommend most physical modalities, other than superficial heat. However, these therapies are still commonly used in clinical practice. Among nonpharmacological therapies that were found to be effective, there was insufficient evidence to determine which patients are most likely to benefit from specific therapies. However, a recent trial which found that a stratified approach (in which patients are assessed for risk factors for chronicity, and higher-risk patients receive more intensive cognitive-behavioral based physical therapy) is more effective than usual care without a stratified approach suggests that psychologically-based therapies and multidisciplinary rehabilitation may be most effective in higher-risk people.631 Other factors that may impact decisions regarding which nonpharmacological therapies to use include cost, availability, and patient preferences. Some evidence suggests that greater patient expectations of benefit from a particular treatment are associated with greater benefits,636, 637 suggesting that patient preferences should be considered in the selection of therapies. Potential barriers to use of some nonpharmacological therapies include variability in health insurance coverage (e.g., for complementary and alternative medicine therapies)642 and nonavailability depending on locale or other factors (e.g., multidisciplinary rehabilitation).643

## Limitations of the Review Process

We included previously published systematic reviews. The reliability of systematic reviews depends on the rigor with which they are conducted.644 Therefore, we focused on higher-quality reviews. For a number of interventions addressed in this report, more than one higher-quality systematic review exists. In addition to quality, we therefore also selected systematic reviews for inclusion based on the closest relevance match based on the Key Questions and scope and how recently searches were conducted.24 If two or more reviews were similar on these criteria, we prioritized inclusion of updates of reviews that were in the prior APS/ACP review. In some cases, the highest-quality systematic reviews did not provide all of the information necessary to assess findings. We only included such reviews if we could address any methodological limitations through review and assessment of the primary studies. Otherwise, such reviews were excluded.

We did not conduct meta-analyses or update meta-analyses included in prior systematic reviews. However, for comparisons without a meta-analysis, we synthesized results qualitatively, using the methods in the AHRQ methods guide. For comparisons for which pooled results were available from prior systematic reviews, we evaluated the consistency of results from new trials against the pooled estimates.

Other limitations of the review process are that we excluded non-English language articles and did not search for studies published only as abstracts. However, some systematic reviews included non-English language articles and abstracts, which did not materially impact conclusions. We were unable to assess for publication bias using graphical or statistical methods to detect small sample effects, methodological limitations in the trials, heterogeneity in the interventions, populations, and outcomes addressed, and small numbers of trials for many comparisons. However, based on searches of reference lists, clinical trials registries, and peer review suggestions, we did not find evidence to suggest that unpublished trials would impact conclusions.

There are other noninvasive interventions for low back pain that we did not address, including herbal medicines,645 educational interventions,646, 647 advice to remain active,646, 648 mattresses, shoe insoles,649 and others.650, 651 We also did not include comparisons of noninvasive therapies versus surgery or interventional procedures, which were outside the scope of this review. We also excluded pain treatment trials that were not restricted to patients with low back pain. The applicability of such trials would depend in part on the proportion of patients with low back pain and what other pain conditions were present.

## Limitations of the Evidence Base

The evidence base had a number of important limitations. As noted previously, evidence on the effectiveness of interventions for radicular low back pain was sparse. Most trials of nonpharmacological treatments focused on patients with chronic low back pain, with insufficient evidence to determine effects for acute low back pain, with the exception of superficial heat. This could be due in part because the natural history or acute low back pain is characterized by rapid improvement, such that nonpharmacological therapies are typically reserved for patients who do not improve in the initial period. A number of interventions were evaluated in small numbers of trials or in trials that primarily had important methodological limitations, precluding strong preclusions. In addition, there were relatively few head-to-head trials of different interventions, making it difficult to compare the effectiveness of one type of therapy versus another, particularly for comparisons of nonpharmacological versus pharmacological therapies.

Another limitation of the evidence base is that studies were frequently short term and often only evaluated patients at the end of a course of therapy, making it difficult to determine whether sustained benefits are present. In addition, many trials reported mean changes in outcome measures (typically pain and function), but did not report dichotomized outcomes (e.g., ≥30% or ≥50% pain relief or functional improvement). Assessment of outcomes based on continuous as well as dichotomized outcomes would provide a more complete assessment of treatment effects.652

Some limitations of the evidence were particularly relevant for trials of nonpharmacological interventions. Studies of nonpharmacological interventions were typically characterized by marked heterogeneity in the specific intervention techniques evaluated, as well as in the duration and intensity of treatments, which could attenuate treatment benefits if suboptimal treatment techniques or intensity of therapy was evaluated. In addition, a number of nonpharmacological therapies (e.g., psychological therapies, exercise therapy, massage, and spinal manipulation) are difficult to blind effectively. Therefore, observed benefits could be due in part to placebo, attentional, or other nonspecific effects, and results are susceptible to performance and other biases, though it is not possible to reliably quantify the extent of such effects. Finally, trials of nonpharmacological therapies did not report harms well; this could be in part because serious harms are not expected with most of these treatments.

## Research Gaps

A number of research gaps limit the full understanding of the effectiveness, comparative effectiveness, and harms of therapies for low back pain.653-656 More research is needed to determine effective treatments for low back pain with radicular symptoms and in understudied populations such as older adults. Trials should be designed to not just evaluate patients immediately after they have completed therapy, but for at least several months after the completion of therapy, in order to help understand whether beneficial effects are sustained. Studies that use more pragmatic designs (e.g., more flexible dosing or use of cointerventions) might help improve patient recruitment and reduce attrition, which is high in long-term trials of low back pain. For nonpharmacological treatments, research to identify optimal treatment techniques and regimens (including intensity and duration of treatments) would be very helpful for defining more standardized interventions to be evaluated in trials.

Studies are needed to determine the long-term effectiveness and harms of opioids for chronic low back pain, including higher-risk patients like those commonly encountered in clinical practice. Studies that compare opioids versus nonopioid therapies that address the psychosocial factors often associated with chronic pain (e.g., interdisciplinary rehabilitation, exercise therapy, or psychological therapies) are needed. Observational studies that are designed to assess serious long-term harms provide some evidence regarding risks of opioids for chronic pain in general, but data specifically in patients with low back pain are lacking.603 Although observational studies based on administrative databases can be helpful for evaluating risks of opioids, such studies are often limited in their ability to address important potential confounders, and should ideally be supplemented by clinical data, such as in well-designed clinical registries. For systemic corticosteroids, the largest trial to date was recently completed and should help further characterize the effectiveness (or lack thereof) of this treatment.657

More research is needed to help understand whether nonradicular low back pain can be reliably classified into clinically meaningful subgroups, and which patients or subgroups are most likely to benefit from specific therapies.658-662 Trials are also needed to confirm whether effects of risk-stratified approaches are reproducible in the United States,663, 664 and to optimize their implementation.665 More research is needed to better understand whether combination therapy with different pharmacological or nonpharmacological treatments is associated with incremental benefits versus individual components of the combination therapy, and which combinations and sequences of therapy are the most effective.

Pain relief was the most commonly assessed outcome in trials of treatment for low back pain, followed by back-specific function. Trials should more consistently assess other outcomes related to return to work, quality of life, and health care utilization, in order to provide a more complete picture of treatment effects. Studies that evaluate the effectiveness of interventions for preventing future episodes of low back pain would also be very helpful, as low back pain can be a recurrent, episodic condition and these patients are likely to account for a high proportion of resources. In addition, trials should evaluate the effectiveness of interventions for preventing the transition from acute to chronic low back pain. In order to provide balanced assessments of low back pain interventions, trials should more consistently and rigorously evaluate and report harms. Trials should routinely collect information on known or common harms associated with a particular intervention, and use more open-ended methods to identify unexpected or uncommon harms.