# Abbreviations Used in the Appendixes

Abbreviation: Term
ADL: Activities of daily living
AE: Adverse event
AIS: Athens Insomnia Scale
BDI: Beck Depression Inventory
bid: Twice daily
BMI: Body mass index
BPI: Brief Pain Inventory
BPI-SF: Brief Pain Inventory-Short Form
BRLP: Back-related leg pain
CBT: Cognitive behavioral therapy
CCRCT: Cochrane Central Register of Controlled Trials
CCT: Controlled clinical trial
CDC HRQOL-4: Centers for Disease Control and Prevention's Health-Related Quality of Life Questionnaire
CGI-S: Clinical Global Impressions of Severity Scale
CI: Confidence interval
CLBP: Chronic low back pain
CMT: Chiropractic Manipulative Therapy
CPAQ: Chronic Pain Acceptance Questionnaire
CSFMPQ: Chinese Short Form McGill Pain Questionnaire
CSQ: Coping Strategies Questionnaire
CT: Computed tomography scan
D: Day
DASS: Depression Anxiety Stress Scales
DPQ: Dallas Pain Questionnaire
DSM-IV: Diagnostic and Statistical Manual of Mental Disorders, 4^th^ edition
EERW: Enriched enrolment with randomized withdrawal
EIFEL: French translation of Roland-Morris Disability Questionnaire
EMG: Electromyography
EPC: Evidence-based Practice Center
ER: Emergency room
FABQ: Fear Avoidance Beliefs Questionnaire
FAPESP: Fundacao de Amparo a Pesquisa do Estado de Sao Paulo
FRI: Functional Rating Index
GA: Graded activity
GDS: Geriatric Depression Scale
GI: Gastrointestinal
GPE: Global Perceived Effect Scale
GRADE: Grading of Recommendations Assessment, Development, and Evaluation
GX: Graded exposure
H: Hour
HADS: The Hospital Anxiety and Depression Scale
HEA: Home exercise with advice
HR: Hazard ratio
HRoB: High risk of bias
HRQOL: Health-related quality of life
HSCL-25: Hopkin's Symptom Checklist
HVLA: High-velocity low-amplitude
I^2^: Statistic that describes the percentage of the variability in effect estimates that is due to heterogeneity
IC: Integrative Care
IM: Intramuscular
IPAQ: International Physical Activity Questionnaire
IPQ: Illness Perception Questionnaire
IPQ-R: Illness Perceptions Questionnaire-Revised
IQR: Interquartile range
ITT: Intention-to-treat
IV: Intravenous therapy
JLEQ: Japan Low Back Pain Evaluation Questionnaire
JOA: Japanese Orthopedic Association
L2: 2^nd^ lumbar vertebra
L4: 4^th^ lumbar vertebra
L5-S1: Lumbosacral joint
LANSS: Leeds Assessment of Neuropathic Symptoms and Signs
LBP: Low back pain
LBPOI: Low Back Pain Outcome Instrument
LBPRS: Low back pain rating scale
LRoB: Low risk of bias
mA: Milliampere
MBR: Multidisciplinary biopsychosocial rehabilitation
MCE: Motor control exercise
MCS: Mental component score of the SF-36
MCS-12: Mental component score of the SF-12
MD: Mean difference
MOS: Medical outcome study
Mos: Months
MPI: Multidimensional Pain Inventory
MPQ: McGill Pain Questionnaire
MRI: Magnetic resonance imaging
NCCAM: National Center for Complementary and Integrative Health
Nd:YAG: Neodymium-doped yttrium aluminium garnet laser
NIAMS: National Institute of Arthritis and Musculoskeletal and Skin Diseases
NIH: National Institute of Health
NIOSHTIC-2: The National Institute for Occupational Safety and Health database
NMT: Measure of back extension strength
NPRS: Numerical pain rating scale
NR: Not reported
NRS: Numeric rating scale
NS: Not significant
NSAID: Nonsteroidal anti-inflammatory drug
OA: Osteoarthritis
ODI: Oswestry Disability Index
OMT: Osteopathic manipulative treatment
PA: Placebo acupuncture
PCS: Pain Catastrophizing Scale
PCS-12: SF12 Physical score
PDI: Pain Disability Index
PEDro: Physiotherapy Evidence Database
PENS: Percutaneous electrical nerve stimulation
PGIC: Patients' Global Impression
PMR: Periodized musculoskeletal rehabilitation
PO: Oral route of medication administration
POMS: Profile of Mood States
PR: Partial response
PRISMA: Preferred Reporting Items for Systematic Reviews and Meta-Analyses
PSC: Patient Specific Complaints
PSEQ: Chronic Pain Self Efficacy Scale
PSFS: Patient-Specific Functional Scale
PSQI: Pittsburgh Sleep Quality Index
PT: Physical therapy
pts: Patients
QBPDS: Quebec Back Pain Disability Scale
QD: Once daily
QHS: Each night at bedtime
QOL: Quality of life
RA: Rheumatoid arthritis
RCT: Randomized controlled trail
RDQ: Roland-Morris Disability Questionnaire
ROB: Risk of bias
RR: Relative risk
S: Second
SA: Sham acupuncture
SAE: Serious adverse event
SCL-90: Symptom Checklist 90
SD: Standard deviation
SF-12: Short Form-12
SF-36: Short Form-36
SF-MPQ: McGill Pain Questionnaire Pain Rating Index- Short-Form
SHCI: Subjective Health Complaint Inventory
SMD: Standardized mean differences
SMR: Skeletal muscle relaxant
SMT: Spinal manipulation therapy
SOE: Summary of evidence
SOWS: Short Opioid Withdrawal Scale
SSRI: Selective serotonin reuptake inhibitor
SSS: Swiss Spinal Stenosis Questionnaire
STAI: State-trait Anxiety Inventory
TA: True acupuncture
TENS: Transcutaneous electrical nerve stimulation
tid: Three times daily
TSK: Tampa Scale of Kinesiophobia
UAW-GM: United Auto Workers- General Motors
UK: United Kingdom
USA: United States of America
USPSTF: United States Preventive Services Task Force
VAS: Visual analog scale
VRS: Visual rating scale
vs.: Versus
w: Week
WHO: World Health Organization
WHOQOL-BREF: World Health Organization Quality of Life-BREF instrument
WMD: Weighted mean difference
WPAI: Work activity impairment subscale
y: Year