# Strength of Evidence

Table H1 Strength of evidence

Key Question Outcome | Study Design Number of Studies | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence
1. What are the comparative benefits and harms of different pharmacological therapies for acute or chronic nonradicular low back pain, radicular low back pain, or spinal stenosis? (Including NSAIDs, acetaminophen, opioids, muscle relaxants, antiseizure medications, antidepressants, corticosteroids, and topicals/patch-delivered medications)
Acetaminophen
Acetaminophen vs. Placebo, acute LBP : Pain and function | 1 RCT | Low | Unable to determine | Direct | Precise | Undetected | Low
Acetaminophen vs. NSAID, acute LBP: Pain and global improvement | 3 RCTs | High | Consistent | Direct | Precise | Undetected | Low
Acetaminophen vs. Placebo, chronic LBP | No studies | - | - | - | - | - | Insufficient
Acetaminophen vs. NSAID, chronic LBP | 1 RCT | High | Unable to determine | Direct | Imprecise | Undetected | Insufficient
Acetaminophen vs. other interventions, acute LBP | 4 RCTs | High | Consistent | Direct | Imprecise | Undetected | Insufficient
Acetaminophen vs. placebo: Adverse events (serious adverse events) | 1 RCT | Low | Consistent | Direct | Imprecise | Undetected | Moderate
Acetaminophen vs. NSAIDs : Adverse events | 3 RCTs in systematic revie | Moderate | Consistent | Direct | Precise | Undetected | Moderate
Acetaminophen vs. Placebo, NSAID or Other intervention, radicular LBP | No studies | - | - | - | - | - | Insufficient
NSAIDs
NSAIDs vs. Placebo, acute LBP : Pain, function | 4 RCTs in systematic review and 1 RCT for pain; 1 RCT for function | Moderate | Consistent for pain Unable to determine for function | Direct | Precise for pain Imprecise for function | Undetected | Moderate for pain, low for function
NSAIDs vs. Placebo, chronic LBP : Pain, function | 4 RCTs in systematic review for pain 2 RCTs for function | Moderate | Consistent | Direct | Precise for pain Imprecise for function | Undetected | Moderate for pain, low for function
NSAIDs vs. Placebo, radicular LBP : Pain | 2 RCTs in systemtic review | Moderate | Inconsistent | Direct | Imprecise | Undetected | Low
NSAID plus another intervention vs. Other intervention alone | 2 RCTs | High | Inconsistent | Direct | Imprecise | Undetected | Insufficient
NSAIDs vs. Interventions other than acetaminophen and opioids | 2 RCTs | High | Inconsistent | Direct | Imprecise | Undetected | Insufficient
NSAID vs. NSAID, acute or chronic LBP : Pain | 27 RCTs | Moderate | Consistent | Direct | Precise | Undetected | Moderate
NSAIDs vs. Placebo : Adverse events | 10 RCTs | Moderate | C onsistent | Direct | Precise | Undetected | Moderate
COX-2-selective NSAIDs vs. nonselective NSAIDs : Adverse events | 4 RCTs | Moderate | Consistent | Direct | Precise | Undetected | Moderate
Opioids, Tramadol and Tapentadol
Opioids vs. Placebo, chronic LBP : Pain and function | 6 RCTs in systematic review and 3 RCTs | Moderate | Consistent | Direct | Precise | Undetected | Moderate
Tramadol vs. Placebo, chronic LBP : Pain and function | 5 RCTs in systematic review and 2 RCTs | Moderate | Consistent | Direct | Precise | Undetected | Moderate
Buprenorphine patch vs. Placebo, subacute or chronic LBP : Pain and function | 2 RCTs in systematic review | Moderate | Consistent for pain Inconsistent for function | Direct | Imprecise | Undetected | Low for pain Insufficient for function
Opioids vs. NSAIDs, chronic LBP : Pain relief, function | 3 RCTs for pain 1RCT for function | Moderate | Inconsistent for pain Unable to determine for function | Direct | Imprecise | Undetected | Insufficient
Opioids vs. Acetaminophen, acute LBP : Days to return to work, pain | 1 RCT for return to work No studies for pain | Moderate | Unable to determine | Direct | Imprecise | Undetected | Insufficient
Long acting opioids vs. Long acting opioids : Pain, function | 4 RCTs | Moderate | Consistent | Direct | Precise | Undetected | Moderate
Long acting opioids vs. Short acting opioids : Pain | 6 RCTs | Moderate | Inconsistent | Direct | Precise | Undetected | Low
Opioids vs. Placebo: Adverse events | 16 RC Ts in systematic review | Moderate | Consistent | Direct | Precise | Undetected | Moderate
Skeletal Muscle Relaxants (SMR)
SMRs vs. Placebo, acute LBP : Pain | 4 RCTs in a systematic review and 1 RCT | Moderate | Consistent | Direct | Precise | Undetected | Moderate
SMR plus NSAID vs. NSAID alone, acute LBP : Pain | 2 RCTs in systematic review and 1 RCT | Moderate | Consistent | Direct | Imprecise | Undetected | Low
SMR vs. Placebo, chronic LBP : Pain | 3 RCTs | Moderate | Inconsistent | Direct | Imprecise | Undetected | Insufficient
SMR vs. SMR, acute or chronic LBP : Pain | 3 RCTs in systematic review | Moderate | Consistent | Direct | Imprecise | Undetected | Low
SMR vs. Placebo, acute LBP : Adverse events | 8 RCTs in systematic review and 1 RCT | Moderate | Consistent | Direct | Precise | Undetected | Moderate
Benzodiazepines
Benzodiazepines vs. Placebo, acute LBP : Pain, function | 2 RCTs | Moderate | Inconsistent | Direct | Imprecise | Undetected | Insufficient
Tetrazepam vs. Placebo, chronic LBP:Pain, overall improvement | 2 RCTs in systematic review | Moderate | Consistent | Direct | Imprecise | Undetected | Low
Diazepam vs. Placebo, acute or subacute radicular pain : Pain, function | 1 RCT | Low | Unable to determine | Direct | Precise | Undetected | Low
Benzodiazepines vs. Skeletal muscle relaxants, chronic LBP: Pain, function | 2 RCTs | Low | Inconsistent | Direct | Imprecise | Undetected | Insufficient
Diazepam vs. Cyclobenzaprine, chronic LBP : Muscle spasms | 1 RCT | Moderate | Unable to determine | Direct | Imprecise | Undetected | Low
Benzodiazepines vs. Placebo: Adverse events | 8 RCTs in systematic review and 1 RCT | Moderate | Consistent | Direct | Imprecise | Undetected | Low
Antidepressants
Tricyclic antidepressants or SSRI vs. Placebo, chronic LBP : Pain, function | 4 RCTs of tricyclics and 3 RCTs of SSRIs in systematic review for pain; 2 RCTs evaluated function | Moderate | Consistent | Direct | Imprecise | Undetected | Moderate for pain, low for function
Duloxetine vs. Placebo, chronic LBP : Pain, Function | 3 RCTs | Low | Consistent | Direct | Precise | Undetected | Moderate
Duloxetine vs. Tricyclic antidepressants | No studies | - | - | - | - | - | Insufficient
Antidepressants vs. Placebo : Adverse events, Serious adverse events | 9 RCTs in systematic review and 3 RCTs | Moderate | Consistent | Direct | Precise | Undetected | Moderate
Antiseizure medications
Antiseizure medications, acute non-radicular LBP | No studies | - | - | - | - | - | Insufficient
Gabapentin vs. Placebo, chronic non-radicular LBP | 1 RCT (abstract only, excluded) | - | - | - | - | Suspected | Insufficient
Gabapentin vs. Placebo, chronic radicular LBP: Pain and function | 3 RCTs | High | Inconsistent | Direct | Imprecise | Undetected | Insufficient
Topiramate vs. Placebo, chronic radicular or mixed radicular and non-radicular LBP: Pain | 2 RCTs | Moderate | Inconsistent | Direct | Imprecise | Undetected | Insufficient
Pregabalin vs. Placebo, chronic radicular LBP : pain, function | 2 RCTs | Moderate | Inconsistent | Direct | Imprecise | Undetected | Insufficient
Pregabalin plus transdermal buprenorphine vs. transdermal buprenorphine, chronic non-radicular LBP : Pain | 1 RCT | Moderate | Unable to determine | Direct | Imprecise | Undetected | Insufficient
Pregabalin plus another anaglesic vs. the other analgesica alone: Pain | 2 RCTs | Moderate | Inconsistent | Direct | Imprecise | Undetected | Insufficient
Gabapentin vs. Placebo : Adverse events | 2 RCTs | Moderate | Consistent | Direct | Imprecise | Undetected | Low
Topiramate vs. Placebo : Withdrawal due to adverse events, sedation, diarrhea | 2 RCTs | Moderate | Inconsistent | Direct | Imprecise | Undetected | Insufficient
Pregabalin vs. Placebo : Withdrawal due to adverse events, somnolence, dizziness | 2 RCTs | Moderate | Inconsistent | Direct | Imprecise | Undetected | Insufficient
Corticosteroids
Systemic corticosteroids vs. Placebo, acute non-radicular LBP : Pain, function | 2 RCTs | Moderate | Consistent | Direct | Imprecise | Undetected | Low
Systematic corticosteroids vs. Placebo, radicular LBP : Pain, function | 5 RCTs | Moderate | Consistent | Direct | Precise | Undetected | Moderate
Systemic corticosteroids vs. Placebo, spinal stenosis: Pain, function | 1 RCT | Moderate | Unable to determine | Direct | Precise | Undetected | Low
Systemic corticosteroids : Adverse events | 12 RCTs | Moderate | Consistent | Direct | Imprecise | Undetected | Low
2. What are the comparative benefits and harms of different nonpharmacological, noninvasive therapies for acute or chronic nonradicular low back pain, radicular low back pain, or spinal stenosis?
Exercise
Exercise vs. Usual care, acute to subacute LBP : Pain, function | 8 RCTs in systematic review and 3 RCTs | Moderate | Consistent | Direct | Imprecise | Undetected | Low
Exercise vs. Usual care, chronic LBP: Pain, Function | 19 RCTs in systematic review 3 RCTs in another systematic review, and 20 RCTs | Moderate | Consistent | Direct | Precise | Undetected | Moderate
MCE vs. Minimal intervention, chronic LBP : Pain, function | 2 RCTs for pain and 3 RCTs for function in systematic review | Modeate | Consistent | Direct | Imprecise | Undetected | Low
Exercise vs. Usual care, non- acute LBP: Work disability | 8 RCTs in systematic review | Moderate | Consistent | Direct | Precise | Undetected` | Moderate
Exercise vs. Usual care, radicular LBP: Pain, function | 3 RCTs | Moderate | Consistent | Direct | Imprecise | Undetected | Low
Exercise vs. Exercise, acute or chronic LBP | >20 RCTs | Moderate | Consistent | Direct | Precise | Suspected | Moderate
Exercise : Adverse events | | | | | | | Low
MCE vs. General exercise, chronic LBP : Pain, function | 6 RCTs in systematic review and 2 RCTs | Moderate | Consistent | Direct | Imprecise | Undetected | Low
MCE vs. Multimodal PT, chronic LBP : Pain, function | 4 RCTs for pain and 2 RCTs for function in systematic review | Moderate | Consistent | Direct | Imprecise | Undetected | Low
MCE plus exercise vs. Exercise alone | 2 RCTs | Moderate | Consistent | Direct | Imprecise | Undetected | Low
MCE : Adverse events | 6 RCTs | Moderate | Consistent | Direct | Precise | Suspected | Low
Pilates
Pilates vs. usual care plus physical activity, chronic LBP: Pain, function | 7 RCTs in systematic review | Moderate | Inconsistent | Direct | Precise | Undetected | Low
Pilates vs. other exercise, chronic LBP: Pain, function | 3 RCTs in systematic review | Moderate | Consistent | Direct | Imprecise | Undetected | Low
Tai Chi
Tai Chi vs. waitlist or no Tai Chi, chronic LBP : Pain, function | 2 RCTs for pain, 1 RCT for function | Moderate | Consistent for pain Unable to determine for function | Direct | Imprecise | Undetected | Low
Tai Chi vs. other exercise, chronic LBP : Pain | 1 RCT | Moderate | Unable to determine | Direct | Imprecise | Undetected | Low
Tai Chi : Adverse events | 2 RCTs | Moderate | Unable to determine | Direct | Imprecise | Undetected | Low
Yoga
Yoga vs. Usual care, chronic LBP :Pain, Function | 1 RCT | Moderate | Unable to determine | Direct | Imprecise | Undetected | Low
Yoga vs. Exercise, chronic LBP : Pain, Function | 5 RCTs in sytematic review | Moderate | Consistent | Direct | Imprecise | Undetected | Low
Yoga vs. Education, chronic LBP : Pain, function | 5 RCTs | Moderate | Consistent | Direct | Precise | Undetected | Moderate
Yoga : Adverse events | 5 RC Ts | Moderate | Consistent | Direct | Imprecise | Suspected | Low
Psychological Therapies
Progressive relaxation vs. wait list control, chronic LBP : Pain, Function | 3 RCTs in systematic review | Moderate | Inconsistent | Direct | Precise | Undetected | Low
EMG biofeedback, chronic LBP : Pain, Function | 3 RCTs in systematic review | Moderate | Consistent | Direct | Imprecise | Undetected | Low
Operant therapy, chronic LBP : Pain, Function | 3 RCTs for pain, 2 RCTs for function in systematic review | Moderate | Consistent | Direct | Imprecise | Undetected | Low
Cognitive therapy vs. Wait list control, chronic LBP | 2 RCTs in systematic review | Moderate | Inconsistent | Direct | Imprecise | Undetected | Insufficient
Cognitive-behavioral and other combined therapy vs. Wait list control, chronic LBP : Pain, Function | 5 RCTs for pain, 4 RCTs for function in systematic review | Moderate | Consistent | Direct | Imprecise | Undetected | Low
Psychological therapies vs. exercise or physical therapy, chronic LBP : Pain | 8 RCTs | Moderate | Inconsistent | Direct | Precise | Undetected | Low
Psychological therapies vs. Psychological therapies : Pain, Function | 10 RCTs | Modeate | Inconsistent | Direct | Precise | Undetected | Moderate
Psychological therapies : Adverse events | 28 RCTs in systematic review | High | Consisent | Direct | Imprecise | Suspected | Low
Multidisciplinary rehabilitation
Multidisciplinary rehabilitation vs. Usual care, chronic LBP : Pain, function, return to work | 9 RCTs in systematic review | Moderate | Inconsistent | Direct | Precise | Undetected | Moderate
Multidisciplinary rehabilitation vs. No multidisciplinary rehabilitation, chronic LBP : Pain, function | 3 RCTs in systematic review | Moderate | Consistent | Direct | Imprecise | Undetected | Low
Multidisciplinary rehabilitation vs. Physical therapy, chronic LBP : Pain, function | 13 RCTs in systematic review | Moderate | Inconsistent | Direct | Precise | Undetected | Moderate
Multidisciplinary rehabilitation, acute LBP, radicular LBP | No studies | | | | | | Insufficient
Multidisciplinary rehabilitation : Adverse events | 2 RCTs | High | Consistent | Direct | Imprecise | Suspected | Low
Acupuncture
Acupuncture vs. Sham acupuncture, subacute LBP : Pain | 3 RCTs in systematic review and 2 RCTs | Moderate | Consistent | Direct | Imprecise | Undetected | Low
Acupuncture vs. Sham acupuncture, chronic LBP : Pain, function | 7 RCTs in systematic review and 1 RCT | Moderate | Inconsistent | Direct | Precise | Undetected | Moderate
Acupuncture vs. No acupuncture, chronic low back pain | 5 RCTs in systematic review | Moderate | Inconsistent | Direct | Precise | Undetected | Moderate
Acupuncture vs. NSAIDs, acute LBP : Overall improvement | 5 RCTs in systematic review | Moderate | Consistent | Direc t | Imprecise | Undetected | Low
Acupuncture vs. Medications, chronic LBP : Pain, Function | 3 RCTs in systematic review | High | Consistent | Direct | Precise | Undetected | Low
Acupuncture : Adverse events | 3 RCTs | Moderate | Consistent | Direct | Imprecise | Undetected | Low
Massage
Massage vs. Sham massage, acute LBP: Pain, function | 2 RCTs in systematic review | Moderate | Consistent | Direct | Imprecise | Undetected | Low
Massage vs. Usual care, chronic LBP: Pain, function | 2 RCTs | Moderate | Inconsistent | Direct | Precise | Undetected | Low
Massage vs. Other interventions, subacute to chronic LBP: Pain, function | 9 RCTs for pain and 4 RCTs for function in systematic review | Moderate | Consistent | Direct | Precise | Undetected | Moderate
Massage plus another active intervention vs. the Other intervention alone, subacute to chronic low back pain: Pain, function | 5 RCTs in systematic review and 2 RCTs | Moderate | Consistent | Direct | Imprecise | Undetected | Low
Massage vs. massage: Pain, function | 6 RCTs | High | Inconsistent | Direct | Imprecise | Undetected | Insufficient
Massage: Adverse events | 12 RCTs | High | Consistent | Direct | Prec ise | Suspected | Low
Spinal manipulation
Spinal manipulation, acute LBP : Pain, function | 1 RCT for pain and 2 RCTs for function | High | Unable to determine for pain Consistent for function | Direct | Imprecise | Undetected | Low for function Insufficient for pain
Spinal manipulation vs. Sham manipulation, chronic LBP : Pain, function | 3 RCTs in systematic review and 1 RCT | Moderate | Inconsistent | Direct | Precise | Undetected | Low for pain Insufficient for function
Spinal manipulation vs. Intert treatment, acute LBP : Pain, Function | 3 RCTs in systematic review | Moderate | Consistent | Direct | Imprecise | Undetected | Low
Spinal manipulation vs. Inert treatment, chronic LBP | 4 RCTs in systematic review and 3 RCTs | Modeate | Inconsistent | Direct | Precise | Undetected | Low
Spinal manipulation vs. Other active interventions, acute LBP : Pain, function | 3 RCTS in systematic review | Moderate | Consistent | Direct | Imprecise | Undetected | Moderate
Spinal manipulation vs. Other interventions, chronic LBP : Pain, function | 6 RCTs in systematic review and 3 RCTs | Moderate | Consistent | Direct | Precise | Undetected | Moderate
Spinal manipulation plus exercise or advice vs. exercise or advice alone, acute LBP : Function | 4 RCTs in systematic review | Moderate | Consistent | Direct | Imprecise | Undetected | Low
Spinal manipulation plus another active treatment, chronic LBP : Pain, function | 3 RCTS in systematic review | Moderate | Consistent | Direct | Imprecise | Undetected | Low
Spinal manipulation : Adverse events | 55 RCTs | Moderate | Consistent | Direct | Precise | Suspected | Low
Ultrasound
Ultrasound vs. Sham ultrasound, chronic LBP : Pain, function | 5 RCTs | Moderate | Consistent for pain Inconsistent for function | Direct | Imprecise | Undetected | Low for pain Insufficient for function
Ultrasound vs. No ultrasound, chronic LBP : Pain, function | 2 RCTs | Moderate | Consistent | Direct | Imprecise | Undetected | Low
Ultrasound plus exercise vs. Exercise, chronic LBP : Pain, Function | 2 RCTs | High | Consistent | Direct | Imprecise | Undetected | Insufficient
Ultrasound plus exercise vs. Exercise, Radicular LBP: Back pain, leg pain | 1 RCT | Moderate | Unable to determine | Direct | Precise | Undetected | Moderate
Ultrasound vs. Other interventions | 3 RCTs | High | Inconsistent | Direct | Imprecise | Undetected | Insufficient
Ultrasound vs. Other interventions, radiculopathy | 2 RCT | High | Unable to determine | Direct | Imprecise | Undetected | Insufficient
Ultrasound, acute non-radicular LBP | No studies | | | | | | Insufficient
Spinal manipulation plus home exercise and advice, radicular LBP | 1 RCT | Moderate | Unable to determine | Direct | Precise | Suspected | Low
Ultrasound vs. Sham ultrasound : Adverse events | 1 RCT | Low | Unable to determine | Direct | Imprecise | Suspected | Low
Transcutaneous electrical nerve stimulation [TENS]
TENS vs. Sham TENS, acute or subacute LBP: Pain, function | 2 RCTs | High | Unable to determine | Direct | Imprecise | Undetected | Insufficient
TENS vs. Sham TENS, chronic LBP : Pain, function | 4 RCTs for pain and 2 RCTs for function in systematic review | Moderate | Consistent | Direct | Iimprecise | Undetected | Low
TENS vs. Acupuncture, chronic LBP : Pain | 4 RCTs for pain and 2 RCTs for function in systematic review | Moderate | Consistent | Direct | Imprecise | Undetected | Low
TENS : Adverse events | 8 RCTs in systematic review | Moderate | Consistent | Direct | Imprecise | Suspected | Low
Electrical muscle stimulation [EMS]
EMS plus exercise vs. Exercise, EMS vs. Other interventions, acute or chronic LBP: Pain, function | 5 RCTs | Moderate | Inconsistent | Direct | Imprecise | Undetected | Insufficient
EMS: Adverse events | 1 RCT | Moderate | Unable to determine | Direct | Imprecise | Suspected | Insufficient
Percutaneous Electrical Nerve Stimulation [PENS]
PENS vs. Sham PENS, PENS plus exercise vs. exercise, PENS vs. other interventions, chronic LBP (with or without radiculopathy) | 7 RCTs | High | Inconsistent | Direct | Imprecise | Undetected | Insufficient
PENS : Adverse events | 1 RCT | High | Unable to determine | Direct | -- | Suspected | Insufficient
Interferential therapy [IFT]
IFT vs. other interventions, IFT plus another intervention vs. the other intervention,subacute to chronic LBP: Pain, function | 4 RCTs | High | Inconsistent | Direct | Imprecise | Undetected | Insufficient
IFT : Adverse events | No studies | | | | | Suspected | Insufficient
Superficial Heat or Cold
Heat wrap vs. Placebo, acute or subacute LBP : Pain, function | 2 RCTs in systematic review and 2 RCTs | Moderate | Consistent | Direct | Precise | Undetected | Moderate
Heat plus exercise vs. exercise alone, acute LBP : Pain, function | 1 RCT | Low | Unable to determine | Direct | Imprecise | Undetected | Low
Heat plus NSAID vs. NSAID alone, acute LBP:Pain | 1 RCT | Moderate | Unable to determine | Direct | Imprecise | Undetected | Insufficient
Heat vs. Simple analgesics, acute or subacute LBP : Pain, function | 1 RCT in systematic review | Low | Unable to determine | Direct | Imprecise | Undetected | Low
Heat vs. Exercise, acute LBP : Pain, Function | 1 RCT in systematic review | Low | Unable to determine | Direct | Imprecise | Undetected | Low
Cold plus naproxen vs. naproxen alone, acute LBP: Pain | 1 RCT | Moderate | Unable to determine | Direct | Imprecise | Undetected | Insufficient
Superficial Cold vs. Placebo | No studies | | | | | | Insufficient
Heat vs. Cold | 3 RCTs | High | Consistent | Direct | Imprecise | Undetected | Insufficient
Heat vs. No heat or placebo : Adverse events, flushing | 2 RCTs | Low | Consistent | Direct | Imprecise | Suspected | Low
Low Level Laser Therapy [LLLT]
LLLT vs. Sham laser, acute LBP | 1 RCT | High | Unable to determine | Direct | Imprecise | Undetected | Insufficient
LLLT vs. Sham laser, chronic LBP : Pain, Function | 3 RCTs for pain, 1 RCT for function | Moderate | Consistent | Direct | Imprecise | Undetected | Low
LLLT plus NSAID vs. Sham plus NSAID, acute or subacute LBP : Pain, function | 1 RCT | Low | Unable to determine | Direct | Imprecise | Undetected | Low
LLLT plus another intervention vs. the other intervention alons, chronic LBP: Pain, function | 3 RCTs | Moderate | Inconsistent | Direct | Imprecise | Undetected | Insufficient
LLLT vs. anotehr intervention: Pain, function | 2 RCTs | High | Unable to determine | Direct | Imprecise | Undetected | Insufficient
LLLT differing wavelengths or doses | 1 RCT | Moderate | Unable to determine | Direct | Imprecise | Undetected | Insufficient
LLLT : Adverse events | 10 RCTs | High | Consistent | Direct | Imprecise | Suspected | Low
Short-wave Diathermy
Short-wave diathermy vs. Sham diathermy, mixed duration LBP : Effectiveness, Adverse events | 4 RCTs | High | Inconsistent | Direct | Imprecise | Undetected | Insufficient
Short-wave diathermy: Adverse events | No studies | | | | | Suspected | Insufficient
Lumbar Supports
Lumbar supports vs. no lumbar supports or an inactive treatment, acute or subacute LBP: Pain, function | 4 RCTs in systematic review and 1 RCT | Moderate | Inconsistent | Direct | Imprecise | Undetected | Insufficient
Lumbar supports vs. no lumbar supports, chronic LBP | 2 RCTs | Moderate | Inconsistent | Direct | Imprecise | Undetected | Insufficient
Lumbar supports vs. no lumbar supports, mixed duration LBP: Pain and function | 1 RCT | Moderate | Unable to determine | Direct | Precise | Undetected | Low
Lumbar support plus education vs. education, acute or subacute LBP : Pain, function | 1 RCT | Moderate | Unable to determine | Direct | Imprecise | Undetected | Low
Lumbar support plus exercise vs. exercise alone, chronic LBP : Pain, function | 1 RCT | Moderate | Unable to determine | Direct | Imprecise | Undetected | Low
Lumbar support vs. other active treaatments : Pain, Function | 3 RCTs | Moderate | Inconsistent | Direct | Imprecise | Undetected | Low
Lumbar supports vs. Lumbar supports: Pain, function | 2 RCTs | Moderate | Inconsistent | Direct | Imprecise | Undetected | Insufficient
Lumbar supports : Adverse events | 8 RCTs in systematic review and 3 RCTs | Moderate | Consistent | Direct | Imprecise | Suspected | Low
Traction
Traction vs. placebo, sham or no treatment, LBP with or without radicular symptoms : Pain, function | 13 RCTs in systematic review and 2 RCTs | Moderate | Inconsistent | Direct | Imprecise | Undetected | Insufficient
Traction vs. physiotherapy, LBP with or without radicular symptoms: Pain, function | 5 RCTs in systematic review | Moderate | Consistent | Direct | Imprecise | Undetected | Low
Traction vs. other interventions, LBP with or without radicular symptoms : Pain, function | 15 RCTs in systematic review | Moderate | Consistent | Direct | Imprecise | Undetected | Low
Traction vs. Traction: Pain, function | 5 RCTs in systematic review | Moderate | Consistent | Direct | Imprecise | Undetected | Low
Traction : Adverse events | 11 RCTs in systematic reviews | Moderate | Consistent | Direct | Imprecise | Undetected | Low
Taping
Kinesio Taping vs. Sham taping, chronic LBP : Pain, Function | 2 RCTs | Low | Inconsistent for pain Consistent for function | Direct | Imprecise | Undetected | Insufficient for pain Low for function
Functional Fascial Taping plus exercise vs. Sham taping plus exercise, chronic LBP: Pain, function | 1 RCT | Moderate | Unable to determine | Direct | Imprecise | Undetected | Insufficient
Kinesio Taping vs. exercise therapy, chronic LBP : Pain, Function | 2 RCTs | Moderate | Inconsistent | Direct | Imprecise | Undetected | Low
Taping : Adverse events | | | | | | | Insufficient