# Excluded Studies

## Studies in an Included Systematic Review Not Directly Used in the Current Review

Akbari A, Khorashadizadeh S, Abdi G. The effect of motor control exercise versus general exercise on lumbar local stabilizing muscles thickness: Randomized controlled trial of patients with chronic low back pain. J Back Musculoskeletal Rehabil. 2008;21(2):105-12.
Alaranta H, Rytokoski U, Rissanen A, et al. Intensive physical and psychosocial training program for patients with chronic low back pain. A controlled clinical trial. Spine (Phila Pa 1976). 1994;19(12):1339-49. [pmid: 8066514].
Alcoff J, Jones E, Rust P, et al. Controlled trial of imipramine for chronic low back pain. J Fam Pract. 1982;14(5):841-6. [pmid: 6210751].
Alexandre NM, de Moraes MA, Correa Filho HR, et al. Evaluation of a program to reduce back pain in nursing personnel. Rev Saude Publica. 2001;35(4):356-61. [pmid: 11600924].
Altmaier EM, Lehmann TR, Russell DW, et al. The effectiveness of psychological interventions for the rehabilitation of low back pain: a randomized controlled trial evaluation. Pain. 1992;49(3):329-35. [pmid: 1408299].
Amlie E, Weber H, Holme I. Treatment of acute low-back pain with piroxicam: results of a double-blind placebo-controlled trial. Spine (Phila Pa 1976). 1987;12(5):473-6. [pmid: 2957801].
Anema JR, Steenstra IA, Bongers PM, et al. Multidisciplinary rehabilitation for subacute low back pain: graded activity or workplace intervention or both? A randomized controlled trial. Spine (Phila Pa 1976). 2007;32(3):291-8. discussion 9-300. [pmid: 17268258].
Ansari NN, Ebadi S, Talebian S, et al. A randomized, single blind placebo controlled clinical trial on the effect of continuous ultrasound on low back pain. Electromyogr Clin Neurophysiol. 2006;46(6):329-36. [pmid: 17147074].
Araki S, Kawamura O, Mataka T. Randomized controlled trial comparing the effect of manual acupuncture with sham acupuncture for acute low back pain. [in Japanese]. J Japan Soc Acupunct Moxibustion. 2001;2001(51):382.
Arbus L, Fajadet B, Aubert D, et al. Activity of tetrazepam (Myolastan®)* * Myolastan® - tetrazepam; Sanofi Recherche, Toulouse, France. in low back pain. A double-blind trial v. placebo. Clinical Trials Journal. 1990;27(4):258-67.
Assendelft WJ, Morton SC, Yu EI, et al. Spinal manipulative therapy for low back pain. A meta-analysis of effectiveness relative to other therapies. Ann Intern Med. 2003;138(11):871-81. [pmid: 12779297].
Assendelft WJJ, Morton SC, Yu EI, et al. Spinal manipulative therapy for low-back pain. Cochrane Database Syst Rev. 2004;(1). [pmid: 14973958].
Atkinson JH, Slater MA, Capparelli EV, et al. Efficacy of noradrenergic and serotonergic antidepressants in chronic back pain: a preliminary concentration-controlled trial. J Clin Psychopharmacol. 2007;27(2):135-42. [pmid: 17414235].
Atkinson JH, Slater MA, Wahlgren DR, et al. Effects of noradrenergic and serotonergic antidepressants on chronic low back pain intensity. Pain. 1999;83(2):137-45. [pmid: 10534584].
Atkinson JH, Slater MA, Williams RA, et al. A placebo-controlled randomized clinical trial of nortriptyline for chronic low back pain. Pain. 1998;76(3):287-96. [pmid: 9718247].
Aure OF, Nilsen JH, Vasseljen O. Manual therapy and exercise therapy in patients with chronic low back pain: a randomized, controlled trial with 1-year follow-up. Spine (Phila Pa 1976). 2003;28(6):525-31. discussion 31-2. [pmid: 12642755].
Avery S, O'Driscoll M-L. Randomised Controlled Trials on the Efficacy Of Spinal Manipulation Therapy in The Treatment of Low Back Pain. Phys Ther Rev. 2004;9(3):146-52. [pmid: 15179309].
Babej-Dolle R, Freytag S, Eckmeyer J, et al. Parenteral dipyrone versus diclofenac and placebo in patients with acute lumbago or sciatic pain: randomized observer-blind multicenter study. Int J Clin Pharmacol Ther. 1994;32(4):204-9. [pmid: 8032581].
Baptista R, Brizzi J, Josef H, et al. Terepeutica da lombalgia com a tizanidina. Folha Medica. 1988.
Baratta RR. A double-blind comparative study of carisoprodol, propoxyphene, and placebo in the management of low back syndrome. Curr Ther Res Clin Exp. 1976;20(3):233-40. [pmid: 134877].
Basford JR, Sheffield CG, Harmsen WS. Laser therapy: a randomized, controlled trial of the effects of low-intensity Nd:YAG laser irradiation on musculoskeletal back pain. Arch Phys Med Rehabil. 1999;80(6):647-52. [pmid: 10378490].
Basmajian JV. Cyclobenzaprine hydrochloride effect on skeletal muscle spasm in the lumbar region and neck: two double-blind controlled clinical and laboratory studies. Arch Phys Med Rehabil. 1978;59(2):58-63. [pmid: 623512].
Basmajian JV. Acute back pain and spasm. A controlled multicenter trial of combined analgesic and antispasm agents. Spine (Phila Pa 1976). 1989;14(4):438-9. [pmid: 2524114].
Beaulieu AD, Peloso P, Bensen W, et al. A randomized, double-blind, 8-week crossover study of once-daily controlled-release tramadol versus immediate-release tramadol taken as needed for chronic noncancer pain. Clin Ther. 2007;29(1):49-60. [pmid: 17379046].
Bendix AF, Bendix T, Labriola M, et al. Functional restoration for chronic low back pain. Two-year follow-up of two randomized clinical trials. Spine (Phila Pa 1976). 1998;23(6):717-25. [pmid: 9549794].
Bendix AF, Bendix T, Lund C, et al. Comparison of three intensive programs for chronic low back pain patients: a prospective, randomized, observer-blinded study with one-year follow-up. Scand J Rehabil Med. 1997;29(2):81-9. [pmid: 9198257].
Bendix AF, Bendix T, Ostenfeld S, et al. Active treatment programs for patients with chronic low back pain: a prospective, randomized, observer-blinded study. Eur Spine J. 1995;4(3):148-52. [pmid: 7552649].
Bendix AF, Bendix T, Vaegter K, et al. Multidisciplinary intensive treatment for chronic low back pain: a randomized, prospective study. Cleve Clin J Med. 1996;63(1):62-9. [pmid: 8590519].
Bendix T, Bendix A, Labriola M, et al. Functional restoration versus outpatient physical training in chronic low back pain: a randomized comparative study. Spine (Phila Pa 1976). 2000;25(19):2494-500. [pmid: 11013502].
Bentsen H, Lindgarde F, Manthorpe R. The effect of dynamic strength back exercise and/or a home training program in 57-year-old women with chronic low back pain. Results of a prospective randomized study with a 3-year follow-up period. Spine (Phila Pa 1976). 1997;22(13):1494-500. [pmid: 9231969].
Bergquist-Ullman M, Larsson U. Acute low back pain in industry. A controlled prospective study with special reference to therapy and confounding factors. Acta Orthop Scand. 1977;(170):1-117. [pmid: 146394].
Berry H, Bloom B, Hamilton EB, et al. Naproxen sodium, diflunisal, and placebo in the treatment of chronic back pain. Ann Rheum Dis. 1982;41(2):129-32. [pmid: 6462116].
Berry H, Hutchinson D. Tizanidine and ibuprofen in acute low-back pain: results of a double-blind multicentre study in general practice. J Int Med Res. 1988;16(2):83-91. [pmid: 2967781].
Berry H, Hutchinson DR. A multicentre placebo-controlled study in general practice to evaluate the efficacy and safety of tizanidine in acute low-back pain. J Int Med Res. 1988;16:75-82. [pmid: 2967780].
Beurskens AJP, de Vet HCP, Koke AJPT, et al. Efficacy of traction for nonspecific low back pain: 12-week and 6-month results of a randomized clinical trial. Spine. 1997;22(23):2756-62. [pmid: 9431610].
Bianchi M. Evaluation of cyclobenzaprine for skeletal muscle spasm of local origin. Postgrad Med Comm. 1978:25-9.
Birbara CA, Puopolo AD, Munoz DR, et al. Treatment of chronic low back pain with etoricoxib, a new cyclo-oxygenase-2 selective inhibitor: improvement in pain and disability--a randomized, placebo-controlled, 3-month trial. J Pain. 2003;4(6):307-15. [pmid: 14622687].
Borenstein D, Lacks S, Wiesel S. Cyclobenzarpine and naproxen versus naproxen alone in the treatment of acute low back pain and muscle spasm. Clin Ther. 1990;12:125-31. [pmid: 2141299].
Borges J, Baptista AF, Santana N, et al. Pilates exercises improve low back pain and quality of life in patients with HTLV-1 virus: a randomized crossover clinical trial. J Bodyw Mov Ther. 2014;18(1):68-74. [pmid: 24411152].
Boyles WF, Glassmann JM, Soyka JP. Management of acute musculoskeletal conditions: Thoracolumbar strain or sprain. A double-blind evaluation comparing the efficacy and safety of carisoprodol with diazepam. Today's Therapeutic Trends. 1983;1(1):1-16.
Bragstad A, Bilkra G. Evaluation of a new skeletal muscle relaxant in the treatment of low back pain (a comparison of DS 103-282 wiht chlorzoxazone). Curr Ther Res. 1979;26(1):39-43.
Brennan GP, Fritz JM, Hunter SJ, et al. Identifying subgroups of patients with acute/subacute “nonspecific” low back pain: results of a randomized clinical trial. Spine (Phila Pa 1976). 2006;31(6):623-31. [pmid: 16540864].
Brinkhaus B, Witt CM, Jena S, et al. Acupuncture in patients with chronic low back pain: a randomized controlled trial. Arch Intern Med. 2006;166(4):450-7. [pmid: 16505266].
Bronfort G, Goldsmith CH, Nelson CF, et al. Trunk exercise combined with spinal manipulative or NSAID therapy for chronic low back pain: a randomized, observer-blinded clinical trial. J Manipulative Physiol Ther. 1996;19(9):570-82. [pmid: 8976475].
Bronfort G, Haas M, Evans RL, et al. Efficacy of spinal manipulation and mobilization for low back pain and neck pain: a systematic review and best evidence synthesis. Spine J. 2004;4(3):335-56. [pmid: 15125860].
Browder DA, Childs JD, Cleland JA, et al. Effectiveness of an extension-oriented treatment approach in a subgroup of subjects with low back pain: a randomized clinical trial. Phys Ther. 2007;87(12):1608-18. discussion 577-9. [pmid: 17895350].
Brown A, Angus A, Chen S, et al. Costs and outcomes of chiropractic treatment for low back pain. Ottowa, Canada. July. 2005.
Bush C, Ditto B, Feuerstein M. A controlled evaluation of paraspinal EMG biofeedback in the treatment of chronic low back pain. Health Psychol. 1985;4(4):307-21. [pmid: 2932330].
Buswell J. Low back pain: a comparison of two treatment programmes. N Z J Physiother. 1982;10:13-7.
Buynak R, Shapiro DY, Okamoto A, et al. Efficacy and safety of tapentadol extended release for the management of chronic low back pain: results of a prospective, randomized, double-blind, placebo- and active-controlled Phase III study. [Erratum appears in Expert Opin Pharmacother. 2010 Nov;11(16):2773]. Expert Opin Pharmacother. 2010;11(11):1787-804. [pmid: 20578811].
Cairns MC, Foster NE, Wright C. Randomized controlled trial of specific spinal stabilization exercises and conventional physiotherapy for recurrent low back pain. Spine (Phila Pa 1976). 2006;31(19):E670-81. [pmid: 16946640].
Carlsson CP, Sjolund BH. Acupuncture for chronic low back pain: a randomized placebo-controlled study with long-term follow-up. Clin J Pain. 2001;17(4):296-305. [pmid: 11783809].
Casale R. Acute low back pain: symptomatic treatment with a muscle relaxing drug. Clin J Pain. 1988;4:81-8.
Chatchawan U, Thinkhamrop B, Kharmwan S, et al. Effectiveness of traditional Thai massage versus Swedish massage among patients with back pain associated with myofascial trigger points. J Bodywork Mov Ther. 2005;9(4):298-309.
Chatzitheodorou D, Kabitsis C, Malliou P, et al. A pilot study of the effects of high-intensity aerobic exercise versus passive interventions on pain, disability, psychological strain, and serum cortisol concentrations in people with chronic low back pain. Phys Ther. 2007;87(3):304-12. [pmid: 17284546].
Cheing GL, Hui-Chan CW. Transcutaneous electrical nerve stimulation: nonparallel antinociceptive effects on chronic clinical pain and acute experimental pain. Arch Phys Med Rehabil. 1999;80(3):305-12. [pmid: 10084439].
Chen Y. Clinical observation of electroacupuncture at SI3 in addition to drug therapy in acute lumbar sprain. [in Chinese]. J Community Med. 2010;(8):39.
Cherkin DC, Deyo RA, Battie M, et al. A comparison of physical therapy, chiropractic manipulation, and provision of an educational booklet for the treatment of patients with low back pain. N Engl J Med. 1998;339(15):1021-9. [pmid: 9761803].
Cherkin DC, Eisenberg D, Sherman KJ, et al. Randomized trial comparing traditional Chinese medical acupuncture, therapeutic massage, and self-care education for chronic low back pain. Arch Intern Med. 2001;161(8):1081-8. [pmid: 11322842].
Cherkin DC, Sherman KJ, Avins AL, et al. A randomized trial comparing acupuncture, simulated acupuncture, and usual care for chronic low back pain. Arch Intern Med. 2009;169(9):858-66. [pmid: 19433697].
Cherkin DC, Sherman KJ, Deyo RA, et al. A review of the evidence for the effectiveness, safety, and cost of acupuncture, massage therapy, and spinal manipulation for back pain. Ann Intern Med. 2003;138(11):898-906. [pmid: 12779300].
Childs JD, Fritz JM, Flynn TW, et al. A clinical prediction rule to identify patients with low back pain most likely to benefit from spinal manipulation: a validation study. Ann Intern Med. 2004;141(12):920-8. [pmid: 15611489].
Chok B, Lee R, Latimer J, et al. Endurance training of the trunk extensor muscles in people with subacute low back pain. Phys Ther. 1999;79(11):1032-42. [pmid: 10534796].
Chown M, Whittamore L, Rush M, et al. A prospective study of patients with chronic back pain randomised to group exercise, physiotherapy or osteopathy. Physiotherapy. 2008;94(1):21-8.
Chrubasik S, Model A, Black A, et al. A randomized double-blind pilot study comparing Doloteffin and Vioxx in the treatment of low back pain. Rheumatology (Oxford). 2003;42(1):141-8. [pmid: 12509627].
Chu LF, D'Arcy N, Brady C, et al. Analgesic tolerance without demonstrable opioid-induced hyperalgesia: a double-blinded, randomized, placebo-controlled trial of sustained-release morphine for treatment of chronic nonradicular low-back pain. Pain. 2012;153(8):1583-92. [pmid: 22704854].
Chung JW, Zeng Y, Wong TK. Drug therapy for the treatment of chronic nonspecific low back pain: systematic review and meta-analysis. Pain physician. 2013;16(6):E685-704. [pmid: 24284847].
Clare HA, Adams R, Maher CG. A systematic review of efficacy of McKenzie therapy for spinal pain. Aust J Physiother. 2004;50(4):209-16. [pmid: 15574109].
Clarke JA, van Tulder MW, Blomberg SEI, et al. Traction for low-back pain with or without sciatica. Cochrane Database Syst Rev. 2007;(2). CD003010. [pmid: 17443521].
Cleland JA, Fritz JM, Kulig K, et al. Comparison of the effectiveness of three manual physical therapy techniques in a subgroup of patients with low back pain who satisfy a clinical prediction rule: a randomized clinical trial. Spine. 2009;34(25):2720-9. [pmid: 19940729].
Coan RM, Wong G, Ku SL, et al. The acupuncture treatment of low back pain: a randomized controlled study. Am J Chin Med. 1980;8(1-2):181-9. [pmid: 6446852].
Coats TL, Borenstein DG, Nangia NK, et al. Effects of valdecoxib in the treatment of chronic low back pain: results of a randomized, placebo-controlled trial. Clin Ther. 2004;26(8):1249-60. [pmid: 15476906].
Colberg K, Hettich M, Sigmund R, et al. The efficacy and tolerability of an 8-day administration of intravenous and oral meloxicam: a comparison with intramuscular and oral diclofenac in patients with acute lumbago. German Meloxicam Ampoule Study Group. Curr Med Res Opin. 1996;13(7):363-77. [pmid: 8862936].
Corts Giner JR. Estudio DS 103-282: relajante muscular en lumbalgia aguda o lumbao (estudio doble ciego de tizanidina + paracetamol vs. placebo + paracetamol. Rev Esp de Cir Ost. 1989:119-24.
Costa LOP, Maher CG, Latimer J, et al. Motor control exercise for chronic low back pain: a randomized placebo-controlled trial. Phys Ther. 2009;89(12):1275-86. [pmid: 19892856].
Coxhead CE, Inskip H, Meade TW, et al. Multi-centre trial of physiotherapy in the management of sciatic symptoms. Lancet. 1981;1(8229):1065-8. [pmid: 6112444].
Cramer GD, Humphreys CR, Hondras MA, et al. The Hmax/Mmax ratio as an outcome measure for acute low back pain. J Manipulative Physiol Ther. 1993;16(1):7-13. [pmid: 8423429].
Critchley DJ, Ratcliffe J, Noonan S, et al. Effectiveness and cost-effectiveness of three types of physiotherapy used to reduce chronic low back pain disability: a pragmatic randomized trial with economic evaluation. Spine. 2007;32(14):1474-81. [pmid: 17572614].
da Fonseca JL, Magini M, de Freitas TH. Laboratory gait analysis in patients with low back pain before and after a pilates intervention. J Sport Rehabil. 2009;18(2):269-82. [pmid: 19561369].
Dalichau S, Scheele K. Auswirkungen elastischer lumbalstutzgurte auf den effect eines muskeltrainingsprogrammes fur patienten mit chronischen ruckenschmerzen. Z Orthop. 2000;138:8-16. [pmid: 10730357].
Dapas F, Hartman SF, Martinez L, et al. Baclofen for the treatment of acute low-back syndrome. A double-blind comparison with placebo. Spine. 1985;10(4):345-9. [pmid: 2931831].
Davies JE, Gibson T, Tester L. The value of exercises in the treatment of low back pain. Rheumatol Rehabil. 1979;18(4):243-7. [pmid: 160072].
Delitto A, Cibulka MT, Erhard RE, et al. Evidence for use of an extension-mobilization category in acute low back syndrome: a prescriptive validation pilot study. Phys Ther. 1993;73(4):216-22. discussion 23-8. [pmid: 8456141].
Descarreaux M, Normand MC, Laurencelle L, et al. Evaluation of a specific home exercise program for low back pain. J Manipulative Physiol Ther. 2002;25(8):497-503. [pmid: 12381971].
Deyo RA, Walsh NE, Martin DC, et al. A controlled trial of transcutaneous electrical nerve stimulation (TENS) and exercise for chronic low back pain. N Engl J Med. 1990;322:1627-34. [pmid: 2140432].
Dickens C, Jayson M, Sutton C, et al. The relationship between pain and depression in a trial using paroxetine in sufferers of chronic low back pain. Psychosomatics. 2000;41(6):490-9. [pmid: 11110112].
Donaldson S, Romney D, Donaldson M, et al. Randomized study of the application of single motor unit biofeedback training to chronic low back pain. J Occup Rehabil. 1994;4(1):23-37. [pmid: 24234261].
Donzelli S, Di Domenica E, Cova AM, et al. Two different techniques in the rehabilitation treatment of low back pain: a randomized controlled trial. Eura Medicophys. 2006;42(3):205-10. [pmid: 17039216].
Doran DM, Newell DJ. Manipulation in treatment of low back pain: a multicentre study. Br Med J. 1975;2(5964):161-4. [pmid: 123815].
Dreiser RL, Le Parc JM, Velicitat P, et al. Oral meloxicam is effective in acute sciatica: two randomised, double-blind trials versus placebo or diclofenac. Inflamm Res. Suppl 1. 2001;50:S17-23. [pmid: 11339516].
Dreiser RL, Marty M, Ionescu E, et al. Relief of acute low back pain with diclofenac-K 12.5 mg tablets: a flexible dose, ibuprofen 200 mg and placebo-controlled clinical trial. Int J Clin Pharmacol Ther. 2003;41(9):375-85. [pmid: 14518597].
Durmu D, Akyol Y, Cengiz K, et al. Effects of therapeutic ultrasound on pain, disability, walking performance, quality of life, and depression in patients with chronic low back pain: A randomized, placebo controlled trial. Turk J Rheumatol. 2010;25(2):82-7.
Durmus D, Alayli G, Goktepe AS, et al. Is phonophoresis effective in the treatment of chronic low back pain? A single-blind randomized controlled trial. Rheumatol Int. 2013;33(7):1737-44. [pmid: 23283539].
Durmus D, Durmaz Y, Canturk F. Effects of therapeutic ultrasound and electrical stimulation program on pain, trunk muscle strength, disability, walking performance, quality of life, and depression in patients with low back pain: a randomized-controlled trial. Rheumatol Int. 2010;30(7):901-10. [pmid: 19644691].
Ebadi S, Ansari NN, Naghdi S, et al. The effect of continuous ultrasound on chronic non-specific low back pain: a single blind placebo-controlled randomized trial. BMC Musculoskelet Disord. 2012;13:192. [pmid: 23031570].
Elnaggar IM, Nordin M, Sheikhzadeh A, et al. Effects of spinal flexion and extension exercises on low-back pain and spinal mobility in chronic mechanical low-back pain patients. Spine (Phila Pa 1976). 1991;16(8):967-72. [pmid: 1835157].
Ernst E, Canter PH. Chiropractic Spinal Manipulation Treatment for Back Pain? A Systematic Review of Randomised Clinical Trials. Phys Ther Rev. 2003;8(2):85. [pmid: 11029157].
Evans C. A randomized controlled trial of flexion exercises, education, and bed rest for patients with acute low back pain. Physiother Can. 1987;39(2):96-101. [pmid: 2931153].
Evans DP, Burke MS, Lloyd KN, et al. Lumbar spinal manipulation on trial. Part I--clinical assessment. Rheumatol Rehabil. 1978;17(1):46-53. [pmid: 153574].
Evans DP, Burke MS, Newcombe RG. Medicines of choice in low back pain. Curr Med Res Opin. 1980;6(8):540-7. [pmid: 6446445].
Faas A, Chavannes AW, van Eijk JT, et al. A randomized, placebo-controlled trial of exercise therapy in patients with acute low back pain. Spine (Phila Pa 1976). 1993;18(11):1388-95. [pmid: 8235809].
Faas A, van Eijk JT, Chavannes AW, et al. A randomized trial of exercise therapy in patients with acute low back pain. Efficacy on sickness absence. Spine (Phila Pa 1976). 1995;20(8):941-7. [pmid: 7644960].
Famaey JP, Bruhwyler J, Geczy J, et al. Open controlled randomized multicenter comparison of nimesulide and diclofenac in the treatment of subacute and chronic low back pain. J Clin Res. 1998;1(219-238):219-38.
Farasyn A, Meeusen R, Nijs J. A pilot randomized placebo-controlled trial of roptrotherapy in patients with subacute non-specific low back pain. J Back Musculoskeletal Rehabil. 2006;19(4):111-7.
Farrell JP, Twomey LT. Acute low back pain. Comparison of two conservative treatment approaches. Med J Aust. 1982;1(4):160-4. [pmid: 6210835].
Ferreira ML, Ferreira PH, Latimer J, et al. Does spinal manipulative therapy help people with chronic low back pain?. Aust J Physiother. 2002;48(4):277-84. [pmid: 12443522].
Ferreira ML, Ferreira PH, Latimer J, et al. Efficacy of spinal manipulative therapy for low back pain of less than three months' duration. J Manipulative Physiol Ther. 2003;26(9):593-601. [pmid: 14673408].
Ferreira ML, Ferreira PH, Latimer J, et al. Comparison of general exercise, motor control exercise and spinal manipulative therapy for chronic low back pain: A randomized trial. Pain. 2007;131(1-2):31-7. [pmid: 17250965].
Field T, Hernandez-Reif M, Diego M, et al. Lower back pain and sleep disturbance are reduced following massage therapy. J Bodywork Mov Ther. 2007;11(2):141-5.
Finckh A, Zufferey P, Schurch MA, et al. Short-term efficacy of intravenous pulse glucocorticoids in acute discogenic sciatica. A randomized controlled trial. Spine (Phila Pa 1976). 2006;31(4):377-81. [pmid: 16481946].
Franca FR, Burke TN, Hanada ES, et al. Segmental stabilization and muscular strengthening in chronic low back pain: a comparative study. Clinics. 2010;65(10):1013-7. [pmid: 21120303].
Franke A, Gebauer S, Franke K, et al. Acupuncture massage vs Swedish massage and individual exercise vs group exercise in low back pain sufferers--a randomized controlled clinical trial in a 2 × 2 factorial design. Forsch Komplementarmed Klass Naturheilkd. 2000;7(6):286-93. [pmid: 11155022].
Friedman BW, Holden L, Esses D, et al. Parenteral corticosteroids for Emergency Department patients with non-radicular low back pain. J Emerg Med. 2006;31(4):365-70. [pmid: 17046475].
Friedrich M, Gittler G, Halberstadt Y, et al. Combined exercise and motivation program: effect on the compliance and level of disability of patients with chronic low back pain: a randomized controlled trial. Arch Phys Med Rehabil. 1998;79(5):475-87. [pmid: 9596385].
Fritz JM, Lindsay W, Matheson JW, et al. Is there a subgroup of patients with low back pain likely to benefit from mechanical traction? Results of a randomized clinical trial and subgrouping analysis. Spine. 2007;32(26):E793-800. [pmid: 18091473].
Frost H, Klaber Moffett JA, Moser JS, et al. Randomised controlled trial for evaluation of fitness programme for patients with chronic low back pain. BMJ. 1995;310(6973):151-4. [pmid: 7833752].
Frost H, Lamb SE, Doll HA, et al. Randomised controlled trial of physiotherapy compared with advice for low back pain. BMJ. 2004;329(7468):708. [pmid: 15377573].
Frost H, Lamb SE, Klaber Moffett JA, et al. A fitness programme for patients with chronic low back pain: 2-year follow-up of a randomised controlled trial. Pain. 1998;75(2-3):273-9. [pmid: 9583763].
Furlan AD, Brosseau L, Imamura M, et al. Massage for low-back pain Cochrane Database Syst Rev. 2002;(2). Art. No.: CD001929. [pmid: 12076429].
Furlan AD, Brosseau L, Imamura M, et al. Massage for low-back pain: a systematic review within the framework of the Cochrane Collaboration Back Review Group. Spine (Phila Pa 1976). 2002;27(17):1896-910. [pmid: 12221356].
Furlan AD, van Tulder MW, Cherkin DC, et al. Acupuncture and dry-needling for low back pain. Cochrane Database Syst Rev. 2005;(1). CD001351. [pmid: 15674876].
Gagnon L. Efficacy of pilates exercises as therapeutic intervention in treating patients with low back pain [dissertation] [dissertation]. Knoxville. University of Tennessee. 2005.
Galantino ML, Bzdewka TM, Eissler-Russo JL, et al. The impact of modified Hatha yoga on chronic low back pain: a pilot study. Altern Ther Health Med. 2004;10(2):56-9. [pmid: 15055095].
Gao H, Wei C. Extrapoint acupuncture treatement of 36 cases of acute lumbar sprain. [in Chinese]. J Gansu Coll Trad Cin Med. 2006;2006(23):49-50.
Gay RE, Bronfort G, Evans RL. Distraction manipulation of the lumbar spine: a review of the literature. J Manipulative Physiol Ther. 2005;28(4):266-73. [pmid: 15883580].
Geisser ME, Wiggert EA, Haig AJ, et al. A randomized, controlled trial of manual therapy and specific adjuvant exercise for chronic low back pain. Clin J Pain. 2005;21(6):463-70. [pmid: 16215330].
Ghoname EA, Craig WF, White PF, et al. Percutaneous electrical nerve stimulation for low back pain: a randomized crossover study. Jama. 1999;281(9):818-23. [pmid: 10071003].
Ghoname EA, White PF, Ahmed HE, et al. Percutaneous electrical nerve stimulation: an alternative to TENS in the management of sciatica. Pain. 1999;83(2):193-9. [pmid: 10534590].
Ghroubi S, Elleuch H, Baklouti S, et al. Chronic low back pain and vertebral manipulation. Ann Readapt Med Phys. 2007;50(7):570-6. [pmid: 17382426].
Gibson JNA, Ahmed M. The effectiveness of flexible an dridig supports in patients with lumbar backache. J Orthop Med. 2002;24:86-9.
Gibson T, Grahame R, Harkness J, et al. Controlled comparison of short-wave diathermy treatment with osteopathic treatment in non-specific low back pain. Lancet. 1985;1(8440):1258-61. [pmid: 2860453].
Giles LG, Muller R. Chronic spinal pain: a randomized clinical trial comparing medication, acupuncture, and spinal manipulation. Spine (Phila Pa 1976). 2003;28(14):1490-502. discussion 502-3. [pmid: 12865832].
Gladwell V, Head S, Haggar M, et al. Does a Program of Pilates Improve Chronic Non-Specific Low Back Pain?. J Sport Rehabil. 2006;15(4):338-50. [pmid: 23128349].
Glomsrod B, Lonn JH, Soukup MG, et al. “Active back school”, prophylactic management for low back pain: three-year follow-up of a randomized, controlled trial. J Rehabil Med. 2001;33(1):26-30. [pmid: 11480466].
Glover JR, Morris JG, Khosla T. Back pain: a randomized clinical trial of rotational manipulation of the trunk. Br J Ind Med. 1974;31(1):59-64. [pmid: 4274488].
Gold R. Orphenadrine Citrate: Sedative or Muscle Relaxant?. Clin Ther. 1978;1(6):451-3.
Goldby LJ, Moore AP, Doust J, et al. A randomized controlled trial investigating the efficiency of musculoskeletal physiotherapy on chronic low back disorder. Spine (Phila Pa 1976). 2006;31(10):1083-93. [pmid: 16648741].
Goldie I. A clinical trial with indomethacin (indomee(R)) in low back pain and sciatica. Acta Orthop Scand. 1968;39(1):117-28. [pmid: 4239771].
Goodkin K, Gullion CM, Agras WS. A randomized, double-blind, placebo-controlled trial of trazodone hydrochloride in chronic low back pain syndrome. Journal of Clinical Psychopharmacology. 1990;10(4):269-78. [pmid: 2149565].
Gordon A, Callaghan D, Spink D, et al. Buprenorphine transdermal system in adults with chronic low back pain: a randomized, double-blind, placebo-controlled crossover study, followed by an open-label extension phase. Clin Ther. 2010;32(5):844-60. [pmid: 20685494].
Gostick N, Allen J, Cranfield R, et al. A comparison of the efficacy and adverse effects of controlled-release dihydrocodeine and immediate-release dihydrocodeine in the treatment of pain in osteoarthritis and chronic back pain. Paper presented at: Proceedings of The Edinburgh Symposium on Pain Control and Medical Education. 1989.
Grubisic F, Grazio S, Jajic Z, et al. Therapeutic ultrasound in chronic low back pain treatment. Reumatizam. 2006;53(1):18-21. [pmid: 17580544].
Gudavalli MR, Cambron JA, McGregor M, et al. A randomized clinical trial and subgroup analysis to compare flexion-distraction with active exercise for chronic low back pain. Eur Spine J. 2006;15(7):1070-82. [pmid: 16341712].
Gur A, Karakoc M, Cevik R, et al. Efficacy of low power laser therapy and exercise on pain and functions in chronic low back pain. Lasers Surg Med. 2003;32(3):233-8. [pmid: 12605431].
Guzman J, Esmail R, Karjalainen K, et al. Multidisciplinary bio-psycho-social rehabilitation for chronic low back pain. Cochrane Database Syst Rev. 2002;(1). CD000963. [pmid: 11869581].
Guzman J, Esmail R, Karjalainen KA, et al. Multidisciplinary rehabilitation for chronic low-back pain: systematic review. BMJ. 2001;322. [pmid: 11420271].
Haake M, Muller H-H, Schade-Brittinger C, et al. German Acupuncture Trials (GERAC) for chronic low back pain: randomized, multicenter, blinded, parallel-group trial with 3 groups. [Erratum appears in Arch Intern Med. 2007 Oct 22;167(19):2072]. Arch Intern Med. 2007;167(17):1892-8. [pmid: 17893311].
Hackett GI, Seddon D, Kaminski D. Electroacupuncture compared with paracetamol for acute low back pain. Practitioner. 1988;232(1443):163-4. [pmid: 2973008].
Hadler NM, Curtis P, Gillings DB, et al. A benefit of spinal manipulation as adjunctive therapy for acute low-back pain: a stratified controlled trial. Spine (Phila Pa 1976). 1987;12(7):702-6. [pmid: 2961085].
Hagen EM, Eriksen HR, Ursin H. Does early intervention with a light mobilization program reduce long-term sick leave for low back pain?. Spine (Phila Pa 1976). 2000;25(15):1973-6. [pmid: 10908942].
Haimovic IC, Beresford HR. Dexamethasone is not superior to placebo for treating lumbosacral radicular pain. Neurology. 1986;36(12):1593-4. [pmid: 2946981].
Hale M, Khan A, Kutch M, et al. Once-daily OROS hydromorphone ER compared with placebo in opioid-tolerant patients with chronic low back pain. [Erratum appears in Curr Med Res Opin. 2010 Aug;26(8):1904]. Curr Med Res Opin. 2010;26(6):1505-18. [pmid: 20429852].
Hale M, Speight K, Harsanyi Z, et al. Efficacy of 12 hourly controlled-release codeine compared with as required dosing of acetaminophen plus codeine in patients with chronic low back pain. Pain Res Manage. 1997;2(1):33-8.
Hale ME, Ahdieh H, Ma T, et al. Efficacy and safety of OPANA ER (oxymorphone extended release) for relief of moderate to severe chronic low back pain in opioid-experienced patients: a 12-week, randomized, double-blind, placebo-controlled study. J Pain. 2007;8(2):175-84. [pmid: 17145204].
Hale ME, Dvergsten C, Gimbel J. Efficacy and safety of oxymorphone extended release in chronic low back pain: results of a randomized, double-blind, placebo- and active-controlled phase III study. J Pain. 2005;6(1):21-8. [pmid: 15629415].
Hall AM, Maher CG, Latimer J, et al. A randomized controlled trial of tai chi for long-term low back pain (TAI CHI): study rationale, design, and methods. BMC Musculoskelet Disord. 2009;10:55. [pmid: 19473546].
Hallegraeff JM, de Greef M, Winters JC, et al. Manipulative therapy and clinical prediction criteria in treatment of acute nonspecific low back pain. [Erratum appears in Percept Mot Skills. 2009 Jun;108(3):981 Note: Hallegraeff, H J M [corrected to Hallegraeff, J M]]. Percept Mot Skills. 2009;108(1):196-208. [pmid: 19425461].
Hancock MJ, Maher CG, Latimer J, et al. Assessment of diclofenac or spinal manipulative therapy, or both, in addition to recommended first-line treatment for acute low back pain: a randomised controlled trial. Lancet. 2007;370(9599):1638-43. [pmid: 17993364].
Hansen FR, Bendix T, Skov P, et al. Intensive, dynamic back-muscle exercises, conventional physiotherapy, or placebo-control treatment of low-back pain. A randomized, observer-blind trial. Spine (Phila Pa 1976). 1993;18(1):98-108. [pmid: 8434332].
Harkapaa K, Jarvikoski A, Mellin G, et al. A controlled study on the outcome of inpatient and outpatient treatment of low back pain. Part I. Pain, disability, compliance, and reported treatment benefits three months after treatment. Scand J Rehabil Med. 1989;21(2):81-9. [pmid: 2526364].
Hayden JA, van Tulder MW, Malmivaara A, et al. Exercise therapy for treatment of non-specific low back pain. Cochrane Database Syst Rev. 2005;(3). [pmid: 16034851].
Hayden JA, van Tulder MW, Malmivaara AV, et al. Meta-analysis: exercise therapy for nonspecific low back pain. Ann Intern Med. 2005;142(9):765-75. [pmid: 15867409].
Hayden JA, van Tulder MW, Tomlinson G. Systematic Review: Strategies for Using Exercise Therapy To Improve Outcomes in Chronic Low Back Pain. Ann Intern Med. 2005;142(9):776-85. [pmid: 15867410].
Hemmila HM, Keinanen-Kiukaanniemi SM, Levoska S, et al. Does folk medicine work? A randomized clinical trial on patients with prolonged back pain. Arch Phys Med Rehabil. 1997;78(6):571-7. [pmid: 9196462].
Hemmila HM, Keinanen-Kiukaanniemi SM, Levoska S, et al. Long-term effectiveness of bone-setting, light exercise therapy, and physiotherapy for prolonged back pain: a randomized controlled trial. J Manipulative Physiol Ther. 2002;25(2):99-104. [pmid: 11896377].
Henchoz Y, de Goumoens P, So AKL, et al. Functional multidisciplinary rehabilitation versus outpatient physiotherapy for non specific low back pain: randomized controlled trial. Swiss Med Wkly. 2010;140:w13133. [pmid: 21181567].
Hennies OL. A new skeletal muscle relaxant (DS 103-282) compared to diazepam in the treatment of muscle spasm of local origin. J Int Med Res. 1981;9(1):62-8. [pmid: 6451461].
Hernandez-Reif M, Field T, Krasnegor J, et al. Lower back pain is reduced and range of motion increased after massage therapy. Int J Neurosci. 2001;106(3-4):131-45. [pmid: 11264915].
Hickey RF. Chronic low back pain: a comparison of diflunisal with paracetamol. N Z Med J. 1982;95(707):312-4. [pmid: 6212783].
Hides JA, Jull GA, Richardson CA. Long-term effects of specific stabilizing exercises for first-episode low back pain. Spine (Phila Pa 1976). 2001;26(11):E243-8. [pmid: 11389408].
Hides JA, Richardson CA, Jull GA. Multifidus muscle recovery is not automatic after resolution of acute, first-episode low back pain. Spine (Phila Pa 1976). 1996;21(23):2763-9. [pmid: 8979323].
Hildebrandt VH, Proper KI, van den Berg R, et al. Cesar therapy is temporarily more effective in patients with chronic low back pain than the standard treatment by family practitioner: randomized, controlled and blinded clinical trial with 1 year follow-up. Ned Tijdschr Geneeskd. 2000;144(47):2258-64. [pmid: 11109471].
Hindle TH 3rd. Comparison of carisoprodol, butabarbital, and placebo in treatment of the low back syndrome. Calif Med. 1972;117(2):7-11. [pmid: 4262210].
Hingorani K. Diazepam in backache. A double-blind controlled trial. Ann Phys Med. 1966;8(8):303-6. [pmid: 4224750].
Hingorani K. Orphenadine/Paracetamol in backache: a double-blind controlled trial. Br J Clin Pract. 1971;25:227-31. [pmid: 4253016].
Hlobil H, Staal JB, Twisk J, et al. The effects of a graded activity intervention for low back pain in occupational health on sick leave, functional status and pain: 12-month results of a randomized controlled trial. J Occup Rehabil. 2005;15(4):569-80. [pmid: 16254756].
Hoehler FK, Tobis JS, Buerger AA. Spinal manipulation for low back pain. Jama. 1981;245(18):1835-8. [pmid: 6453240].
Hoffman BM, Papas RK, Chatkoff DK, et al. Meta-analysis of psychological interventions for chronic low back pain. Health Psychol. 2007;26(1):1-9. [pmid: 17209691].
Hoiriis KT, Pfleger B, McDuffie FC, et al. A randomized clinical trial comparing chiropractic adjustments to muscle relaxants for subacute low back pain. J Manipulative Physiol Ther. 2004;27(6):388-98. [pmid: 15319761].
Hondras MA, Long CR, Cao Y, et al. A randomized controlled trial comparing 2 types of spinal manipulation and minimal conservative medical care for adults 55 years and older with subacute or chronic low back pain. J Manipulative Physiol Ther. 2009;32(5):330-43. [pmid: 19539115].
Hsieh CY, Adams AH, Tobis J, et al. Effectiveness of four conservative treatments for subacute low back pain: a randomized clinical trial. Spine (Phila Pa 1976). 2002;27(11):1142-8. [pmid: 12045509].
Hsieh CY, Phillips RB, Adams AH, et al. Functional outcomes of low back pain: Comparison of four treatment groups in a randomized controlled trial. J Manipulative Physiol Ther. 1992;15(1):4-9. [pmid: 1531488].
Hsieh LL, Kuo CH, Lee LH, et al. Treatment of low back pain by acupressure and physical therapy: randomised controlled trial. BMJ. 2006;332(7543):696-700. [pmid: 16488895].
Hsieh LL, Kuo CH, Yen MF, et al. A randomized controlled clinical trial for low back pain treated by acupressure and physical therapy. Prev Med. 2004;39(1):168-76. [pmid: 15207999].
Hurley DA, McDonough SM, Dempster M, et al. A randomized clinical trial of manipulative therapy and interferential therapy for acute low back pain. Spine (Phila Pa 1976). 2004;29(20):2207-16. [pmid: 15480130].
Hurley DA, Minder PM, McDonough SM, et al. Interferential therapy electrode placement technique in acute low back pain: a preliminary investigation. Arch Phys Med Rehabil. 2001;82(4):485-93. [pmid: 11295009].
Hurri H. The Swedish back school in chronic low back pain. Part I. Benefits. Scand J Rehabil Med. 1989;21(1):33-40. [pmid: 2523558].
Hurwitz EL, Morgenstern H, Harber P, et al. A randomized trial of medical care with and without physical therapy and chiropractic care with and without physical modalities for patients with low back pain: 6-month follow-up outcomes from the UCLA low back pain study. Spine (Phila Pa 1976). 2002;27(20):2193-204. [pmid: 12394892].
Inoue M, Hojo T, Nakajima M, et al. Comparison of the effectiveness of acupuncture treatment and local anaesthetic injection for low back pain: a randomised controlled clinical trial. Acupunct Med. 2009;27(4):174-7. [pmid: 19942724].
Inoue M, Kitakoji H, Ishizaki N, et al. Relief of low back pain immediately after acupuncture treatment--a randomised, placebo controlled trial. Acupunct Med. 2006;24(3):103-8. [pmid: 17013356].
Itoh K, Itoh S, Katsumi Y, et al. A pilot study on using acupuncture and transcutaneous electrical nerve stimulation to treat chronic non-specific low back pain. Complement Ther Clin Pract. 2009;15(1):22-5. [pmid: 19161950].
Itoh K, Katsumi Y, Hirota S, et al. Effects of trigger point acupuncture on chronic low back pain in elderly patients--a sham-controlled randomised trial. Acupunct Med. 2006;24(1):5-12. [pmid: 16618043].
Itoh K, Katsumi Y, Kitakoji H. Trigger point acupuncture treatment of chronic low back pain in elderly patients--a blinded RCT. Acupunct Med. 2004;22(4):170-7. [pmid: 15628774].
Jacobs JH, Grayson MF. Trial of an anti-inflammatory agent (indomethacin) in low back pain with and without radicular involvement. Br Med J. 1968;3(5611):158-60. [pmid: 4232743].
Jamison RN, Raymond SA, Slawsby EA, et al. Opioid therapy for chronic noncancer back pain. A randomized prospective study. Spine (Phila Pa 1976). 1998;23(23):2591-600. [pmid: 9854758].
Jarzem PF, Harvey EJ, Arcaro N, et al. Transcutaneous electrical nerve stimulation [TENS] for chronic low back pain. J Musculoskelet Pain. 2005;13(2):3-9.
Jarzem PF, Harvey EJ, Arcaro N, et al. Transcutaneous electrical nerve stimulation [TENS] for short-term treatment of low back pain - Randomized double blind crossover study of sham versus conventional TENS. J Musculoskelet Pain. 2005;13(2):11-7.
Jenkins DG, Ebbutt AF, Evans CD. Tofranil in the treatment of low back pain. J Int Med Res. 1976;4(2 Suppl):28-40. [pmid: 140827].
Jin M, Chen J. Acupuncture treatment for 40 cases of acute lumbar sprain. [in Chinese]. J Gansu Coll Trad Chin Med. 2008;2006(23):49-50.
Johannsen F, Remvig L, Kryger P, et al. Exercises for chronic low back pain: a clinical trial. J Orthop Sports Phys Ther. 1995;22(2):52-9. [pmid: 7581431].
Johnson RE, Jones GT, Wiles NJ, et al. Active exercise, education, and cognitive behavioral therapy for persistent disabling low back pain: a randomized controlled trial. Spine. 2007;32(15):1578-85. [pmid: 17621203].
Jousset N, Fanello S, Bontoux L, et al. Effects of functional restoration versus 3 hours per week physical therapy: a randomized controlled study. Spine (Phila Pa 1976). 2004;29(5):487-93. discussion 94. [pmid: 15129059].
Juni P, Battaglia M, Nuesch E, et al. A randomised controlled trial of spinal manipulative therapy in acute low back pain. Ann Rheum Dis. 2009;68(9):1420-7. [pmid: 18775942].
Kaapa EH, Frantsi K, Sarna S, et al. Multidisciplinary group rehabilitation versus individual physiotherapy for chronic nonspecific low back pain: a randomized trial. Spine (Phila Pa 1976). 2006;31(4):371-6. [pmid: 16481945].
Kalso E, Edwards JE, Moore RA, et al. Opioids in chronic non-cancer pain: systematic review of efficacy and safety. Pain. 2004;112(3):372-80. [pmid: 15561393].
Kankaanpaa M, Taimela S, Airaksinen O, et al. The efficacy of active rehabilitation in chronic low back pain. Effect on pain intensity, self-experienced disability, and lumbar fatigability. Spine (Phila Pa 1976). 1999;24(10):1034-42. [pmid: 10332798].
Karjalainen K, Malmivaara A, Pohjolainen T, et al. Mini-intervention for subacute low back pain: a randomized controlled trial. Spine (Phila Pa 1976). 2003;28(6):533-40. discussion 40-1. [pmid: 12642757].
Karjalainen KA, Malmivaara A, van Tulder MW, et al. Multidisciplinary biopsychosocial rehabilitation for subacute low-back pain among working age adults. Cochrane Database Syst Rev. 2009;(4).
Katz J, Pennella-Vaughan J, Hetzel RD, et al. A randomized, placebo-controlled trial of bupropion sustained release in chronic low back pain. J Pain. 2005;6(10):656-61. [pmid: 16202958].
Katz N, Ju WD, Krupa DA, et al. Efficacy and safety of rofecoxib in patients with chronic low back pain: results from two 4-week, randomized, placebo-controlled, parallel-group, double-blind trials. Spine (Phila Pa 1976). 2003;28(9):851-8. discussion 9. [pmid: 12941996].
Katz N, Rauck R, Ahdieh H, et al. A 12-week, randomized, placebo-controlled trial assessing the safety and efficacy of oxymorphone extended release for opioid-naive patients with chronic low back pain. Curr Med Res Opin. 2007;23(1):117-28. [pmid: 17257473].
Kendall P, Jenkins J. Exercises for backache: a double-blind controlled trial. Physiotherapy. 1968;54:154-7.
Kennedy S, Baxter GD, Kerr DP, et al. Acupuncture for acute non-specific low back pain: a pilot randomised non-penetrating sham controlled trial. Complement Ther Med. 2008;16(3):139-46. [pmid: 18534326].
Kerr DP, Walsh DM, Baxter D. Acupuncture in the management of chronic low back pain: a blinded randomized controlled trial. Clin J Pain. 2003;19(6):364-70. [pmid: 14600536].
Khadilkar A, Milne A, Brosseau L, et al. Transcutaneous electrical nerve stimulation (TENS) for chronic low-back pain. Cochrane Database Syst Rev. 2005;(3). Art. No.: CD003008. [pmid: 16034883].
Khoromi S, Cui L, Nackers L, et al. Morphine, nortriptyline and their combination vs. placebo in patients with chronic lumbar root pain. Pain. 2007;130(1-2):66-75. [pmid: 17182183].
Khoromi S, Patsalides A, Parada S, et al. Topiramate in chronic lumbar radicular pain. J Pain. 2005;6(12):829-36. [pmid: 16326371].
Kittang G, Melvaer T, Baerheim A. Acupuncture contra antiphlogistics in acute lumbago. Tidsskr Nor Laegeforen. 2001;121(10):1207-10. [pmid: 11402745].
Klein RG, Eek BC. Low-energy laser treatment and exercise for chronic low back pain: double-blind controlled trial. Arch Phys Med Rehabil. 1990;71(1):34-7. [pmid: 2136991].
Klinger N, Wilson R, Kanniainen C, et al. Intravenous orphenadrine for the treatment of lumbar paravertebral muscle strain. Curr Ther Res. 1988;43(2):247-54.
Koes BW, Bouter LM, van Mameren H, et al. Randomised clinical trial of manipulative therapy and physiotherapy for persistent back and neck complaints: results of one year follow up. BMJ. 1992;304(6827):601-5. [pmid: 1532760].
Kole-Snijders AM, Vlaeyen JW, Goossens ME, et al. Chronic low-back pain: what does cognitive coping skills training add to operant behavioral treatment? Results of a randomized clinical trial. J Consult Clin Psychol. 1999;67(6):931-44. [pmid: 10596514].
Konrad K, Tatrai T, Hunka A, et al. Controlled trial of balneotherapy in treatment of low back pain. Ann Rheum Dis. 1992;51(6):820-2. [pmid: 1535495].
Kool J, Bachmann S, Oesch P, et al. Function-centered rehabilitation increases work days in patients with nonacute nonspecific low back pain: 1-year results from a randomized controlled trial. Arch Phys Med Rehabil. 2007;88(9):1089-94. [pmid: 17826451].
Kool J, de Bie R, Oesch P, et al. Exercise reduces sick leave in patients with non-acute non-specific low back pain: a meta-analysis. J Rehabil Med. 2004;36(2):49-62. [pmid: 15180219].
Kool JP, Oesch PR, Bachmann S, et al. Increasing days at work using function-centered rehabilitation in nonacute nonspecific low back pain: a randomized controlled trial. Arch Phys Med Rehabil. 2005;86(5):857-64. [pmid: 15895328].
Koumantakis GA, Watson PJ, Oldham JA. Trunk muscle stabilization training plus general exercise versus general exercise only: randomized controlled trial of patients with recurrent low back pain. Phys Ther. 2005;85(3):209-25. [pmid: 15733046].
Kuijpers T, van Middelkoop M, Rubinstein SM, et al. A systematic review on the effectiveness of pharmacological interventions for chronic non-specific low-back pain. Eur Spine J. 2011;20(1):40-50. [pmid: 20680369].
Kumar S, Negi MPS, Sharma VP, et al. Efficacy of two multimodal treatments on physical strength of occupationally subgrouped male with low back pain. J Back Musculoskeletal Rehabil. 2009;22(3):179-88. [pmid: 20023348].
Kumar S, Sharma VP, Shukla R, et al. Comparative efficacy of two multimodal treatments on male and female sub-groups with low back pain (part II). J Back Musculoskeletal Rehabil. 2010;23(1):1-9. [pmid: 20231783].
Kuukkanen T, Malkia E, Kautiainen H, et al. Effectiveness of a home exercise programme in low back pain: a randomized five-year follow-up study. Physiother Res Int. 2007;12(4):213-24. [pmid: 17849435].
Kuukkanen TM, Malkia EA. An experimental controlled study on postural sway and therapeutic exercise in subjects with low back pain. Clin Rehabil. 2000;14(2):192-202. [pmid: 10763797].
Lacey PH, Dodd GD, Shannon DJ. A double blind, placebo controlled study of piroxicam in the management of acute musculoskeletal disorders. Eur J Rheumatol Inflamm. 1984;7(3):95-104. [pmid: 6443759].
Lambeek LC, van Mechelen W, Knol DL, et al. Randomised controlled trial of integrated care to reduce disability from chronic low back pain in working and private life. BMJ. 2010;340:c1035. [pmid: 20234040].
Lan J. Analysis of application of acupuncture analgesia in acute lumbar sprain. [in Chinese]. J Community Med. 2009;(7):68-9.
Landen BR. Heat or cold for the relief of low back pain?. Phys Ther. 1967;47(12):1126-8. [pmid: 4229712].
Leeuw M, Goossens MEJB, van Breukelen GJP, et al. Exposure in vivo versus operant graded activity in chronic low back pain patients: results of a randomized controlled trial. Pain. 2008;138(1):192-207. [pmid: 18242858].
Leibing E, Leonhardt U, Koster G, et al. Acupuncture treatment of chronic low-back pain -- a randomized, blinded, placebo-controlled trial with 9-month follow-up. Pain. 2002;96(1-2):189-96. [pmid: 11932074].
Lepisto P. A comparative trial of ds 103-283 and placebo in the treatment of acute skeletal muscle spasms due to disorders of the back. Ther Res. 1979;26(4):454-59.
Letchuman R, Deusinger R. Comparison of sacrospinalis myoelectric activity and pain levels in patients undergoing static and intermittent lumbar traction. Spine. 1993;18(10):1361-5. [pmid: 8211369].
Lewis JS, Hewitt JS, Billington L, et al. A randomized clinical trial comparing two physiotherapy interventions for chronic low back pain. Spine (Phila Pa 1976). 2005;30(7):711-21. [pmid: 15803071].
Licciardone JC, Brimhall AK, King LN. Osteopathic manipulative treatment for low back pain: a systematic review and meta-analysis of randomized controlled trials. BMC Musculoskelet Disord. 2005;6:43. [pmid: 16080794].
Licciardone JC, Stoll ST, Fulda KG, et al. Osteopathic manipulative treatment for chronic low back pain: a randomized controlled trial. Spine (Phila Pa 1976). 2003;28(13):1355-62. [pmid: 12838090].
Liddle SD, Baxter GD, Gracey JH. Exercise and chronic low back pain: what works?. Pain. 2004;107(1-2):176-90. [pmid: 14715404].
Lidstrom A, Zachrisson M. Physical therapy on low back pain and sciatica. An attempt at evaluation. Scand J Rehabil Med. 1970;2(1):37-42. [pmid: 4257208].
Lin M-L, Lin M-H, Fen J-J, et al. A comparison between pulsed radiofrequency and electro-acupuncture for relieving pain in patients with chronic low back pain. Acupunct Electrother Res. 2010;35(3-4):133-46. [pmid: 21319602].
Lindstrom I, Ohlund C, Eek C, et al. The effect of graded activity on patients with subacute low back pain: a randomized prospective clinical study with an operant-conditioning behavioral approach. Phys Ther. 1992;72(4):279-90. discussion 91-3. [pmid: 1533941].
Lindstrom I, Ohlund C, Eek C, et al. Mobility, strength, and fitness after a graded activity program for patients with subacute low back pain. A randomized prospective clinical study with a behavioral therapy approach. Spine (Phila Pa 1976). 1992;17(6):641-52. [pmid: 1385658].
Linton SJ, Boersma K, Jansson M, et al. A randomized controlled trial of exposure in vivo for patients with spinal pain reporting fear of work-related activities. Eur J Pain. 2008;12(6):722-30. [pmid: 18155934].
Linton SJ, Bradley LA, Jensen I, et al. The secondary prevention of low back pain: a controlled study with follow-up. Pain. 1989;36(2):197-207. [pmid: 2521930].
Liu J, Li N. Clinical observation of a combination of acupuncture and drug administration for non-specific acute lumbar sprain. J Acupunct Tuina Sci. 2010;8(1):47-9.
Ljunggren AE, Weber H, Kogstad O, et al. Effect of exercise on sick leave due to low back pain. A randomized, comparative, long-term study. Spine (Phila Pa 1976). 1997;22(14):1610-6. discussion 7. [pmid: 9253097].
Longo L, Tamburini A, Monti A, et al. Treatment with 904 nm and 10 600 nm laser of acute lumbago: double blind control. Laser Clin Res. 1988;3:16-20.
Lonn JH, Glomsrod B, Soukup MG, et al. Active back school: prophylactic management for low back pain. A randomized, controlled, 1-year follow-up study. Spine (Phila Pa 1976). 1999;24(9):865-71. [pmid: 10327507].
MacDonald RS, Bell CM. An open controlled assessment of osteopathic manipulation in nonspecific low-back pain. Spine (Phila Pa 1976). 1990;15(5):364-70. [pmid: 2141951].
Machado LA, de Souza M, Ferreira PH, et al. The McKenzie method for low back pain: a systematic review of the literature with a meta-analysis approach. Spine (Phila Pa 1976). 2006;31(9):E254-62. [pmid: 16641766].
Machado LAC, Azevedo DC, Capanema MB, et al. Client-centered therapy vs exercise therapy for chronic low back pain: a pilot randomized controlled trial in Brazil. Pain Med. 2007;8(3):251-8. [pmid: 17371412].
MacIntyre L. The effect of Pilates on patients' chronic low back pain: A pilot study [dissertation]. 2006.
Mackawan S, Eungpinichpong W, Pantumethakul R, et al. Effets of traditional Thai massage versus joint mobilization on substance P and pain perception in patients with non-specific low back pain. J Bodywork Mov Ther. 2007;11(1):9-16.
Malmivaara A, Hakkinen U, Aro T, et al. The treatment of acute low back pain--bed rest, exercises, or ordinary activity?. N Engl J Med. 1995;332(6):351-5. [pmid: 7823996].
Mangels M, Schwarz S, Worringen U, et al. Evaluation of a behavioral-medical inpatient rehabilitation treatment including booster sessions: a randomized controlled study. Clin J Pain. 2009;25(5):356-64. [pmid: 19454868].
Manheimer E, White A, Berman B, et al. Meta-analysis: acupuncture for low back pain. Ann Intern Med. 2005;142(8):651-63. [pmid: 15838072].
Manniche C, Hesselsoe G, Bentzen L, et al. Clinical trial of intensive muscle training for chronic low back pain. Lancet. 1988;2(8626-8627):1473-6. [pmid: 2904582].
Manniche C, Lundberg E, Christensen I, et al. Intensive dynamic back exercises for chronic low back pain: a clinical trial. Pain. 1991;47(1):53-63. [pmid: 1837606].
Mannion AF, Muntener M, Taimela S, et al. A randomized clinical trial of three active therapies for chronic low back pain. Spine (Phila Pa 1976). 1999;24(23):2435-48. [pmid: 10626305].
Mannion AF, Muntener M, Taimela S, et al. Comparison of three active therapies for chronic low back pain: results of a randomized clinical trial with one-year follow-up. Rheumatology (Oxford). 2001;40(7):772-8. [pmid: 11477282].
Mannion AF, Taimela S, Muntener M, et al. Active therapy for chronic low back pain part 1. Effects on back muscle activation, fatigability, and strength. Spine (Phila Pa 1976). 2001;26(8):897-908. [pmid: 11317112].
Marshall PWM, Kennedy S, Brooks C, et al. Pilates exercise or stationary cycling for chronic nonspecific low back pain: does it matter? a randomized controlled trial with 6-month follow-up. Spine. 2013;38(15):E952-9. [pmid: 23615384].
Martell BA, O'Connor PG, Kerns RD, et al. Systematic review: opioid treatment for chronic back pain: prevalence, efficacy, and association with addiction. Ann Intern Med. 2007;146(2):116-27. [pmid: 17227935].
Mathews W, Morkel M, Mathews J. Manipulation and traction for lumbago and sciatica: Physiotherapeutic techniques used in two controlled trials. Physiother Pract. 1988;4(4):201-6.
Mayer JM, Ralph L, Look M, et al. Treating acute low back pain with continuous low-level heat wrap therapy and/or exercise: a randomized controlled trial. Spine J. 2005;5(4):395-403. [pmid: 15996609].
McCauley JD, Thelen MH, Frank RG, et al. Hypnosis compared to relaxation in the outpatient management of chronic low back pain. Arch Phys Med Rehabil. 1983;64(11):548-52. [pmid: 6227304].
McCleane GJ. Does gabapentin have an analgesic effect on background, movement and referred pain? A randomised, double-blind, placebo controlled study. The Pain Clinic. 2001;13(2):103-7.
McNeely ML, Torrance G, Magee DJ. A systematic review of physiotherapy for spondylolysis and spondylolisthesis. Man Ther. 2003;8(2):80-91. [pmid: 12890435].
Melzack R, Jeans ME, Stratford JG, et al. Ice massage and transcutaneous electrical stimulation: comparison of treatment for low-back pain. Pain. 1980;9(2):209-17. [pmid: 6450393].
Melzack R, Vetere P, Finch M. Transcutaneous electrical nerve stimulation for low back pain. A comparison of TENS and massage for pain and range of motion. Phys Ther. 1983;63:489-93. [pmid: 6220415].
Milgrom C, Finestone A, Lev B, et al. Overexertional lumbar and thoracic back pain among recruits: a prospective study of risk factors and treatment regimens. J Spinal Disord. 1993;6(3):187-93. [pmid: 8347966].
Miller ER, Schenk RJ, Karnes JL, et al. A comparison of the McKenzie approach to a specific spine stabilization program for chronic low back pain. J Manual Manipulative Ther. 2005;13(2):103-12.
Million R, Nilsen K, Jayson M, et al. Evaluation of low back pain and assessment of lumbar corsets with and without back supports. Ann Rheum Dis. 1981;40(5):449-54. [pmid: 6458250].
Miyamoto GC, Costa LO, Galvanin T, et al. Efficacy of the addition of modified Pilates exercises to a minimal intervention in patients with chronic low back pain: a randomized controlled trial. Phys Ther. 2013;93(3):310-20. [pmid: 23064732].
Moffett JK, Torgerson D, Bell-Syer S, et al. Randomised controlled trial of exercise for low back pain: clinical outcomes, costs, and preferences. BMJ. 1999;319(7205):279-83. [pmid: 10426734].
Mohseni-Bandpei MA, Critchley J, Staunton T, et al. A prospective randomised controlled trial of spinal manipulation and ultrasound in the treatment of chronic low back pain. Physiotherapy. 2006;92(1):34-42.
Moll W. Therapy of acute lumbovertebral syndromes through optimal muscle relaxation using diazepam. Results of a double-blind study on 68 cases. Med Welt. 1973;24(45):1747-51. [pmid: 4272092].
Monticone M, Barbarino A, Testi C, et al. Symptomatic efficacy of stabilizing treatment versus laser therapy for sub-acute low back pain with positive tests for sacroiliac dysfunction: A randomised clinical controlled trial with 1 year follow-up. Eur. 2004;40(4):263-8. [pmid: 16175148].
Monticone M, Ferrante S, Rocca B, et al. Effect of a long-lasting multidisciplinary program on disability and fear-avoidance behaviors in patients with chronic low back pain: results of a randomized controlled trial. Clin J Pain. 2013;29(11):929-38. [pmid: 23328343].
Morone G, Iosa M, Paolucci T, et al. Efficacy of perceptive rehabilitation in the treatment of chronic nonspecific low back pain through a new tool: a randomized clinical study. Clin Rehabil. 2012;26(4):339-50. [pmid: 21965520].
Morone G, Paolucci T, Alcuri MR, et al. Quality of life improved by multidisciplinary back school program in patients with chronic non-specific low back pain: a single blind randomized controlled trial. Eur J Phys Rehabil Med. 2011;47(4):533-41. [pmid: 21508915].
Moseley L. Combined physiotherapy and education is efficacious for chronic low back pain. Aust J Physiother. 2002;48(4):297-302. [pmid: 12443524].
Muckle DS. Flurbiprofen for the treatment of soft tissue trauma. Am J Med. 1986;80(3A):76-80. [pmid: 2938471].
Muehlbacher M, Nickel MK, Kettler C, et al. Topiramate in treatment of patients with chronic low back pain: a randomized, double-blind, placebo-controlled study. Clin J Pain. 2006;22(6):526-31. [pmid: 16788338].
Muller R, Giles LG. Long-term follow-up of a randomized clinical trial assessing the efficacy of medication, acupuncture, and spinal manipulation for chronic mechanical spinal pain syndromes. J Manipulative Physiol Ther. 2005;28(1):3-11. [pmid: 15726029].
Nadler SF, Steiner DJ, Erasala GN, et al. Continuous low-level heatwrap therapy for treating acute nonspecific low back pain. Arch Phys Med Rehabil. 2003;84(3):329-34. [pmid: 12638099].
Nadler SF, Steiner DJ, Erasala GN, et al. Continuous low-level heat wrap therapy provides more efficacy than Ibuprofen and acetaminophen for acute low back pain. Spine (Phila Pa 1976). 2002;27(10):1012-7. [pmid: 12004166].
Nadler SF, Steiner DJ, Petty SR, et al. Overnight use of continuous low-level heatwrap therapy for relief of low back pain. Arch Phys Med Rehabil. 2003;84(3):335-42. [pmid: 12638100].
Nalamachu S, Hale M, Khan A. Hydromorphone extended release for neuropathic and non-neuropathic/nociceptive chronic low back pain: a post hoc analysis of data from a randomized, multicenter, double-blind, placebo-controlled clinical trial. J Opioid Manag. 2014;10(5):311-22. [pmid: 25350473].
Newton-John TR, Spence SH, Schotte D. Cognitive-behavioural therapy versus EMG biofeedback in the treatment of chronic low back pain. Behav Res Ther. 1995;33(6):691-7. [pmid: 7654161].
Nicholas MK, Wilson PH, Goyen J. Operant-behavioural and cognitive-behavioural treatment for chronic low back pain. Behav Res Ther. 1991;29(3):225-38. [pmid: 1831972].
Nicholas MK, Wilson PH, Goyen J. Comparison of cognitive-behavioral group treatment and an alternative non-psychological treatment for chronic low back pain. Pain. 1992;48(3):339-47. [pmid: 1534400].
Nicholson B, Ross E, Sasaki J, et al. Randomized trial comparing polymer-coated extended-release morphine sulfate to controlled-release oxycodone HCl in moderate to severe nonmalignant pain. Curr Med Res Opin. 2006;22(8):1503-14. [pmid: 16870075].
Niemisto L, Lahtinen-Suopanki T, Rissanen P, et al. A randomized trial of combined manipulation, stabilizing exercises, and physician consultation compared to physician consultation alone for chronic low back pain. Spine (Phila Pa 1976). 2003;28(19):2185-91. [pmid: 14520029].
Niemisto L, Rissanen P, Sarna S, et al. Cost-effectiveness of combined manipulation, stabilizing exercises, and physician consultation compared to physician consultation alone for chronic low back pain: a prospective randomized trial with 2-year follow-up. Spine (Phila Pa 1976). 2005;30(10):1109-15. [pmid: 15897822].
Nouwen A. EMG biofeedback used to reduce standing levels of paraspinal muscle tension in chronic low back pain. Pain. 1983;17(4):353-60. [pmid: 6229707].
Nuhr M, Hoerauf K, Bertalanffy A, et al. Active warming during emergency transport relieves acute low back pain. Spine (Phila Pa 1976). 2004;29(14):1499-503. [pmid: 15247569].
Nwuga VC. Ultrasound in treatment of back pain resulting from prolapsed intervertebral disc. Arch Phys Med Rehabil. 1983;64(2):88-9. [pmid: 6218793].
O'Donnell JB, Ekman EF, Spalding WM, et al. The effectiveness of a weak opioid medication versus a cyclo-oxygenase-2 (COX-2) selective non-steroidal anti-inflammatory drug in treating flare-up of chronic low-back pain: results from two randomized, double-blind, 6-week studies. J Int Med Res. 2009;37(6):1789-802. [pmid: 20146877].
Ostelo RW, van Tulder MW, Vlaeyen JW, et al. Behavioural treatment for chronic low-back pain. Cochrane Database Syst Rev. 2005;(1). CD002014. [pmid: 15674889].
O'Sullivan PB, Phyty GD, Twomey LT, et al. Evaluation of specific stabilizing exercise in the treatment of chronic low back pain with radiologic diagnosis of spondylolysis or spondylolisthesis. Spine (Phila Pa 1976). 1997;22(24):2959-67. [pmid: 9431633].
Peloso PM, Fortin L, Beaulieu A, et al. Analgesic efficacy and safety of tramadol/ acetaminophen combination tablets (Ultracet) in treatment of chronic low back pain: a multicenter, outpatient, randomized, double blind, placebo controlled trial. J Rheumatol. 2004;31(12):2454-63. [pmid: 15570651].
Penrose KW, Chook K, Stump JL. Acute and chronic effects of pneumatic lumbar suppor on muscular strength, flexibility, and functional impairment index. Sports Training Med Rehab. 1991;2:121-9.
Petersen T, Kryger P, Ekdahl C, et al. The effect of McKenzie therapy as compared with that of intensive strengthening training for the treatment of patients with subacute or chronic low back pain: A randomized controlled trial. Spine (Phila Pa 1976). 2002;27(16):1702-9. [pmid: 12195058].
Petersen T, Larsen K, Jacobsen S. One-year follow-up comparison of the effectiveness of McKenzie treatment and strengthening training for patients with chronic low back pain: outcome and prognostic factors. Spine. 2007;32(26):2948-56. [pmid: 18091486].
Pheasant H, Bursk A, Goldfarb J, et al. Amitriptyline and chronic low back pain: a randomized double-blind crossover study. Spine (Phila Pa 1976). 1983;8:552-7. [pmid: 6228015].
Pipino F, Menarini C, Lombardi G, et al. A direct myotonolytic (Pridinol Mesilate) for the mangement of chronic low back pain: A multicentre, comparitive clinical evaluation. Eur J Clin Res. 1991;1(1):55-70.
Pohjolainen T, Jekunen A, Autio L, et al. Treatment of acute low back pain with the COX-2-selective anti-inflammatory drug nimesulide: results of a randomized, double-blind comparative trial versus ibuprofen. Spine (Phila Pa 1976). 2000;25(12):1579-85. [pmid: 10851109].
Poole H, Glenn S, Murphy P. A randomised controlled study of reflexology for the management of chronic low back pain. Eur J Pain. 2007;11(8):878-87. [pmid: 17459741].
Pope MH, Phillips RB, Haugh LD, et al. A prospective randomized three-week trial of spinal manipulation, transcutaneous muscle stimulation, massage and corset in the treatment of subacute low back pain. Spine (Phila Pa 1976). 1994;19(22):2571-7. [pmid: 7855683].
Porsman O, Friis H. Prolapsed lumbar disc treated with intramuscularly administered dexamethasonephosphate. A prospectively planned, double-blind, controlled clinical trial in 52 patients. Scand J Rheumatol. 1979;8(3):142-4. [pmid: 386492].
Postacchini F, Facchini M, Palieri P. Efficacy of various forms of conservative treatment in low back pain. A comparative study. Neuro-Orthopedics. 1988;6(1):28-35.
Pratzel HG, Alken RG, Ramm S. Efficacy and tolerance of repeated oral doses of tolperisone hydrochloride in the treatment of painful reflex muscle spasm: results of a prospective placebo-controlled double-blind trial. Pain. 1996;67(2-3):417-25. [pmid: 8951937].
Preyde M. Effectiveness of massage therapy for subacute low-back pain: a randomized controlled trial. CMAJ. 2000;162(13):1815-20. [pmid: 10906914].
Pua Y-H, Cai C-C, Lim K-C. Treadmill walking with body weight support is no more effective than cycling when added to an exercise program for lumbar spinal stenosis: a randomised controlled trial. Aust J Physiother. 2007;53(2):83-9. [pmid: 17535143].
Pushpika Attanayake AM, Somarathna KIWK, Vyas GH, et al. Clinical evaluation of selected Yogic procedures in individuals with low back pain. Ayu. 2010;31(2):245-50. [pmid: 22131719].
Quinn F. Influence of Pilates-based mat exercise on chronic lower back pain [dissertation]. 2005.
Quinn K, Barry S, Barry L. Do patients with chronic low back pain benefit from attending Pilates classes after completing conventional physiotherapy treatment?. Physiother Pract Res. 2011;32(1):5-12.
Raber M, Hofmann S, Junge K, et al. Analgesic Efficacy and Tolerability of Tramadol 100mg Sustained-Release Capsules in Patients with Moderate to Severe Chronic Low Back Pain. Clin Drug Invest. 1999;17(6):415-23.
Rajpal N, Arora M, Chauhan V. The study on efficacy of Pilates and McKenzie exercise in postural low back pain – A rehabilitative protocol. Physiotherapy and Occupational Therapy Journal. 2008;1:33-56.
Rasmussen G. Manipulation in treatment of low back pain: a randomized clinical trial. Man Med. 1979;1:8-10.
Rasmussen J, Laetgaard J, Lindecrona A-L, et al. Manipulation does not add to the effect of extension exercises in chronic low-back pain (LBP). A randomized, controlled, double blind study. Joint Bone Spine. 2008;75(6):708-13. [pmid: 19028434].
Rasmussen-Barr E, Ang B, Arvidsson I, et al. Graded exercise for recurrent low-back pain: a randomized, controlled trial with 6-, 12-, and 36-month follow-ups. Spine. 2009;34(3):221-8. [pmid: 19179916].
Rasmussen-Barr E, Nilsson-Wikmar L, Arvidsson I. Stabilizing training compared with manual treatment in sub-acute and chronic low-back pain. Man Ther. 2003;8(4):233-41. [pmid: 14559046].
Rauck RL, Bookbinder SA, Bunker TR, et al. The ACTION study: a randomized, open-label, multicenter trial comparing once-a-day extended-release morphine sulfate capsules (AVINZA) to twice-a-day controlled-release oxycodone hydrochloride tablets (OxyContin) for the treatment of chronic, moderate to severe low back pain. J Opioid Manag. 2006;2(3):155-66. [pmid: 17319449].
Risch SV, Norvell NK, Pollock ML, et al. Lumbar strengthening in chronic low back pain patients. Physiologic and psychological benefits. Spine (Phila Pa 1976). 1993;18(2):232-8. [pmid: 8185727].
Rittweger J, Just K, Kautzsch K, et al. Treatment of chronic lower back pain with lumbar extension and whole-body vibration exercise: a randomized controlled trial. Spine (Phila Pa 1976). 2002;27(17):1829-34. [pmid: 12221343].
Roberts D, Walls C, Carlile J, et al. Relief of chronic low back pain: heat versus cold. 2nd edition ed. Baltimore. Urban & Schwarzenberg. 1992.
Roche G, Ponthieux A, Parot-Shinkel E, et al. Comparison of a functional restoration program with active individual physical therapy for patients with chronic low back pain: a randomized controlled trial. Arch Phys Med Rehabil. 2007;88(10):1229-35. [pmid: 17908562].
Roelofs PDDM, Bierma-Zeinstra SMA, van Poppel MNM, et al. Lumbar supports to prevent recurrent low back pain among home care workers: a randomized trial. [Summary for patients in Ann Intern Med. 2007 Nov 20;147(10):I54; PMID: 18025442]. Ann Intern Med. 2007;147(10):685-92. [pmid: 18025444].
Roth SH, Fleischmann RM, Burch FX, et al. Around-the-clock, controlled-release oxycodone therapy for osteoarthritis-related pain: placebo-controlled trial and long-term evaluation. Arch Intern Med. 2000;160(6):853-60. [pmid: 10737286].
Rollings H. Management of acute musculoskeletal conditions - Thoracolumbar strain or sprain: A doulbe-blind evaluation comparing the efficacy and safety of carisoprodol with cyclobenzaprene hydrochloride. Curr Ther Res. 1983;34(6):917-28.
Roman MP. A clinical evaluation of ultrasound by use of a placebo technic. Phys Ther Rev. 1960;40:649-52. [pmid: 13742988].
Rose MJ, Reilly JP, Pennie B, et al. Chronic low back pain rehabilitation programs: a study of the optimum duration of treatment and a comparison of group and individual therapy. Spine (Phila Pa 1976). 1997;22(19):2246-51. discussion 52-3. [pmid: 9346145].
Ruoff GE, Rosenthal N, Jordan D, et al. Tramadol/acetaminophen combination tablets for the treatment of chronic lower back pain: a multicenter, randomized, double-blind, placebo-controlled outpatient study. Clin Ther. 2003;25(4):1123-41. [pmid: 12809961].
Rydeard R. Evaluation of a targeted exercise rehabilitation approach and its effectiveness in the treatment of pain, functional disability and muscle function in a population with longstanding unresolved low back pain [dissertation]. Kingston, Canada. Queens University. 2001.
Salzman RT, Roberts MS, Wild J, et al. Can a controlled-release oral dose form of oxycodone be used as readily as an immediate-release form for the purpose of titrating to stable pain control?. J Pain Symptom Manage. 1999;18(4):271-9. [pmid: 10534967].
Salzmann E, Pforringer W, Paal G, et al. Treatment of chronic low-back syndrome with tetrazepam in a placebo controlled double-blind trial. J Drug Devel. 1992;4(4):219-28.
Saper RB, Sherman KJ, Cullum-Dugan D, et al. Yoga for chronic low back pain in a predominantly minority population: a pilot randomized controlled trial. Altern Ther Health Med. 2009;15(6):18-27. [pmid: 19943573].
Sator-Katzenschlager SM, Scharbert G, Kozek-Langenecker SA, et al. The short- and long-term benefit in chronic low back pain through adjuvant electrical versus manual auricular acupuncture. Anesth Analg. 2004;98(5):1359-64. table of contents. [pmid: 15105215].
Schimmel JJP, de Kleuver M, Horsting PP, et al. No effect of traction in patients with low back pain: a single centre, single blind, randomized controlled trial of Intervertebral Differential Dynamics Therapy. Eur Spine J. 2009;18(12):1843-50. [pmid: 19484433].
Schnitzer TJ, Gray WL, Paster RZ, et al. Efficacy of tramadol in treatment of chronic low back pain. J Rheumatol. 2000;27(3):772-8. [pmid: 10743823].
Schreiber S, Vinokur S, Shavelzon V, et al. A randomized trial of fluoxetine versus amitriptyline in musculo-skeletal pain. Isr J Psychiatr Rel. 2001;38(2):88-94. [pmid: 11475920].
Schweikert B, Jacobi E, Seitz R, et al. Effectiveness and cost-effectiveness of adding a cognitive behavioral treatment to the rehabilitation of chronic low back pain. J Rheumatol. 2006;33(12):2519-26. [pmid: 17143986].
Seferlis T, Nemeth G, Carlsson AM, et al. Conservative treatment in patients sick-listed for acute low-back pain: a prospective randomised study with 12 months' follow-up. Eur Spine J. 1998;7(6):461-70. [pmid: 9883955].
Shankar N, Thakur M, Tandon OP, et al. Autonomic status and pain profile in patients of chronic low back pain and following electro acupuncture therapy: a randomized control trial. Indian J Physiol Pharmacol. 2011;55(1):25-36. [pmid: 22315807].
Shaughnessy M, Caulfield B. A pilot study to investigate the effect of lumbar stabilisation exercise training on functional ability and quality of life in patients with chronic low back pain. Int J Rehabil Res. 2004;27(4):297-301. [pmid: 15572993].
Sherman KJ, Cherkin DC, Erro J, et al. Comparing yoga, exercise, and a self-care book for chronic low back pain: a randomized, controlled trial. Ann Intern Med. 2005;143(12):849-56. [pmid: 16365466].
Sherman KJ, Cherkin DC, Wellman RD, et al. A randomized trial comparing yoga, stretching, and a self-care book for chronic low back pain. Arch Intern Med. 2011;171(22):2019-26. [pmid: 22025101].
Sherry E, Kitchener P, Smart R. A prospective randomized controlled study of VAX-D and TENS for the treatment of chronic low back pain. Neurol Res. 2001;23(7):780-4. [pmid: 11680522].
Sirdalud Ternelin Asia-Pacific Study Group. Efficacy and gastroprotective effects of tizanidine plus diclofenac versus placebo plus dicofenac in patients with painful muscle spasms. Curr Ther Res. 1998;59:13-22.
Sjogren T, Nissinen KJ, Jarvenpaa SK, et al. Effects of a workplace physical exercise intervention on the intensity of headache and neck and shoulder symptoms and upper extremity muscular strength of office workers: a cluster randomized controlled cross-over trial. Pain. 2005;116(1-2):119-28. [pmid: 15927388].
Skargren EI, Oberg BE, Carlsson PG, et al. Cost and effectiveness analysis of chiropractic and physiotherapy treatment for low back and neck pain. Six-month follow-up. Spine (Phila Pa 1976). 1997;22(18):2167-77. [pmid: 9322328].
Skillgate E, Vingard E, Alfredsson L. Naprapathic manual therapy or evidence-based care for back and neck pain: a randomized, controlled trial. Clin J Pain. 2007;23(5):431-9. [pmid: 17515742].
Skouen JS, Grasdal AL, Haldorsen EM, et al. Relative cost-effectiveness of extensive and light multidisciplinary treatment programs versus treatment as usual for patients with chronic low back pain on long-term sick leave: randomized controlled study. Spine (Phila Pa 1976). 2002;27(9):901-9. discussion 9-10. [pmid: 11979157].
Smeets RJ, Severens JL, Beelen S, et al. More is not always better: cost-effectiveness analysis of combined, single behavioral and single physical rehabilitation programs for chronic low back pain. Eur J Pain. 2009;13(1):71-81. [pmid: 18434221].
Smeets RJ, Vlaeyen JW, Hidding A, et al. Active rehabilitation for chronic low back pain: cognitive-behavioral, physical, or both? First direct post-treatment results from a randomized controlled trial [ISRCTN22714229]. BMC Musculoskelet Disord. 2006;7:5. [pmid: 16426449].
Smeets RJEM, Vlaeyen JWS, Hidding A, et al. Chronic low back pain: physical training, graded activity with problem solving training, or both? The one-year post-treatment results of a randomized controlled trial. [Reprint in Ned Tijdschr Geneeskd. 2009 Mar 21;153(12):543-9; PMID: 19368107]. Pain. 2008;134:263-76. [pmid: 17498879].
Sorge J, Stadler T. Comparison of the analgesic efficacy and tolerability of tramadol 100mg sustained-release tablets and tramadol 50mg capsules for the treatment of chronic low back pain. Clin Drug Invest. 1997;14(3):157-64.
Soriano F, Rios R. Gallium Arsenide laser treatment of chronic low back pain: a prospective, randomized and double blind study. Laser Ther. 1998;10:175-80.
Soukup MG, Glomsrod B, Lonn JH, et al. The effect of a Mensendieck exercise program as secondary prophylaxis for recurrent low back pain. A randomized, controlled trial with 12-month follow-up. Spine (Phila Pa 1976). 1999;24(15):1585-91. discussion 92. [pmid: 10457579].
Soukup MG, Lonn J, Glomsrod B, et al. Exercises and education as secondary prevention for recurrent low back pain. Physiother Res Int. 2001;6(1):27-39. [pmid: 11379254].
St John Dixon A, Owen-Smith BD, Harrison RA. Cold-sensitive, non-specific low back pain: a comparative trial of treatment. Clinical Trials Journal. 1972;4:16-21.
Staal JB, Hlobil H, Twisk JW, et al. Graded activity for low back pain in occupational health care: a randomized, controlled trial. Ann Intern Med. 2004;140(2):77-84. [pmid: 14734329].
Stankovic R, Johnell O. Conservative treatment of acute low-back pain. A prospective randomized trial: McKenzie method of treatment versus patient education in “mini back school”. Spine (Phila Pa 1976). 1990;15(2):120-3. [pmid: 2139241].
Steenstra IA, Anema JR, Bongers PM, et al. The effectiveness of graded activity for low back pain in occupational healthcare. Occup Environ Med. 2006;63(11):718-25. [pmid: 16847036].
Stein D, Peri T, Edelstein E, et al. The efficacy of amitriptyline and acetaminophen in the management of acute low back pain. Psychosomatics. 1996;37(1):63-70. [pmid: 8600497].
Steiner DJ, Sitar S, Wen W, et al. Efficacy and safety of the seven-day buprenorphine transdermal system in opioid-naive patients with moderate to severe chronic low back pain: an enriched, randomized, double-blind, placebo-controlled study. J Pain Symptom Manage. 2011;42(6):903-17. [pmid: 21945130].
Storheim K, Brox JI, Holm I, et al. Intensive group training versus cognitive intervention in sub-acute low back pain: short-term results of a single-blind randomized controlled trial. J Rehabil Med. 2003;35(3):132-40. [pmid: 12809196].
Strong J. Incorporating cognitive-behavioral therapy with occupational therapy: A comparative study with patients with low back pain. J Occup Rehabil. 1998;8(1):61-71.
Stuckey SJ, Jacobs A, Goldfarb J. EMG biofeedback training, relaxation training, and placebo for the relief of chronic back pain. Percept Mot Skills. 1986;63(3):1023-36. [pmid: 2949196].
Su J-t, Zhou Q-h, Li R, et al. Immediate analgesic effect of wrist-ankle acupuncture for acute lumbago: a randomized controlled trial. Zhongguo zhenjiu. 2010;30(8):617-22. [pmid: 20942274].
Sutlive TG, Mabry LM, Easterling EJ, et al. Comparison of short-term response to two spinal manipulation techniques for patients with low back pain in a military beneficiary population. Mil Med. 2009;174(7):750-6. [pmid: 19685848].
Sweetman BJ, Baig A, Parsons DL. Mefenamic acid, chlormezanone-paracetamol, ethoheptazine-aspirin-meprobamate: a comparative study in acute low back pain. Br J Clin Pract. 1987;41(2):619-24. [pmid: 2960369].
Sweetman BJ, Heinrich I, Anderson JAD. A randomized controlled trial of exercises, short wave diathermy, and traction for low back pain, with evidence of diagnosis-related response to treatment. J Orthop Rheumatol. 1993;6(4):159-66.
Szpalski M, Hayez JP. Objective functional assessment of the efficacy of tenoxicam in the treatment of acute low back pain. A double-blind placebo-controlled study. Br J Rheumatol. 1994;33(1):74-8. [pmid: 8162464].
Tavafian SS, Jamshidi AR, Mohammad K. Treatment of chronic low back pain: a randomized clinical trial comparing multidisciplinary group-based rehabilitation program and oral drug treatment with oral drug treatment alone. Clin J Pain. 2011;27(9):811-8. [pmid: 21642845].
Tavafian SS, Jamshidi AR, Montazeri A. A randomized study of back school in women with chronic low back pain: quality of life at three, six, and twelve months follow-up. Spine. 2008;33(15):1617-21. [pmid: 18580739].
Tekur P, Chametcha S, Hongasandra RN, et al. Effect of yoga on quality of life of clbp patients: A randomized control study. Int J Yoga. 2010;3(1):10-7. [pmid: 20948896].
Tekur P, Singphow C, Nagendra HR, et al. Effect of short-term intensive yoga program on pain, functional disability and spinal flexibility in chronic low back pain: a randomized control study. J Altern Complement Med. 2008;14(6):637-44. [pmid: 18673078].
Tervo T, Petaja L, Lepisto P. A controlled clinical trial of a muscle relaxants analgesic combination in the treatment of acute lumbago. Br J Clin Pract. 1976;30:62-4. [pmid: 130920].
Tesio L, Merlo A. Autotraction versus passive traction: an open controlled study in lumbar disc herniation. Arch Phys Med Rehabil. 1993;74(8):871-6. [pmid: 8347073].
Teyhen DS, Miltenberger CE, Deiters HM, et al. The use of ultrasound imaging of the abdominal drawing-in maneuver in subjects with low back pain. J Orthop Sports Phys Ther. 2005;35(6):346-55. [pmid: 16001906].
Thomas KJ, MacPherson H, Thorpe L, et al. Randomised controlled trial of a short course of traditional acupuncture compared with usual care for persistent non-specific low back pain. BMJ. 2006;333(7569):623. [pmid: 16980316].
Thomas KJ, MacPherson H, Thorpe L, et al. Randomized controlled trial of a short course of traditional acupuncture compared with usual care for persistent non-specific low back pain. J Accupunct Assoc Chartered Phys. 2007;3:47-56.
Tilbrook HE, Cox H, Hewitt CE, et al. Yoga for chronic low back pain: a randomized trial. Ann Intern Med. 2011;155(9):569-78. [pmid: 22041945].
Topuz O, Ozfidan E, Ozgen M, et al. Efficacy of transcutaneous electrical nerve stimulation and percutaneous neuromodulation therapy in chronic low back pain. J Back Musculoskeletal Rehabil. 2004;17(3-4):127-33.
Torstensen TA, Ljunggren AE, Meen HD, et al. Efficiency and costs of medical exercise therapy, conventional physiotherapy, and self-exercise in patients with chronic low back pain. A pragmatic, randomized, single-blinded, controlled trial with 1-year follow-up. Spine (Phila Pa 1976). 1998;23(23):2616-24. [pmid: 9854761].
Toya S, Motegi M, Inomata K, et al. Report on a computer-randomized double blind clinical trial to determine the effectiveness of the GaAlAs (830 nm) diode laser for pain attenuation in selected pain groups. Laser Ther. 1994;6:143.
Treves R, Montaine de la Roque P, Dumond JJ, et al. Prospective study of the analgesic action of clomipramine versus placebo in refractory lumbosciatica (68 cases). Rev Rhum Mal Osteoartic. 1991;58(7):549-52. [pmid: 1833813].
Tritilanunt T, Wajanavisit W. The efficacy of an aerobic exercise and health education program for treatment of chronic low back pain. J Med Assoc Thai. Suppl 2. 2001;84:S528-33. [pmid: 11853276].
Turner JA. Comparison of group progressive-relaxation training and cognitive-behavioral group therapy for chronic low back pain. J Consult Clin Psychol. 1982;50(5):757-65. [pmid: 6216275].
Turner JA, Clancy S. Comparison of operant behavioral and cognitive-behavioral group treatment for chronic low back pain. J Consult Clin Psychol. 1988;56(2):261-6. [pmid: 2967314].
Turner JA, Clancy S, McQuade KJ, et al. Effectiveness of behavioral therapy for chronic low back pain: a component analysis. J Consult Clin Psychol. 1990;58(5):573-9. [pmid: 2147702].
Turner JA, Jensen MP. Efficacy of cognitive therapy for chronic low back pain. Pain. 1993;52(2):169-77. [pmid: 8455964].
Tveito TH, Hysing M, Eriksen HR. Low back pain interventions at the workplace: a systematic literature review. Occup Med (Lond). 2004;54(1):3-13. [pmid: 14963248].
Uberall MA, Mueller-Schwefe GHH, Terhaag B. Efficacy and safety of flupirtine modified release for the management of moderate to severe chronic low back pain: results of SUPREME, a prospective randomized, double-blind, placebo- and active-controlled parallel-group phase IV study. Curr Med Res Opin. 2012;28(10):1617-34. [pmid: 22970658].
UK BEAM Trial Team. United Kingdom back pain exercise and manipulation (UK BEAM) randomised trial: effectiveness of physical treatments for back pain in primary care. BMJ. 2004;329(7479):1377. [pmid: 15556955].
Underwood MR, Morgan J. The use of a back class teaching extension exercises in the treatment of acute low back pain in primary care. Fam Pract. 1998;15(1):9-15. [pmid: 9527292].
Unsgaard-Tondel M, Fladmark AM, Salvesen O, et al. Motor control exercises, sling exercises, and general exercises for patients with chronic low back pain: a randomized controlled trial with 1-year follow-up. Phys Ther. 2010;90(10):1426-40. [pmid: 20671099].
Vad VB, Bhat AL, Tarabichi Y. The role of the Back Rx exercise program in diskogenic low back pain: a prospective randomized trial. Arch Phys Med Rehabil. 2007;88(5):577-82. [pmid: 17466725].
Valle-Jones J, Walsh H, O'Hara J, et al. Controlled trial of a back support (‘Lumbotrain’) in patients with non-specific low back pain. Curr Med Res Opin. 1992;12(9):604-13. [pmid: 1533832].
van den Hout JHC, Vlaeyen JWS, Heuts PHTG, et al. Secondary Prevention of Work-Related Disability in Nonspecific Low Back Pain: Does Problem-Solving Therapy Help? A Randomized Clinical Trial. Clin J Pain. 2003;19(2):87-96. [pmid: 12616178].
van der Heijden G, Beurskens A, Dirx M, et al. Efficacy of lumbar traction: a randomised clinical trial. Physiotherapy. 1995;81(1):29-35.
van der Roer N, van Tulder M, Barendse J, et al. Intensive group training protocol versus guideline physiotherapy for patients with chronic low back pain: a randomised controlled trial. Eur Spine J. 2008;17(9):1193-200. [pmid: 18663487].
van der Roer N, van Tulder M, van Mechelen W, et al. Economic evaluation of an intensive group training protocol compared with usual care physiotherapy in patients with chronic low back pain. Spine. 2008;33(4):445-51. [pmid: 18277878].
van Tulder MW, Touray T, Furlan AD, et al. Muscle relaxants for nonspecific low back pain: a systematic review within the framework of the cochrane collaboration. Spine (Phila Pa 1976). 2003;28(17):1978-92. [pmid: 12973146].
van Tulder MW, Touray T, Furlan AD, et al. Muscle relaxants for non-specific low-back pain. Cochrane Database Syst Rev. 2009;(4).
Von Korff M, Balderson BH, Saunders K, et al. A trial of an activating intervention for chronic back pain in primary care and physical therapy settings. Pain. 2005;113(3):323-30. [pmid: 15661440].
Vorsanger GJ, Xiang J, Gana TJ, et al. Extended-release tramadol (tramadol ER) in the treatment of chronic low back pain. J Opioid Manag. 2008;4(2):87-97. [pmid: 18557165].
Vroomen PC, de Krom MC, Slofstra PD, et al. Conservative treatment of sciatica: a systematic review. J Spinal Disord. 2000;13(6):463-9. [pmid: 11132976].
Waagen GN, Haldeman S, Cook G, et al. Short term trial of chiropractic adjustments for the relief of chronic low back pain. Manual Med. 1986;(2):63-7.
Wajswelner H, Metcalf B, Bennell K. Clinical pilates versus general exercise for chronic low back pain: randomized trial. Med Sci Sports Exerc. 2012;44(7):1197-205. [pmid: 22246216].
Waterworth RF, Hunter IA. An open study of diflunisal, conservative and manipulative therapy in the management of acute mechanical low back pain. N Z Med J. 1985;98(779):372-5. [pmid: 3157894].
Weber H. Comparison of the effect of diazepam and levomepromazine on pain in patients with acute lumbago-sciatica. J Oslo City Hosp. 1980;30(5):65-8. [pmid: 6446597].
Weber H, Aasand G. The effect of phenylbutazone on patients with acute lumbago-sciatica. A double blind trial. J Oslo City Hosp. 1980;30(5):69-72. [pmid: 6446598].
Weber H, Holme I, Amlie E. The natural course of acute sciatica with nerve root symptoms in a double-blind placebo-controlled trial evaluating the effect of piroxicam. Spine (Phila Pa 1976). 1993;18(11):1433-8. [pmid: 8235813].
Webster LR, Butera PG, Moran LV, et al. Oxytrex minimizes physical dependence while providing effective analgesia: a randomized controlled trial in low back pain. J Pain. 2006;7(12):937-46. [pmid: 17157780].
Weiner DK, Rudy TE, Glick RM, et al. Efficacy of percutaneous electrical nerve stimulation for the treatment of chronic low back pain in older adults. J Am Geriatr Soc. 2003;51(5):599-608. [pmid: 12752833].
Werners R, Pynsent PB, Bulstrode CJ. Randomized trial comparing interferential therapy with motorized lumbar traction and massage in the management of low back pain in a primary care setting. Spine (Phila Pa 1976). 1999;24(15):1579-84. [pmid: 10457578].
White AW. Low back pain in men receiving workmen's compensation. Can Med Assoc J. 1966;95(2):50-6. [pmid: 4222996].
Wiesel SW, Cuckler JM, Deluca F, et al. Acute low-back pain. An objective analysis of conservative therapy. Spine (Phila Pa 1976). 1980;5(4):324-30. [pmid: 6450448].
Wilkey A, Gregory M, Byfield D, et al. A comparison between chiropractic management and pain clinic management for chronic low-back pain in a national health service outpatient clinic. J Altern Complement Med. 2008;14(5):465-73. [pmid: 18564952].
Williams K, Abildso C, Steinberg L, et al. Evaluation of the effectiveness and efficacy of Iyengar yoga therapy on chronic low back pain. Spine. 2009;34(19):2066-76. [pmid: 19701112].
Williams KA, Petronis J, Smith D, et al. Effect of Iyengar yoga therapy for chronic low back pain. Pain. 2005;115(1-2):107-17. [pmid: 15836974].
Witt CM, Jena S, Selim D, et al. Pragmatic randomized trial evaluating the clinical and economic effectiveness of acupuncture for chronic low back pain. Am J Epidemiol. 2006;164(5):487-96. [pmid: 16798792].
Witt CM, Manheimer E, Hammerschlag R, et al. How well do randomized trials inform decision making: systematic review using comparative effectiveness research measures on acupuncture for back pain. PLoS ONE. 2012;7(2):e32399. [pmid: 22389699].
Woodhead T, Clough A. A systematic review of the evidence for manipulation in the treatment of low back pain. J Orthop Med. 2005;27:99-120.
Worth SGA, Bunn JY. Real-time ultrasound feedback and abdominal hollowing exercises for people with low back pain. N Z J Physiother. 2007;35(1):4-11.
Wu Y-c, Zhang B-m, Wang C-m, et al. Observation on short-term and long-term therapeutic effects of electroacupuncture at Houxi (SI 3) on acute lumbar sprain. Zhongguo Zhen Jiu. 2007;27(1):3-5. [pmid: 17378192].
Ximenes A, Robles M, Sands G, et al. Valdecoxib is as efficacious as diclofenac in the treatment of acute low back pain. Clin J Pain. 2007;23(3):244-50. [pmid: 17314584].
Yelland MJ, Glasziou PP, Bogduk N, et al. Prolotherapy injections, saline injections, and exercises for chronic low-back pain: a randomized trial. Spine (Phila Pa 1976). 2004;29(1):9-16. discussion. [pmid: 14699269].
Yeung CK, Leung MC, Chow DH. The use of electro-acupuncture in conjunction with exercise for the treatment of chronic low-back pain. J Altern Complement Med. 2003;9(4):479-90. [pmid: 14499023].
Yildirim K, Şışecıoğlu M, Karatay S, et al. The effectiveness of gabapentin in patients with chronic radiculopathy. The Pain Clinic. 2003;15(3):213-8.
Yip YB, Tse SH. The effectiveness of relaxation acupoint stimulation and acupressure with aromatic lavender essential oil for non-specific low back pain in Hong Kong: a randomised controlled trial. Complement Ther Med. 2004;12(1):28-37. [pmid: 15130569].
Yokoyama M, Sun X, Oku S, et al. Comparison of percutaneous electrical nerve stimulation with transcutaneous electrical nerve stimulation for long-term pain relief in patients with chronic low back pain. Anesth Analg. 2004;98(6):1552-6. table of contents. [pmid: 15155304].
Yozbatiran N, Yildirim Y, Parlak B. Effects of fitness and aquafitness exercises on physical fitness in patients with chronic low back pain. The Pain Clinic. 2004;16(1):35-42.
Yuan J, Purepong N, Hunter RF, et al. Different frequencies of acupuncture treatment for chronic low back pain: an assessor-blinded pilot randomised controlled trial. Complement Ther Med. 2009;17(3):131-40. [pmid: 19398066].
Yun M, Shao Y, Zhang Y, et al. Hegu acupuncture for chronic low-back pain: a randomized controlled trial. J Altern Complement Med. 2012;18(2):130-6. [pmid: 22339101].
Zaproudina N, Hietikko T, Hanninen OOP, et al. Effectiveness of traditional bone setting in treating chronic low back pain: a randomised pilot trial. Complement Ther Med. 2009;17(1):23-8. [pmid: 19114225].
Zaringhalam J, Manaheji H, Rastqar A, et al. Reduction of chronic non-specific low back pain: a randomised controlled clinical trial on acupuncture and baclofen. Chin. 2010;5:15. [pmid: 20416100].
Zeada M. Effects of Pilates on low back pain and urine catecholamine. Ovidius University Annals. Series Physiotherapy Education and Sport. 2011;(12):41-7.
Zerbini C, Ozturk ZE, Grifka J, et al. Efficacy of etoricoxib 60 mg/day and diclofenac 150 mg/day in reduction of pain and disability in patients with chronic low back pain: results of a 4-week, multinational, randomized, double-blind study. Curr Med Res Opin. 2005;21(12):2037-49. [pmid: 16368055].
Zheng Z. Observations on the therapeutic effects of treating 90 cases of acute lumbar sprain by acupunctuing Xing Jian (LR2). [in Chinese]. J Community Med. 2005;1(7):68-9.
Zylbergold RS, Piper MC. Lumbar disc disease: comparative analysis of physical therapy treatments. Arch Phys Med Rehabil. 1981;62(4):176-9. [pmid: 6453571].

## All Other Excluded Studies

Chiropractic and yoga as an effective combination therapy for the treatment of low back pain: A randomised controlled trial. Clin Chiropr. 2012;15(2):85. Excluded: not a study (letter, editorial, non-systematic review article).
Aalto TJ, Leinonen V, Herno A, et al. Postoperative rehabilitation does not improve functional outcome in lumbar spinal stenosis: a prospective study with 2-year postoperative follow-up. Eur Spine J. 2011;20(8):1331-40. Excluded: wrong outcome. [pmid: 21523459].
Aasa B, Berglund L, Michaelson P, et al. Individualized low-load motor control exercises and education versus a high-load lifting exercise and education to improve activity, pain intensity, and physical performance in patients with low back pain: a randomized controlled trial. J Orthop Sports Phys Ther. 2015;45(2):77-85. B1. 4. Excluded: sample size too small. [pmid: 25641309].
Abbott AD, Tyni-Lenne R, Hedlund R. Early rehabilitation targeting cognition, behavior, and motor function after lumbar fusion: a randomized controlled trial. Spine. 2010;35(8):848-57. Excluded: wrong population. [pmid: 20354468].
Abdel Shaheed C, Maher CG, Williams KA, et al. Interventions available over the counter and advice for acute low back pain: systematic review and meta-analysis. J Pain. 2014;15(1):2-15. Excluded: using original studies instead (e.g. meta-analysis, compiled study data, or data from another publication). [pmid: 24373568].
Adamczyk A, Kiebzak W, Wilk-Franczuk M, et al. Effectiveness of holistic physiotherapy for low back pain. Ortop Tramatol Rehabil. 2009;11(6):562-76. Excluded: wrong intervention. [pmid: 20201159].
Afilalo M, Morlion B. Efficacy of tapentadol ER for managing moderate to severe chronic pain. Pain physician. 2013;16(1):27-40. Excluded: wrong population. [pmid: 23340531].
Ahmad S, Buchh V, Koul A, et al. Chronic low back pain and treatment with microwave diathermy. Indian J Pain. 2013;27:22-5. Excluded: wrong study deisgn for key question.
Aina A, May S, Clare H. The centralization phenomenon of spinal symptoms--a systematic review. Man Ther. 2004;9(3):134-43. Excluded: wrong intervention. [pmid: 15245707].
Akbarzadeh M, Ghaemmaghami M, Yazdanpanahi Z, et al. The Effect Dry Cupping Therapy at Acupoint BL23 on the Intensity of Postpartum Low Back Pain in Primiparous Women Based on Two Types of Questionnaires, 2012; A Randomized Clinical Trial. Int. 2014;2(2):112-20. Excluded: wrong intervention. [pmid: 25349852].
Akhmadeeva L, Rayanova G, Blinova N, et al. The effects of transcutaneous electrical nerve stimulation (TENS) for patients with low back pain: First two randomized contolled trials in Russia with dynamic TENS devices. Journal of Neurology. Conference: Joint Congress of European Neurology 2014. Istanbul Turkey. Conference Start: 20140531 Conference End: 20140603. Conference Publication:(var.pagings). 2014:S110. Excluded: not a study (letter, editorial, non-systematic review article).
Akhmadeeva LR, Setchenkova NM, Magzhanov RV, et al. Randomized blind placebo-controlled study of the effectiveness of transcutaneous adaptive electrostimulation in the treatment of nonspecific low back pain. Zh Nevrol Psikhiatr Im S S Korsakova. 2010;110(4):57-62. Excluded: not English language but possibly relevant. [pmid: 20517212].
Akyol Y, Durmus D, Alayli G, et al. Effectiveness of physical therapy agents in patients with lumbar spinal stenosis. [Turkish]. Turkiye Fiziksel Tip Ve Rehabilitasyon Dergisi. 2009;55(4):140-6. Excluded: not English language but possibly relevant.
Aladro-Gonzalvo AR, Araya-Vargas GA, Machado-Diaz M, et al. Pilates-based exercise for persistent, non-specific low back pain and associated functional disability: a meta-analysis with meta-regression. J Bodyw Mov Ther. 2013;17(1):125-36. Excluded: Pre-2007 systematic review or superseded by a more recent review. [pmid: 23294694].
Alaka K, Zhang Q, Ahl J, et al. Safety of duloxetine for the treatment of older patients with osteoarthritis knee pain or chronic low back pain. J Pain. 2013;14(4 SUPPL. 1). Excluded: not a study (letter, editorial, non-systematic review article).
Alayat MSM, Atya AM, Ali MME, et al. Long-term effect of high-intensity laser therapy in the treatment of patients with chronic low back pain: a randomized blinded placebo-controlled trial. Lasers Med Sci. 2014;29(3):1065-73. Excluded: wrong intervention. [pmid: 24178907].
Aleksiev AR. Ten-year follow-up of strengthening versus flexibility exercises with or without abdominal bracing in recurrent low back pain. Spine. 2014;39(13):997-1003. Excluded: wrong population. [pmid: 24732860].
Allan L, Richarz U, Simpson K, et al. Transdermal fentanyl versus sustained release oral morphine in strong-opioid naive patients with chronic low back pain. Spine (Phila Pa 1976). 2005;30(22):2484-90. Excluded: wrong comparison. [pmid: 16284584].
Ammendolia C, Furlan AD, Imamura M, et al. Evidence-informed management of chronic low back pain with needle acupuncture. Spine J. 2008;8(1):160-72. Excluded: Pre-2007 systematic review or superseded by a more recent review. [pmid: 18164464].
Ammendolia C, Stuber K, de Bruin LK, et al. Nonoperative treatment of lumbar spinal stenosis with neurogenic claudication: a systematic review. Spine. 2012;37(10):E609-16. Excluded: using original studies instead (e.g. meta-analysis, compiled study data, or data from another publication). [pmid: 22158059].
Ammendolia C, Stuber K, Tomkins-Lane C, et al. What interventions improve walking ability in neurogenic claudication with lumbar spinal stenosis? A systematic review. Eur Spine J. 2014;23(6):1282-301. Excluded: using original studies instead (e.g. meta-analysis, compiled study data, or data from another publication). [pmid: 24633719].
Ammendolia C, Stuber KJ, Rok E, et al. Nonoperative treatment for lumbar spinal stenosis with neurogenic claudication. Cochrane Database Syst Rev. 2013;8. CD010712. Excluded: using original studies instead (e.g. meta-analysis, compiled study data, or data from another publication). [pmid: 23996271].
Andersen T, Christensen FB, Egund N, et al. The effect of electrical stimulation on lumbar spinal fusion in older patients: a randomized, controlled, multi-center trial: part 2: fusion rates. Spine. 2009;34(21):2248-53. Excluded: wrong population. [pmid: 19934803].
Andrade SC, Araujo AG, Vilar MJ. Back school for patients with non-specific chronic low-back pain: benefits from the association of an exercise program with patient's education. Acta Reumatol. 2008;33(4):443-50. Excluded: not English language but possibly relevant. [pmid: 19107089].
Andrusaitis SF, Brech GC, Vitale GF, et al. Trunk stabilization among women with chronic lower back pain: a randomized, controlled, and blinded pilot study. Clinics. 2011;66(9):1645-50. Excluded: wrong study deisgn for key question. [pmid: 22179174].
Erratum: Efficacy and safety of tapentadol extended release for the management of chronic low back pain: Results of a prospective, randomized, double-blind, placebo- and active-controlled Phase III study. (Expert Opin. Pharmacother. (2010) 11 (1787-1804)). Expert Opin Pharmacother. 2010;11(16):2773. Excluded: not a study (letter, editorial, non-systematic review article). [pmid: 20578811].
Apeldoorn AT, Bosmans JE, Ostelo RW, et al. Cost-effectiveness of a classification-based system for sub-acute and chronic low back pain. Eur Spine J. 2012;21(7):1290-300. Excluded: wrong outcome. [pmid: 22258622].
Apeldoorn AT, Ostelo RW, van Helvoirt H, et al. The cost-effectiveness of a treatment-based classification system for low back pain: design of a randomised controlled trial and economic evaluation. BMC Musculoskelet Disord. 2010;11:58. Excluded: wrong outcome. [pmid: 20346133].
Apeldoorn AT, Ostelo RW, van Helvoirt H, et al. A randomized controlled trial on the effectiveness of a classification-based system for subacute and chronic low back pain. Spine. 2012;37(16):1347-56. Excluded: wrong intervention. [pmid: 22333955].
Apfel CC, Cakmakkaya OS, Martin W, et al. Restoration of disk height through non-surgical spinal decompression is associated with decreased discogenic low back pain: a retrospective cohort study. BMC Musculoskelet Disord. 2010;11:155. Excluded: wrong outcome. [pmid: 20615252].
Arul Prakasam KC, Salman P, Senthilkumar N. Comparative assessment of analgesic effect of different NSAID's in the management of low back pain. Int J PharmTech Res. 2011;3(3):1260-1264. 2011. Date of Publication: July-Sept 2011): 1264. Excluded: wrong study deisgn for key question.
Assendelft WJ, Morton SC, Yu EI, et al. WITHDRAWN: Spinal manipulative therapy for low-back pain. Cochrane Database Syst Rev. 2013;1. CD000447. Excluded: not a study (letter, editorial, non-systematic review article). [pmid: 23440781].
Atherton J, Clarke A, Harrison R, et al. Low Back Pain. Occup Ther. May. 1983:133-4. Excluded: wrong intervention.
Atkinson J, Slater M, Patel S, et al. Gabapentin for chronic back pain: a randomized clinical trial. J Pain. 2010;11(4, Supplement):S37. Excluded: not a study (letter, editorial, non-systematic review article).
Ay Uslusoy G, Savas S. Effectiveness of extension-controlled lumbar support and elastic lumbar support in chronic low back pain in short-term follow-up and the factors affecting the compliance: A randomized controlled clinical study. Turkiye Fiziksel Tip ve Rehabilitasyon Dergisi. 2013;59(3):182-8. Excluded: wrong intervention.
Bachmann S, Wieser S, Oesch P, et al. Three-year cost analysis of function-centred versus pain-centred inpatient rehabilitation in patients with chronic non-specific low back pain. J Rehabil Med. 2009;41(11):919-23. Excluded: wrong outcome. [pmid: 19841844].
Baena-Beato PA, Arroyo-Morales M, Delgado-Fernandez M, et al. Effects of different frequencies (2-3 days/week) of aquatic therapy program in adults with chronic low back pain. A non-randomized comparison trial. Pain Med. 2013;14(1):145-58. Excluded: wrong intervention. [pmid: 23279214].
Baena-Beato PA, Artero EG, Arroyo-Morales M, et al. Aquatic therapy improves pain, disability, quality of life, body composition and fitness in sedentary adults with chronic low back pain. A controlled clinical trial. Clin Rehabil. 2014;28(4):350-60. Excluded: wrong intervention. [pmid: 24177712].
Bahrami-Taghanaki H, Liu Y, Azizi H, et al. A randomized, controlled trial of acupuncture for chronic low-back pain. Altern Ther Health Med. 2014;20(3):13-9. Excluded: wrong study deisgn for key question. [pmid: 24755566].
Balakatounis KC, Panagiotopoulou KA, Mitsiokapa EA, et al. Evidence-based evaluation and current practice of non-operative treatment strategies for lumbar stenosis. Folia Med (Plovdiv). 2011;53(3):5-14. Excluded: Pre-2007 systematic review or superseded by a more recent review. [pmid: 22359977].
Banerjee M, Bhattacharyya K, Sarkar RN, et al. Comparative study of efficacy and tolerability of flupirtine versus tramadol in non-steroidal anti-inflammatory drug intolerant mechanical low back pain. Indian J Rheumatol. 2012;7(3):135-40. Excluded: wrong intervention.
Barker KL, Elliott CJ, Sackley CM, et al. Treatment of chronic back pain by sensory discrimination training. A Phase I RCT of a novel device (FairMed) vs. TENS. BMC Musculoskelet Disord. 2008;9:97. Excluded: wrong intervention. [pmid: 18588702].
Baron R, Schwittay A, Binder A, et al. Effectiveness of tapentadol prolonged release (PR) versus oxycodone/naloxone pr for severe chronic low back pain with a neuropathic pain component. Pain pract. Conference: 7th World Congress of the World Institute of Pain, WIP 2014. Maastricht Netherlands. Conference Start: 20140507 Conference End: 20140510. Conference Publication:(var.pagings). 2014:59-60. Excluded: not a study (letter, editorial, non-systematic review article).
Basler H-D, Bertalanffy H, Quint S, et al. TTM-based counselling in physiotherapy does not contribute to an increase of adherence to activity recommendations in older adults with chronic low back pain--a randomised controlled trial. Eur J Pain. 2007;11(1):31-7. Excluded: wrong population. [pmid: 16448828].
Behrbalk E, Halpern P, Boszczyk BM, et al. Anxiolytic medication as an adjunct to morphine analgesia for acute low back pain management in the emergency department: a prospective randomized trial. Spine. 2014;39(1):17-22. Excluded: wrong intervention. [pmid: 24270933].
Bell JA, Burnett A. Exercise for the primary, secondary and tertiary prevention of low back pain in the workplace: a systematic review. J Occup Rehabil. 2009;19(1):8-24. Excluded: wrong population. [pmid: 19219537].
Ben Salah Frih Z, Fendri Y, Jellad A, et al. Efficacy and treatment compliance of a home-based rehabilitation programme for chronic low back pain: a randomized, controlled study. Ann Phys Rehabil Med. 2009;52(6):485-96. Excluded: wrong study deisgn for key question. [pmid: 19473905].
Beneciuk JM, Robinson ME, George SZ. Low back pain subgroups using fear-avoidance model measures: results of a cluster analysis. Clin J Pain. 2012;28(8):658-66. Excluded: wrong study deisgn for key question. [pmid: 22510537].
Bergstrom C, Jensen I, Hagberg J, et al. Effectiveness of different interventions using a psychosocial subgroup assignment in chronic neck and back pain patients: a 10-year follow-up. Disabil Rehabil. 2012;34(2):110-8. Excluded: wrong population. [pmid: 21988525].
Bi X, Zhao J, Zhao L, et al. Pelvic floor muscle exercise for chronic low back pain. J Int Med Res. 2013;41(1):146-52. Excluded: sample size too small. [pmid: 23569140].
Bialosky JE, Bishop MD, Robinson ME, et al. Spinal manipulative therapy has an immediate effect on thermal pain sensitivity in people with low back pain: a randomized controlled trial. Phys Ther. 2009;89(12):1292-303. Excluded: wrong outcome. [pmid: 19797305].
Bigos SJ, Holland J, Holland C, et al. High-quality controlled trials on preventing episodes of back problems: systematic literature review in working-age adults. Spine J. 2009;9(2):147-68. Excluded: wrong population. [pmid: 19185272].
Binder A, Baron R, Schwittay A, et al. Safety/tolerability of tapentadol prolonged release (pr) versus oxycodone/naloxone pr for severe chronic low back pain with a neuropathic pain component. Pain pract. 2014. Conference: 7th World Congress of the World Institute of Pain, WIP 2014 Maastricht Netherlands. Conference Start: 20140507 Conference End: 20140510. Conference Publication:(var.pagings): 61. Excluded: not a study (letter, editorial, non-systematic review article).
Biondi D, Xiang J, Benson C, et al. Tapentadol immediate release versus oxycodone immediate release for treatment of acute low back pain. Pain physician. 2013;16(3):E237-46. Excluded: wrong comparison. [pmid: 23703422].
Bishop PB, Quon JA, Fisher CG, et al. The Chiropractic Hospital-based Interventions Research Outcomes (CHIRO) study: a randomized controlled trial on the effectiveness of clinical practice guidelines in the medical and chiropractic management of patients with acute mechanical low back pain. Spine J. 2010;10(12):1055-64. Excluded: wrong population. [pmid: 20889389].
Blodt S, Pach D, Kaster T, et al. Qigong versus exercise therapy for chronic low back pain in adults-a randomized controlled non-inferiority trial. J Altern Complement Med. 20(5):A52. Excluded: not a study (letter, editorial, non-systematic review article).
Bogefeldt J, Grunnesjo MI, Svardsudd K, et al. Sick leave reductions from a comprehensive manual therapy programme for low back pain: the Gotland Low Back Pain Study. Clin Rehabil. 2008;22(6):529-41. Excluded: wrong outcome. [pmid: 18511533].
Bonetti F, Curti S, Mattioli S, et al. Effectiveness of a ‘Global Postural Reeducation’ program for persistent low back pain: a non-randomized controlled trial. BMC Musculoskelet Disord. 2010;11:285. Excluded: sample size too small. [pmid: 21162726].
Borenstein DG, Korn S. Efficacy of a low-dose regimen of cyclobenzaprine hydrochloride in acute skeletal muscle spasm: results of two placebo-controlled trials. Clin Ther. 2003;25(4):1056-73. Excluded: wrong population. [pmid: 12809957].
Borkan JM, Koes B, Reis S, et al. A report from the Second International Forum for Primary Care Research on Low Back Pain. Reexamining priorities. Spine (Phila Pa 1976). 1998;23(18):1992-6. Excluded: wrong study deisgn for key question. [pmid: 9779533].
Bronfort G, Haas M, Evans R, et al. Evidence-informed management of chronic low back pain with spinal manipulation and mobilization. Spine J. 2008;8(1):213-25. Excluded: Pre-2007 systematic review or superseded by a more recent review. [pmid: 18164469].
Bronfort G, Haas M, Evans R, et al. Effectiveness of manual therapies: the UK evidence report. Chiropr Osteopat. 2010;18:3. Excluded: using original studies instead (e.g. meta-analysis, compiled study data, or data from another publication). [pmid: 20184717].
Brooks C, Kennedy S, Marshall PWM. Specific trunk and general exercise elicit similar changes in anticipatory postural adjustments in patients with chronic low back pain: a randomized controlled trial. Spine. 2012;37(25):E1543-50. Excluded: using original studies instead (e.g. meta-analysis, compiled study data, or data from another publication). [pmid: 22926279].
Brosseau L, Wells GA, Poitras S, et al. Ottawa Panel evidence-based clinical practice guidelines on therapeutic massage for low back pain. J Bodywork Mov Ther. 2012;16(4):424-55. Excluded: using original studies instead (e.g. meta-analysis, compiled study data, or data from another publication). [pmid: 23036876].
Brox JI, Sorensen R, Friis A, et al. Randomized clinical trial of lumbar instrumented fusion and cognitive intervention and exercises in patients with chronic low back pain and disc degeneration. Spine (Phila Pa 1976). 2003;28(17):1913-21. Excluded: wrong comparison. [pmid: 12973134].
Brox JI, Storheim K, Grotle M, et al. Systematic review of back schools, brief education, and fear-avoidance training for chronic low back pain. Spine J. 2008;8(6):948-58. Excluded: Pre-2007 systematic review or superseded by a more recent review. [pmid: 18024224].
Brox JI, Storheim K, Grotle M, et al. Evidence-informed management of chronic low back pain with back schools, brief education, and fear-avoidance training. Spine J. 2008;8(1):28-39. Excluded: Pre-2007 systematic review or superseded by a more recent review. [pmid: 18164451].
Bruce-Low S, Smith D, Burnet S, et al. One lumbar extension training session per week is sufficient for strength gains and reductions in pain in patients with chronic low back pain ergonomics. Ergonomics. 2012;55(4):500-7. Excluded: sample size too small. [pmid: 22397454].
Bruehl S, Burns JW, Chung OY, et al. Interacting effects of trait anger and acute anger arousal on pain: the role of endogenous opioids. Psychosom Med. 2011;73(7):612-9. Excluded: wrong outcome. [pmid: 21862829].
Bruehl S, Burns JW, Chung OY, et al. Anger management style and emotional reactivity to noxious stimuli among chronic pain patients and healthy controls: the role of endogenous opioids. Health Psychol. 2008;27(2):204-14. Excluded: wrong outcome. [pmid: 18377139].
Bruehl S, Burns JW, Gupta R, et al. Endogenous opioid inhibition of chronic low-back pain influences degree of back pain relief after morphine administration. Reg Anesth Pain Med. 2014;39(2):120-5. Excluded: wrong study deisgn for key question. [pmid: 24553304].
Brunner E, De Herdt A, Minguet P, et al. Can cognitive behavioural therapy based strategies be integrated into physiotherapy for the prevention of chronic low back pain? A systematic review. Disabil Rehabil. 2013;35(1):1-10. Excluded: using original studies instead (e.g. meta-analysis, compiled study data, or data from another publication). [pmid: 22607157].
Buechter RB, Fechtelpeter D. Climbing for preventing and treating health problems: a systematic review of randomized controlled trials. Ger Med Sci. 2011;9:Doc19. Excluded: using original studies instead (e.g. meta-analysis, compiled study data, or data from another publication). [pmid: 21863133].
Bunzli S, Gillham D, Esterman A. Physiotherapy-provided operant conditioning in the management of low back pain disability: A systematic review. Physiother Res Int. 2011;16(1):4-19. Excluded: wrong intervention. [pmid: 20310071].
Burke SM, Shorten GD. Perioperative pregabalin improves pain and functional outcomes 3 months after lumbar discectomy. Anesth Analg. 2010;110(4):1180-5. Excluded: wrong population. [pmid: 20103545].
Buynak R, Shapiro D, Okamoto A, et al. Efficacy, safety, and gastrointestinal tolerability of tapentadol ER in a randomized, double-blind, placebo- and active-controlled phase III study of patients with chronic low back pain. J Pain. 2009;10(4, Supplement 1):S48. Excluded: not a study (letter, editorial, non-systematic review article).
Calmels P, Jacob JF, Fayolle-Minon I, et al. Use of isokinetic techniques vs standard physiotherapy in patients with chronic low back pain. Preliminary results. Ann Readapt Med Phys. 2004;47(1):20-7. Excluded: not English language but possibly relevant. [pmid: 14967569].
Cambron JA, Duarte M, Dexheimer J, et al. Shoe orthotics for the treatment of chronic low back pain: a randomized controlled pilot study. J Manipulative Physiol Ther. 2011;34(4):254-60. Excluded: wrong intervention. [pmid: 21621727].
Carpenter KM, Stoner SA, Mundt JM, et al. An online self-help CBT intervention for chronic lower back pain. Clin J Pain. 2012;28(1):14-22. Excluded: wrong intervention. [pmid: 21681084].
Casserley-Feeney SN, Daly L, Hurley DA. The access randomized clinical trial of public versus private physiotherapy for low back pain. Spine. 2012;37(2):85-96. Excluded: wrong intervention. [pmid: 21289590].
Cawston H, Davie A, Paget M-A, et al. Efficacy of duloxetine versus alternative oral therapies: an indirect comparison of randomised clinical trials in chronic low back pain. Eur Spine J. 2013;22(9):1996-2009. Excluded: using original studies instead (e.g. meta-analysis, compiled study data, or data from another publication). [pmid: 23686477].
Cecchi F, Negrini S, Pasquini G, et al. Predictors of functional outcome in patients with chronic low back pain undergoing back school, individual physiotherapy or spinal manipulation. Eur J Phys Rehabil Med. 2012;48(3):371-8. Excluded: using original studies instead (e.g. meta-analysis, compiled study data, or data from another publication). [pmid: 22569488].
Cevik R, Bilici A, Gur A, et al. Effect of new traction technique of prone position on distraction of lumbar vertebrae and its relation with different application of heating therapy in low back pain. J Back Musculoskeletal Rehabil. 2007;20(2-3):71-7. Excluded: wrong study deisgn for key question.
Chan CW, Mok NW, Yeung EW. Aerobic exercise training in addition to conventional physiotherapy for chronic low back pain: a randomized controlled trial. Arch Phys Med Rehabil. 2011;92(10):1681-5. Excluded: sample size too small. [pmid: 21839983].
Chan HN, Fam J, Ng B-Y. Use of antidepressants in the treatment of chronic pain. Ann Acad Med Singapore. 2009;38(11):974-9. Excluded: using original studies instead (e.g. meta-analysis, compiled study data, or data from another publication). [pmid: 19956820].
Chang DH, Bae UY, Jung JH, et al. The effects of burning acupuncture therapy with Chuna therapy for low back pain patients. Journal of Oriental Rehabilitation Medicine. 2012;21(3):21-32. Excluded: not English language but possibly relevant.
Chang ST, Chen LC, Chang CC, et al. Efficacy and safety of piroxicam beta-cyclodextrin sachets for treating chronic low back pain: a randomized, parallel, active-controlled trial. Journal of medical sciences (Taipei, Taiwan). 2008;28(3):111-9. Excluded: wrong comparison.
Chang ST, Chen LC, Chang CC, et al. Effects of piroxicam-beta-cyclodextrin sachets on abnormal postural sway in patients with chronic low back pain. J Clin Pharm Ther. 2008;33(5):495-506. Excluded: wrong outcome. [pmid: 18834364].
Chaparro LE, Furlan AD, Deshpande A, et al. Opioids compared to placebo or other treatments for chronic low-back pain. Cochrane Database Syst Rev. 2013;8. CD004959. Excluded: using original studies instead (e.g. meta-analysis, compiled study data, or data from another publication). [pmid: 23983011].
Chaparro LE, Furlan AD, Deshpande A, et al. Opioids compared with placebo or other treatments for chronic low back pain: an update of the Cochrane Review. [Reprint of Cochrane Database Syst Rev. 2013;8:CD004959; PMID: 23983011]. Spine. 2014;39(7):556-63. Excluded: using original studies instead (e.g. meta-analysis, compiled study data, or data from another publication). [pmid: 24480962].
Charlusz M, Gasztych J, Irzmanski R, et al. Comparative analysis of analgesic efficacy of selected physiotherapy methods in low back pain patients. Ortop Tramatol Rehabil. 2010;12(3):225-36. Excluded: wrong study deisgn for key question. [pmid: 20675864].
Chen Y-W, Wang H-H. The effectiveness of acupressure on relieving pain: a systematic review. Pain Manag Nurs. 2014;15(2):539-50. Excluded: wrong population. [pmid: 23415783].
Chenot J-F, Becker A, Leonhardt C, et al. Use of complementary alternative medicine for low back pain consulting in general practice: a cohort study. BMC Altern Med. 2007;7:42. Excluded: wrong study deisgn for key question. [pmid: 18088435].
Childs JD, Teyhen DS, Van Wyngaarden JJ, et al. Predictors of web-based follow-up response in the Prevention Of Low Back Pain In The Military Trial (POLM). BMC Musculoskelet Disord. 2011;12:132. Excluded: wrong outcome. [pmid: 21668961].
Chilibeck PD, Vatanparast H, Cornish SM, et al. Evidence-based risk assessment and recommendations for physical activity: arthritis, osteoporosis, and low back pain. Appl Physiol Nutr Metab. Suppl 1. 2011;36:S49-79. Excluded: using original studies instead (e.g. meta-analysis, compiled study data, or data from another publication). [pmid: 21800948].
Choi KLB, Verbeek JH, Tam WW, et al. Exercises for prevention of recurrences of low-back pain. Cochrane Database Syst Rev. 2011;(2). Excluded: wrong outcome.
Chon S-C, You JH, Saliba SA. Cocontraction of ankle dorsiflexors and transversus abdominis function in patients with low back pain. J Athlet Train. 2012;47(4):379-89. Excluded: wrong outcome. [pmid: 22889653].
Chou R, Atlas SJ, Stanos SP, et al. Nonsurgical interventional therapies for low back pain: a review of the evidence for an American Pain Society clinical practice guideline. Spine. 2009;34(10):1078-93. Excluded: wrong intervention. [pmid: 19363456].
Chou R, Huffman LH, American Pain Society, et al. Nonpharmacologic therapies for acute and chronic low back pain: a review of the evidence for an American Pain Society/American College of Physicians clinical practice guideline. Ann Intern Med. 2007;147(7):492-504. Excluded: relevant to background only. [pmid: 17909210].
Christiansen S, Oettingen G, Dahme B, et al. A short goal-pursuit intervention to improve physical capacity: a randomized clinical trial in chronic back pain patients. Pain. 2010;149(3):444-52. Excluded: wrong population. [pmid: 20199846].
Chrubasik JE, Roufogalis BD, Chrubasik S. Evidence of effectiveness of herbal antiinflammatory drugs in the treatment of painful osteoarthritis and chronic low back pain. Phytother Res. 2007;21(7):675-83. Excluded: wrong population. [pmid: 17444576].
Chuang L-H, Soares MO, Tilbrook H, et al. A pragmatic multicentered randomized controlled trial of yoga for chronic low back pain: economic evaluation. Spine. 2012;37(18):1593-601. Excluded: wrong outcome. [pmid: 22433499].
Cifuentes M, Willetts J, Wasiak R. Health maintenance care in work-related low back pain and its association with disability recurrence. J Occup Environ Med. 2011;53(4):396-404. Excluded: wrong population. [pmid: 21407100].
Ciriello VM, Shaw WS, Rivard AJ, et al. Dynamic training of the lumbar musculature to prevent recurrence of acute low back pain: a randomized controlled trial using a daily pain recall for 1 year. Disabil Rehabil. 2012;34(19):1648-56. Excluded: wrong population. [pmid: 22380600].
Clinical Guideline Subcommittee on Low Back P, American Osteopathic A. American Osteopathic Association guidelines for osteopathic manipulative treatment (OMT) for patients with low back pain. J Am Osteopath Assoc. 2010;110(11):653-66. Excluded: Pre-2007 systematic review or superseded by a more recent review. [pmid: 21135197].
Cloutier C, Sutton I, Robinson L, et al. A randomized, placebo-controlled, titration-to-effect, crossover study of a combination of oxycodone and naloxone in patients with chronic low back pain. Pain Res Manag. Conference: 2010 Annual Conference of the Canadian Pain Society. Calgary, AB Canada. Conference Start: 20100512 Conference End: 20100515. Conference Publication:(var.pagings). 2010;15(2):103. Date of Publication: March-April 2010): April. Excluded: not a study (letter, editorial, non-systematic review article).
Codding C, Levinsky D, Hale M, et al. Analgesic efficacy and safety of controlled-release hydrocodone and acetaminophen tablets, dosed twice daily, for moderate to severe mechanical chronic low-back pain: A randomized, double-blind, placebo-controlled withdrawal trial. J Pain. 2008;9(4 Suppl):38. Excluded: not a study (letter, editorial, non-systematic review article).
Codding C, Levinsky D, Hale ME, et al. Efficacy and safety evaluation of 12 weeks extended-release hydrocodone/acetaminophen treatment in patients with chronic low back pain (CLBP) by prior opioid use. Pain Med. Conference: 25th Annual Meeting of the American Academy of Pain Medicine, AAPM. Honolulu, HI United States. Conference Start: 20090127 Conference End: 20090131. Conference Publication:(var.pagings). 2009;10(1):260. 2009. Date of Publication: January-February 2009):-February. Excluded: not a study (letter, editorial, non-systematic review article).
Colini Baldeschi G, Cobianchi MR. Study of codeine-paracetamol combination treatment compared with tramadol-paracetamol in the control of moderate-to-severe low back pain. Minerva Med. 2012;103(3):177-82. Excluded: not English language but possibly relevant. [pmid: 22653097].
Comer C, Redmond AC, Bird HA, et al. A home exercise programme is no more beneficial than advice and education for people with neurogenic claudication: results from a randomised controlled trial. PLoS ONE. 2013;8(9):e72878. Excluded: wrong population. [pmid: 24098633].
Constant F, Collin JF, Guillemin F, et al. Effectiveness of spa therapy in chronic low back pain: a randomized clinical trial. J Rheumatol. 1995;22(7):1315-20. Excluded: wrong intervention. [pmid: 7562765].
Constant F, Guillemin F, Collin JF, et al. Use of spa therapy to improve the quality of life of chronic low back pain patients. Med Care. 1998;36(9):1309-14. Excluded: wrong intervention. [pmid: 9749654].
Cook C, Cook A, Worrell T. Manual therapy provided by physical therapists in a hospital-based setting: a retrospective analysis. J Manipulative Physiol Ther. 2008;31(5):338-43. Excluded: wrong study deisgn for key question. [pmid: 18558275].
Cook C, Learman K, Showalter C, et al. Early use of thrust manipulation versus non-thrust manipulation: a randomized clinical trial. Manual Ther. 2013;18(3):191-8. Excluded: wrong comparison. [pmid: 23040656].
Cook CE, Showalter C, Kabbaz V, et al. Can a within/between-session change in pain during reassessment predict outcome using a manual therapy intervention in patients with mechanical low back pain?. Manual Ther. 2012;17(4):325-9. Excluded: wrong intervention. [pmid: 22445052].
Coppack RJ, Kristensen J, Karageorghis CI. Use of a goal setting intervention to increase adherence to low back pain rehabilitation: a randomized controlled trial. Clin Rehabil. 2012;26(11):1032-42. Excluded: wrong outcome. [pmid: 22357799].
Costa Lda C, Koes BW, Pransky G, et al. Primary care research priorities in low back pain: an update. Spine (Phila Pa 1976). 2013;38(2):148-56. Excluded: wrong study deisgn for key question. [pmid: 22781003].
Cox JM. A randomized controlled trial comparing 2 types of spinal manipulation and minimal conservative medical care for adults 55 years and older with subacute or chronic low back pain. J Manipulative Physiol Ther. 2009;32(7):601. Excluded: not a study (letter, editorial, non-systematic review article). [pmid: 19748413].
Cramer GD, Cambron J, Cantu JA, et al. Magnetic resonance imaging zygapophyseal joint space changes (gapping) in low back pain patients following spinal manipulation and side-posture positioning: a randomized controlled mechanisms trial with blinding. J Manipulative Physiol Ther. 2013;36(4):203-17. Excluded: wrong outcome. [pmid: 23648055].
Cramer H, Haller H, Lauche R, et al. Mindfulness-based stress reduction for low back pain. A systematic review. BMC Altern Med. 2012;12:162. Excluded: wrong intervention. [pmid: 23009599].
Cruser A, Maurer D, Hensel K, et al. A randomized, controlled trial of osteopathic manipulative treatment for acute low back pain in active duty military personnel. J Manual Manipulative Ther. 2012;20(1):5-15. Excluded: wrong population.
Cuesta-Vargas AI, Adams N, Salazar JA, et al. Deep water running and general practice in primary care for non-specific low back pain versus general practice alone: randomized controlled trial. Clin Rheumatol. 2012;31(7):1073-8. Excluded: wrong intervention. [pmid: 22453844].
Cuesta-Vargas AI, Garcia-Romero JC, Arroyo-Morales M, et al. Exercise, manual therapy, and education with or without high-intensity deep-water running for nonspecific chronic low back pain: a pragmatic randomized controlled trial. Am J Phys Med Rehabil. 2011;90(7):526-34. quiz 35-8. Excluded: wrong intervention. [pmid: 21765272].
Dagenais S, Gay RE, Tricco AC, et al. NASS Contemporary Concepts in Spine Care: spinal manipulation therapy for acute low back pain. Spine J. 2010;10(10):918-40. Excluded: Pre-2007 systematic review or superseded by a more recent review. [pmid: 20869008].
Dagenais S, Mayer J, Haldeman S, et al. Evidence-informed management of chronic low back pain with prolotherapy. Spine J. 2008;8(1):203-12. Excluded: wrong intervention. [pmid: 18164468].
Dagenais S, Mayer J, Wooley JR, et al. Evidence-informed management of chronic low back pain with medicine-assisted manipulation. Spine J. 2008;8(1):142-9. Excluded: Pre-2007 systematic review or superseded by a more recent review. [pmid: 18164462].
D'Amico M, Roncoletta P, Di Felice F, et al. LBP and lower limb discrepancy: 3D evaluation of postural rebalancing via underfoot wedge correction. Stud Health Technol Inform. 2012;176:108-12. Excluded: wrong intervention. [pmid: 22744470].
Dascanio V, Birks Y, Clark L, et al. Randomized cohort trial was shown to be feasible for evaluating treatments in low back pain. J Clin Epidemiol. 2014;67(8):940-6. Excluded: wrong study deisgn for key question. [pmid: 24836758].
Davies RA, Maher CG, Hancock MJ. A systematic review of paracetamol for non-specific low back pain. Eur Spine J. 2008;17(11):1423-30. Excluded: using original studies instead (e.g. meta-analysis, compiled study data, or data from another publication). [pmid: 18797937].
Davis M, Goforth HW, Gamier P. Oxycodone combined with opioid receptor antagonists: efficacy and safety. Expert Opin Drug Saf. 2013;12(3):389-402. Excluded: not a study (letter, editorial, non-systematic review article). [pmid: 23534906].
Davis MP, Srivastava M. Demographics, assessment and management of pain in the elderly. Drugs Aging. 2003;20(1):23-57. Excluded: wrong study deisgn for key question. [pmid: 12513114].
del Pozo-Cruz B, del Pozo-Cruz J, Adsuar JC, et al. Reanalysis of a tailored web-based exercise programme for office workers with sub-acute low back pain: assessing the stage of change in behaviour. Psychol Health Med. 2013;18(6):687-97. Excluded: wrong intervention. [pmid: 23398551].
del Pozo-Cruz B, Hernandez Mocholi MA, Adsuar JC, et al. Effects of whole body vibration therapy on main outcome measures for chronic non-specific low back pain: a single-blind randomized controlled trial. J Rehabil Med. 2011;43(8):689-94. Excluded: wrong intervention. [pmid: 21687923].
del Pozo-Cruz B, Parraca JA, del Pozo-Cruz J, et al. An occupational, internet-based intervention to prevent chronicity in subacute lower back pain: a randomised controlled trial. J Rehabil Med. 2012;44(7):581-7. Excluded: wrong intervention. [pmid: 22674240].
Delitto A, George SZ, Van Dillen LR, et al. Low back pain. J Orthop Sports Phys Ther. 2012;42(4):A1-57. Excluded: using original studies instead (e.g. meta-analysis, compiled study data, or data from another publication). [pmid: 22466247].
Denis A, Zelmar A, Le Pogam M-A, et al. The PRESLO study: evaluation of a global secondary low back pain prevention program for health care personnel in a hospital setting. Multicenter, randomized intervention trial. BMC Musculoskelet Disord. 2012;13:234. Excluded: not a study (letter, editorial, non-systematic review article). [pmid: 23181446].
Deshpande A, Furlan A, Mailis-Gagnon A, et al. Opioids for chronic low-back pain. Cochrane Database Syst Rev. 2007;(3). CD004959. Excluded: using original studies instead (e.g. meta-analysis, compiled study data, or data from another publication). [pmid: 17636781].
Dharmshaktu P, Tayal V, Kalra BS. Efficacy of antidepressants as analgesics: a review. J Clin Pharmacol. 2012;52(1):6-17. Excluded: wrong population. [pmid: 21415285].
Di Lorenzo L, Forte A, Formisano R, et al. Low back pain after unstable extracapsular hip fractures: randomized control trial on a specific training. Eur. 2007;43(3):349-57. Excluded: wrong population. [pmid: 17595600].
Diaz Arribas MJ, Ramos Sanchez M, Pardo Hervas P, et al. Effectiveness of the physical therapy Godelive Denys-Struyf method for nonspecific low back pain: primary care randomized control trial. Spine. 2009;34(15):1529-38. Excluded: wrong intervention. [pmid: 19564761].
Diaz-Arribas MJ, Kovacs FM, Royuela A, et al. Effectiveness of the Godelieve Denys-Struyf (GDS) method in people with low back pain: cluster randomized controlled trial. Phys Ther. 2015;95(3):319-36. Excluded: wrong intervention. [pmid: 25359444].
Dogan M, Sahin O, Elden H, et al. Additional therapeutic effect of balneotherapy in low back pain. South Med J. 2011;104(8):574-8. Excluded: wrong intervention. [pmid: 21886066].
Domenech J, Banos R, Penalver L, et al. Design considerations of a randomized clinical trial on a cognitive behavioural intervention using communication and information technologies for managing chronic low back pain. BMC Musculoskelet Disord. 2013;14:142. Excluded: not a study (letter, editorial, non-systematic review article). [pmid: 23607895].
Donaldson M, Learman K, O'Halloran B, et al. The role of patients' expectation of appropriate initial manual therapy treatment in outcomes for patients with low back pain. J Manipulative Physiol Ther. 2013;36(5):276-83. Excluded: using original studies instead (e.g. meta-analysis, compiled study data, or data from another publication). [pmid: 23829882].
Donelson R. Improving spine care using mechanical diagnosis and therapy. SpineLine. 2012. September/October. PMID. Excluded: wrong outcome.
Dougherty PE, Karuza J, Savino D, et al. Evaluation of a modified clinical prediction rule for use with spinal manipulative therapy in patients with chronic low back pain: a randomized clinical trial. Chiropr Man Therap. 2014;22(1):41. Excluded: wrong intervention. [pmid: 25426289].
Dufour N, Thamsborg G, Oefeldt A, et al. Treatment of chronic low back pain: a randomized, clinical trial comparing group-based multidisciplinary biopsychosocial rehabilitation and intensive individual therapist-assisted back muscle strengthening exercises. Spine. 2010;35(5):469-76. Excluded: wrong intervention. [pmid: 20147878].
Dundar U, Solak O, Yigit I, et al. Clinical effectiveness of aquatic exercise to treat chronic low back pain: a randomized controlled trial. Spine. 2009;34(14):1436-40. Excluded: wrong intervention. [pmid: 19525833].
Dworkin RH, Turk DC, McDermott MP, et al. Interpreting the clinical importance of group differences in chronic pain clinical trials: IMMPACT recommendations. Pain. 2009;146(3):238-44. Excluded: not a study (letter, editorial, non-systematic review article). [pmid: 19836888].
Dwornik M, Kujawa J, Bialoszewski D, et al. Electromyographic and clinical evaluation of the efficacy of neuromobilization in patients with low back pain. Ortop Tramatol Rehabil. 2009;11(2):164-76. Excluded: wrong study deisgn for key question. [pmid: 19502673].
Eardley S, Brien S, Little P, et al. Professional kinesiology practice for chronic low back pain: single-blind, randomised controlled pilot study. Forsch Komplementarmed. 2013;20(3):180-8. Excluded: wrong intervention. [pmid: 23860019].
Ebadi S, Ansari NN, Henschke N, et al. The effect of continuous ultrasound on chronic low back pain: protocol of a randomized controlled trial. BMC Musculoskelet Disord. 2011;12:59. Excluded: not a study (letter, editorial, non-systematic review article). [pmid: 21406117].
Ebadi S, Ansari NN, Naghdi S, et al. A study of therapeutic ultrasound and exercise treatment for muscle fatigue in patients with chronic non specific low back pain: a preliminary report. J Back Musculoskeletal Rehabil. 2013;26(2):221-6. Excluded: wrong study deisgn for key question. [pmid: 23640325].
Egan S, Saper R. Predictors of adherence to treatment for chronic low back pain in a 12-week RCT comparing Yoga, physical therapy, and education. J Altern Complement Med. Conference: International Research Congress on Integrative Medicine and Health, IRCIMH 2014. Miami, FL United States. Conference Start: 20140513 Conference End: 20140516. Conference Publication:(var.pagings). 2014:A56. Excluded: not a study (letter, editorial, non-systematic review article).
Eisenberg DM, Post DE, Davis RB, et al. Addition of choice of complementary therapies to usual care for acute low back pain: a randomized controlled trial. Spine. 2007;32(2):151-8. Excluded: wrong intervention. [pmid: 17224808].
Eken C, Serinken M, Elicabuk H, et al. Intravenous paracetamol versus dexketoprofen versus morphine in acute mechanical low back pain in the emergency department: a randomised double-blind controlled trial. Emerg Med J. 2014;31(3):177-81. Excluded: wrong intervention. [pmid: 23407378].
Engbert K, Weber M. The effects of therapeutic climbing in patients with chronic low back pain: a randomized controlled study. Spine. 2011;36(11):842-9. Excluded: sample size too small. [pmid: 21192296].
Engel A. All failures count. Pain Med. 2015;16(2):404. Excluded: not a study (letter, editorial, non-systematic review article). [pmid: 25530072].
Engers AJ, Jellema P, Wensing M, et al. Individual patient education for low back pain. Cochrane Database Syst Rev. 2011;(2). Excluded: wrong intervention.
Ergun H, Polat O, Demirkan NA, et al. The efficacy, safety, and pharmacokinetics of intramuscular and oral phenyramidol in patients with low back pain in an emergency department. Turk J Med Sci. 2010;40(1):71-6. Excluded: wrong intervention.
Ernst E. The complexity of complementary medicine: chiropractic for back pain. Clin Rheumatol. 2005;24(5):445-6. Excluded: not a study (letter, editorial, non-systematic review article). [pmid: 16328602].
Etropolski M, Kuperwasser B, Flugel M, et al. Safety and tolerability of tapentadol extended release in moderate to severe chronic osteoarthritis or low back pain management: pooled analysis of randomized controlled trials. Adv Ther. 2014;31(6):604-20. Excluded: wrong population. [pmid: 24985410].
Etropolski M, Lange B, Goldberg J, et al. A pooled analysis of patient-specific factors and efficacy and tolerability of tapentadol extended release treatment for moderate to severe chronic pain. J Opioid Manag. 2013;9(5):343-56. Excluded: wrong study deisgn for key question. [pmid: 24353047].
Etropolski M, Shapiro DY, Okamoto A, et al. Tolerability of equivalent doses of tapentadol immediate release (IR) and tapentadol extended release (ER) in a crossover study of patients with moderate-to-severe chronic low back pain. Pain Med. Conference: 26th Annual Meeting of the American Academy of Pain Medicine, AAPM. San Antonio, TX United States. Conference Start: 20100203 Conference End: 20100206. Conference Publication. 2010;11(2):287-8. Excluded: not a study (letter, editorial, non-systematic review article).
Etropolski MS, Okamoto A, Shapiro DY, et al. Dose conversion between tapentadol immediate and extended release for low back pain. Pain physician. 2010;13(1):61-70. Excluded: wrong study deisgn for key question. [pmid: 20119464].
Evans DD, Carter M, Panico R, et al. Characteristics and predictors of short-term outcomes in individuals self-selecting yoga or physical therapy for treatment of chronic low back pain. Pm R. 2010;2(11):1006-15. Excluded: wrong study deisgn for key question. [pmid: 21093836].
Ewert T, Limm H, Wessels T, et al. The comparative effectiveness of a multimodal program versus exercise alone for the secondary prevention of chronic low back pain and disability. Pm R. 2009;1(9):798-808. Excluded: wrong population. [pmid: 19769912].
Farhadi K, Schwebel DC, Saeb M, et al. The effectiveness of wet-cupping for nonspecific low back pain in Iran: a randomized controlled trial. Complement Ther Med. 2009;17(1):9-15. Excluded: wrong intervention. [pmid: 19114223].
Feng Y, Gao Y, Yang W, et al. Reduction in nerve root compression by the nucleus pulposus after Feng's spinal manipulation. Neural Regen Res. 2013;8(12):1139-45. Excluded: wrong intervention. [pmid: 25206408].
Ferrari R. A cohort-controlled trial of the addition of customized foot orthotics to standard care in fibromyalgia. Clin Rheumatol. 2012;31(7):1041-5. Excluded: wrong population. [pmid: 22426704].
Ferrari R. Effect of customized foot orthotics in addition to usual care for the management of chronic low back pain following work-related low back injury. J Manipulative Physiol Ther. 2013;36(6):359-63. Excluded: wrong intervention. [pmid: 23830710].
Ferreira ML, Smeets RJEM, Kamper SJ, et al. Can we explain heterogeneity among randomized clinical trials of exercise for chronic back pain? A meta-regression analysis of randomized controlled trials. Phys Ther. 2010;90(10):1383-403. Excluded: relevant to background only. [pmid: 20671101].
Ferreira PH, Ferreira ML, Maher CG, et al. The therapeutic alliance between clinicians and patients predicts outcome in chronic low back pain. Phys Ther. 2013;93(4):470-8. Excluded: wrong intervention. [pmid: 23139428].
Finan PH, Burns JW, Jensen MP, et al. Pain coping but not readiness to change is associated with pretreatment pain-related functioning. Clin J Pain. 2012;28(8):687-92. Excluded: wrong intervention. [pmid: 22688600].
Foster L, Clapp L, Erickson M, et al. Botulinum toxin A and chronic low back pain: a randomized, double-blind study. Neurology. 2001;56(10):1290-3. Excluded: wrong intervention. [pmid: 11376175].
Franca FR, Burke TN, Caffaro RR, et al. Effects of muscular stretching and segmental stabilization on functional disability and pain in patients with chronic low back pain: a randomized, controlled trial. J Manipulative Physiol Ther. 2012;35(4):279-85. Excluded: using original studies instead (e.g. meta-analysis, compiled study data, or data from another publication). [pmid: 22632587].
Franke H, Fryer G, Ostelo WJGR, et al. Muscle energy technique for non-specific low-back pain. Cochrane Database Syst Rev. 2015;(2). Excluded: wrong intervention.
Friedmann N, Klutzaritz V, Webster L. Long-term safety of Remoxy (extended-release oxycodone) in patients with moderate to severe chronic osteoarthritis or low back pain. Pain Med. 2011;12(5):755-60. Excluded: wrong population. [pmid: 21481168].
Fuentes J, Armijo-Olivo S, Funabashi M, et al. Enhanced therapeutic alliance modulates pain intensity and muscle pain sensitivity in patients with chronic low back pain: an experimental controlled study. Phys Ther. 2014;94(4):477-89. Excluded: wrong intervention. [pmid: 24309616].
Fulga I, Lupescu O, Spircu T. Local tolerability and effectiveness of Ketospray 10% cutaneous spray solution. Panminerva Med. 2012;54(1 Suppl 4):23-33. Excluded: wrong population. [pmid: 23241932].
Furlan AD, Imamura M, Dryden T, et al. Massage for low-back pain. Cochrane Database Syst Rev. 2008;(4). CD001929. Excluded: Pre-2007 systematic review or superseded by a more recent review. [pmid: 18843627].
Furlan AD, Imamura M, Dryden T, et al. Massage for low back pain: an updated systematic review within the framework of the Cochrane Back Review Group. [Reprint of Cochrane Database Syst Rev. 2008;(4):CD001929; PMID: 18843627]. Spine. 2009;34(16):1669-84. Excluded: Pre-2007 systematic review or superseded by a more recent review. [pmid: 19561560].
Furlan AD, van Tulder MW, Cherkin D, et al. Acupuncture and dry-needling for low back pain. Cochrane Database Syst Rev. 2011;(2). Excluded: Pre-2007 systematic review or superseded by a more recent review.
Furlan AD, Yazdi F, Tsertsvadze A, et al. Complementary and alternative therapies for back pain II. Evid rep/technol assess. 2010;(194):1-764. Excluded: Pre-2007 systematic review or superseded by a more recent review. [pmid: 23126534].
Furlan AD, Yazdi F, Tsertsvadze A, et al. A systematic review and meta-analysis of efficacy, cost-effectiveness, and safety of selected complementary and alternative medicine for neck and low-back pain. Evid Based Complement Alternat Med. 2012;2012:953139. Excluded: Pre-2007 systematic review or superseded by a more recent review. [pmid: 22203884].
Gadsby GJ, Flowerdew M. Transcutaneous electrical nerve stimulation and acupuncture-like transcutaneous electrical nerve stimulation for chronic low back pain. Cochrane Database Syst Rev. 2006;(4). Excluded: not a study (letter, editorial, non-systematic review article).
Gagnier JJ. Evidence-informed management of chronic low back pain with herbal, vitamin, mineral, and homeopathic supplements. Spine J. 2008;8(1):70-9. Excluded: wrong intervention. [pmid: 18164456].
Gagnier JJ, van Tulder MW, Berman BM, et al. Herbal medicine for low back pain. Cochrane Database Syst Rev. 2011;(2). Excluded: wrong intervention.
Galvez R, Schafer M, Hans G, et al. Tapentadol prolonged release versus strong opioids for severe, chronic low back pain: results of an open-label, phase 3b study. Adv Ther. 2013;30(3):229-59. Excluded: wrong study deisgn for key question. [pmid: 23475406].
Garcia AN, Gondo FLB, Costa RA, et al. Effects of two physical therapy interventions in patients with chronic non-specific low back pain: feasibility of a randomized controlled trial. Rev Bras Fisioter. 2011;15(5):420-7. Excluded: not a study (letter, editorial, non-systematic review article). [pmid: 22002187].
Garfin SR, Pye SA. Bed design and its effect on chronic low back pain--a limited controlled trial. Pain. 1981;10(1):87-91. Excluded: wrong intervention. [pmid: 6453325].
Garra G, Singer AJ, Leno R, et al. Heat or cold packs for neck and back strain: a randomized controlled trial of efficacy. Acad Emerg Med. 2010;17(5):484-9. Excluded: wrong population. [pmid: 20536800].
Gatchel RJ, Mayer TG. Evidence-informed management of chronic low back pain with functional restoration. Spine J. 2008;8(1):65-9. Excluded: not a study (letter, editorial, non-systematic review article). [pmid: 18164455].
Gatti A, Sabato AF, Carucci A, et al. Adequacy assessment of oxycodone/paracetamol (acetaminophen) in multimodal chronic pain : a prospective observational study. Clin Drug Invest. Suppl 1. 2009;29:31-40. Excluded: wrong study deisgn for key question. [pmid: 19445553].
Gatti A, Sabato AF, Occhioni R, et al. Controlled-release oxycodone and pregabalin in the treatment of neuropathic pain: results of a multicenter Italian study. Eur Neurol. 2009;61(3):129-37. Excluded: wrong population. [pmid: 19092248].
Gatti R, Faccendini S, Tettamanti A, et al. Efficacy of trunk balance exercises for individuals with chronic low back pain: a randomized clinical trial. J Orthop Sports Phys Ther. 2011;41(8):542-52. Excluded: sample size too small. [pmid: 21654092].
Gay RE, Brault JS. Evidence-informed management of chronic low back pain with traction therapy. Spine J. 2008;8(1):234-42. Excluded: Pre-2007 systematic review or superseded by a more recent review. [pmid: 18164471].
George SZ, Childs JD, Teyhen DS, et al. Rationale, design, and protocol for the prevention of low back pain in the military (POLM) trial (NCT00373009). BMC Musculoskelet Disord. 2007;8:92. Excluded: not a study (letter, editorial, non-systematic review article). [pmid: 17868436].
George SZ, Fritz JM, Childs JD. Investigation of elevated fear-avoidance beliefs for patients with low back pain: a secondary analysis involving patients enrolled in physical therapy clinical trials. J Orthop Sports Phys Ther. 2008;38(2):50-8. Excluded: wrong study deisgn for key question. [pmid: 18349490].
George SZ, Robinson ME. Preference, expectation, and satisfaction in a clinical trial of behavioral interventions for acute and sub-acute low back pain. J Pain. 2010;11(11):1074-82. Excluded: wrong study deisgn for key question. [pmid: 20466596].
George SZ, Wittmer VT, Fillingim RB, et al. Comparison of graded exercise and graded exposure clinical outcomes for patients with chronic low back pain. J Orthop Sports Phys Ther. 2010;40(11):694-704. Excluded: sample size too small. [pmid: 20972340].
Giannetti BM, Staiger C, Bulitta M, et al. Efficacy and safety of comfrey root extract ointment in the treatment of acute upper or lower back pain: results of a double-blind, randomised, placebo controlled, multicentre trial. BJSM online. 2010;44(9):637-41. Excluded: wrong intervention. [pmid: 19460762].
Gilbert JR, Taylor DW, Hildebrand A, et al. Clinical trial of common treatments for low back pain in family practice. Br Med J (Clin Res Ed). 1985;291(6498):791-4. Excluded: wrong population. [pmid: 2931153].
Glazov G. The influence of baseline characteristics on response to a laser acupuncture intervention: an exploratory analysis. Acupunct Med. 2010;28(1):6-11. Excluded: wrong study deisgn for key question. [pmid: 20351369].
Glazov G, Schattner P, Lopez D, et al. Laser acupuncture for chronic non-specific low back pain: a controlled clinical trial. Acupunct Med. 2009;27(3):94-100. Excluded: wrong intervention. [pmid: 19734378].
Glazov G, Yelland M, Emery J. Low-dose laser acupuncture for non-specific chronic low back pain: a double-blind randomised controlled trial. Acupunct Med. 2014;32(2):116-23. Excluded: wrong intervention. [pmid: 24280948].
Goertz CM, Pohlman KA, Vining RD, et al. Patient-centered outcomes of high-velocity, low-amplitude spinal manipulation for low back pain: a systematic review. J Electromyogr Kinesiol. 2012;22(5):670-91. Excluded: Pre-2007 systematic review or superseded by a more recent review. [pmid: 22534288].
Goforth HW, Preud'homme XA, Krystal AD. A randomized, double-blind, placebo-controlled trial of eszopiclone for the treatment of insomnia in patients with chronic low back pain. Sleep. 2014;37(6):1053-60. Excluded: wrong intervention. [pmid: 24882900].
Gonzalez-Iglesias J, Fernandez-de-Las-Penas C, Cleland JA, et al. Short-term effects of cervical kinesio taping on pain and cervical range of motion in patients with acute whiplash injury: a randomized clinical trial. J Orthop Sports Phys Ther. 2009;39(7):515-21. Excluded: wrong population. [pmid: 19574662].
Gordon A, Callaghan D, Spink D, et al. A randomized, double-blind, crossover comparison of buprenorphine transdermal system (BTDS) and placebo in patients with chronic low back pain. JPTCP. 2010. Excluded: not a study (letter, editorial, non-systematic review article).
Gordon A, Rashiq S, Moulin DE, et al. Buprenorphine transdermal system for opioid therapy in patients with chronic low back pain. Pain Res Manag. 2010;15(3):169-78. Excluded: inadequate duration. [pmid: 20577660].
Gore M, Sadosky AB, Leslie DL, et al. Therapy switching, augmentation, and discontinuation in patients with osteoarthritis and chronic low back pain. Pain pract. 2012;12(6):457-68. Excluded: wrong outcome. [pmid: 22230466].
Gotzsche PC. NSAIDs. Clin Evid (Online). 2010. Excluded: not a study (letter, editorial, non-systematic review article). [pmid: 21733202].
Gould EM, Jensen MP, Victor TW, et al. The pain quality response profile of oxymorphone extended release in the treatment of low back pain. Clin J Pain. 2009;25(2):116-22. Excluded: using original studies instead (e.g. meta-analysis, compiled study data, or data from another publication). [pmid: 19333156].
Green J, Dain B, Munera C, et al. A randomized, double-blind, placebo-controlled, multicenter trial to assess the efficacy and safety of oxycodone/ naloxone extended-release tablets (OXN) in opioid-experienced subjects with chronic low back pain. J Pain. Conference: 33rd Annual Scientific Meeting of the American Pain Society. Tampa, FL United States. Conference Start: 20140430 Conference End: 20140503. Conference Publication:(var.pagings). 2014:S89. Excluded: not a study (letter, editorial, non-systematic review article).
Gregg CD, Hoffman CW, Hall H, et al. Outcomes of an interdisciplinary rehabilitation programme for the management of chronic low back pain. J Prim Health Care. 2011;3(3):222-7. Excluded: wrong outcome. [pmid: 21892425].
Gremeaux V, Benaim C, Poiraudeau S, et al. Evaluation of the benefits of low back pain patients' education workshops during spa therapy. Joint Bone Spine. 2013;80(1):82-7. Excluded: wrong intervention. [pmid: 22342470].
Grunnesjo MI, Bogefeldt JP, Blomberg SIE, et al. A randomized controlled trial of the effects of muscle stretching, manual therapy and steroid injections in addition to ‘stay active’ care on health-related quality of life in acute or subacute low back pain. Clin Rehabil. 2011;25(11):999-1010. Excluded: wrong outcome. [pmid: 21831926].
Guillemin F, Constant F, Collin JF, et al. Short and long-term effect of spa therapy in chronic low back pain. Br J Rheumatol. 1994;33(2):148-51. Excluded: wrong intervention. [pmid: 8162480].
Gupta RK, Bruehl S, Burns JW, et al. Relationship between endogenous opioid function and opioid analgesic adverse effects. Reg Anesth Pain Med. 2014;39(3):219-24. Excluded: wrong study deisgn for key question. [pmid: 24682081].
Haas M, Vavrek D, Peterson D, et al. Dose response of spinal manipulation for low back pain: Short-term outcomes from a randomized trial. Clin Chiropr. 2011;14(4):154. Excluded: using original studies instead (e.g. meta-analysis, compiled study data, or data from another publication).
Hagen E, Grasdal A, Eriksen HR. Does early intervention with a light mobilization program reduce long-term sick leave for low back pain: a 3-year follow-up study. Spine (Phila Pa 1976). 2003;28(20):2309-15. discussion 16. Excluded: wrong intervention. [pmid: 14560075].
Hahne AJ, Ford JJ, McMeeken JM. Conservative management of lumbar disc herniation with associated radiculopathy: a systematic review. Spine. 2010;35(11):E488-504. Excluded: wrong intervention. [pmid: 20421859].
Haladay DE, Miller SJ, Challis J, et al. Quality of systematic reviews on specific spinal stabilization exercise for chronic low back pain. J Orthop Sports Phys Ther. 2013;43(4):242-50. Excluded: wrong study deisgn for key question. [pmid: 23321935].
Haldavnekar RV, Tekur P, Nagarathna R, et al. Effect of yogic colon cleansing (Laghu Sankhaprakshalana Kriya) on pain, spinal flexibility, disability and state anxiety in chronic low back pain. Int J Yoga. 2014;7(2):111-9. Excluded: wrong study deisgn for key question. [pmid: 25035620].
Hale M, D'Andrea D, Yang R, et al. Efficacy and tolerability of hydrocodone extended-release tablets for the treatment of moderate to severe pain in opioid-treated patients with osteoarthritis or low back pain. J Pain. Conference: 31st Annual Scientific Meeting of the American Pain Society. Honolulu, HI United States. Conference Start: 20120516 Conference End: 20120519. Conference Publication:(var.pagings). 2012:S84. Excluded: not a study (letter, editorial, non-systematic review article).
Hale M, Upmalis D, Okamoto A, et al. Tolerability of tapentadol immediate release in patients with lower back pain or osteoarthritis of the hip or knee over 90 days: a randomized, double-blind study. Curr Med Res Opin. 2009;25(5):1095-104. Excluded: wrong population. [pmid: 19301989].
Hale ME, Fleischmann R, Salzman R, et al. Efficacy and safety of controlled-release versus immediate-release oxycodone: randomized, double-blind evaluation in patients with chronic back pain. Clin J Pain. 1999;15(3):179-83. Excluded: wrong comparison. [pmid: 10524470].
Hale ME, Nalamachu SR, Khan A, et al. Effectiveness and gastrointestinal tolerability during conversion and titration with once-daily OROS hydromorphone extended release in opioid-tolerant patients with chronic low back pain. J Pain Res. 2013;6:319-29. Excluded: wrong study deisgn for key question. [pmid: 23658495].
Hall H, McIntosh G, Boyle C. Effectiveness of a low back pain classification system. Spine J. 2009;9(8):648-57. Excluded: wrong intervention. [pmid: 19501026].
Hall S, Lewith G, Brien S, et al. An exploratory pilot study to design and assess the credibility of a sham kinesiology treatment. Forsch Komplementarmed. 2008;15(6):321-6. Excluded: wrong study deisgn for key question. [pmid: 19142041].
Hamre HJ, Witt CM, Glockmann A, et al. Anthroposophic vs. conventional therapy for chronic low back pain: a prospective comparative study. Eur J Med Res. 2007;12(7):302-10. Excluded: not a study (letter, editorial, non-systematic review article). [pmid: 17933703].
Han X, Ma W-Z, Wang W-Y. Randomized controlled trails for “equilibrium-acupuncture” treatment of lumbar pain in patients with lumbar intervertebral disc prolapse. Chen Tzu Yen Chiu. 2013;38(1):57-63. Excluded: not English language but possibly relevant. [pmid: 23650802].
Hancock MJ, Maher CG, Cleland JA, Fritz JM, Kulig K, et al. Comparison of the effectiveness of three manual physical therapy techniques in a subgroup of patients with low back pain who satisfy a clinical prediction rule. A randomized clinical trial. Spine. 2009;34:2720-9. Spine. 2010;35(7):839; author reply -40. Excluded: not a study (letter, editorial, non-systematic review article). [pmid: 19940729].
Hancock MJ, Maher CG, Latimer J, et al. Independent evaluation of a clinical prediction rule for spinal manipulative therapy: a randomised controlled trial. Eur Spine J. 2008;17(7):936-43. Excluded: using original studies instead (e.g. meta-analysis, compiled study data, or data from another publication). [pmid: 18427840].
Hancock MJ, Maher CG, Latimer J, et al. Can predictors of response to NSAIDs be identified in patients with acute low back pain?. Clin J Pain. 2009;25(8):659-65. Excluded: wrong outcome. [pmid: 19920714].
Haroutiunian S, Drennan DA, Lipman AG. Topical NSAID therapy for musculoskeletal pain. Pain Med. 2010;11(4):535-49. Excluded: wrong population. [pmid: 20210866].
Hart DL, Werneke MW, et al. On “motor control exercise for chronic low back pain..”Costa LOP, Maher CG, Latimer J, etal.Phys Ther.2009;89:1275-1286. Phys Ther. 2010;90(2):308-10. author reply 10-1. Excluded: not a study (letter, editorial, non-systematic review article). [pmid: 20123694].
Harte AA, Baxter GD, Gracey JH. To evaluate the effectiveness of traction in the management of lumbosacral radiculopathy. [abstract]. BJJ. 2008;90-B(SUPP_II):218. Excluded: not a study (letter, editorial, non-systematic review article).
Harts CC, Helmhout PH, de Bie RA, et al. A high-intensity lumbar extensor strengthening program is little better than a low-intensity program or a waiting list control group for chronic low back pain: a randomised clinical trial. Aust J Physiother. 2008;54(1):23-31. Excluded: sample size too small. [pmid: 18298356].
Hasegawa M, Horiki N, Tanaka K, et al. The efficacy of rebamipide add-on therapy in arthritic patients with COX-2 selective inhibitor-related gastrointestinal events: a prospective, randomized, open-label blinded-endpoint pilot study by the GLORIA study group. Mod Rheumatol. 2013;23(6):1172-8. Excluded: wrong population. [pmid: 23306427].
Hawk C, Long CR, Rowell RM, et al. A randomized trial investigating a chiropractic manual placebo: a novel design using standardized forces in the delivery of active and control treatments. J Altern Complement Med. 2005;11(1):109-17. Excluded: wrong intervention. [pmid: 15750369].
Hay EM, Mullis R, Lewis M, et al. Comparison of physical treatments versus a brief pain-management programme for back pain in primary care: a randomised clinical trial in physiotherapy practice. Lancet. 2005;365(9476):2024-30. Excluded: wrong intervention. [pmid: 15950716].
Hayden J, van Tulder MW, Malmivaara A, et al. Exercise therapy for treatment of non-specific low back pain. Cochrane Database Syst Rev. 2011;(2). Excluded: using original studies instead (e.g. meta-analysis, compiled study data, or data from another publication).
Hayden JA, Dunn KM, van der Windt DA, et al. What is the prognosis of back pain?. Best Pract Res Clin Rheumatol. 2010;24(2):167-79. Excluded: not a study (letter, editorial, non-systematic review article). [pmid: 20227639].
Hebert EP, Landin D. Effects of a learning model and augmented feedback on tennis skill acquisition. Res Q Exerc Sport. 1994;65(3):250-7. Excluded: wrong population. [pmid: 7973074].
Hebert JJ, Koppenhaver SL, Walker BF. Subgrouping patients with low back pain: a treatment-based approach to classification. Sports health. 2011;3(6):534-42. Excluded: wrong intervention. [pmid: 23016055].
Henchoz Y, Kai-Lik So A. Exercise and nonspecific low back pain: a literature review. Joint Bone Spine. 2008;75(5):533-9. Excluded: not a study (letter, editorial, non-systematic review article). [pmid: 18801686].
Hendrick P, Te Wake AM, Tikkisetty AS, et al. The effectiveness of walking as an intervention for low back pain: a systematic review. Eur Spine J. 2010;19(10):1613-20. Excluded: using original studies instead (e.g. meta-analysis, compiled study data, or data from another publication). [pmid: 20414688].
Henry SM, Westervelt KC. The use of real-time ultrasound feedback in teaching abdominal hollowing exercises to healthy subjects. J Orthop Sports Phys Ther. 2005;35(6):338-45. Excluded: wrong population. [pmid: 16001905].
Hentschke C, Hofmann J, Pfeifer K. A bio-psycho-social exercise program (RUCKGEWINN) for chronic low back pain in rehabilitation aftercare--study protocol for a randomised controlled trial. BMC Musculoskelet Disord. 2010;11:266. Excluded: not a study (letter, editorial, non-systematic review article). [pmid: 21083918].
Hertzman-Miller RP, Morgenstern H, Hurwitz EL, et al. Comparing the satisfaction of low back pain patients randomized to receive medical or chiropractic care: results from the UCLA low-back pain study. Am J Public Health. 2002;92(10):1628-33. Excluded: wrong outcome. [pmid: 12356612].
Heymans MW, de Vet HC, Bongers PM, et al. The effectiveness of high-intensity versus low-intensity back schools in an occupational setting: a pragmatic randomized controlled trial. Spine (Phila Pa 1976). 2006;31(10):1075-82. Excluded: wrong intervention. [pmid: 16648740].
Heymans MW, van Tulder MW, Esmail R, et al. Back schools for non-specific low-back pain. Cochrane Database Syst Rev. 2011;(2). Excluded: Pre-2007 systematic review or superseded by a more recent review.
Hidalgo B, Detrembleur C, Hall T, et al. The efficacy of manual therapy and exercise for different stages of non-specific low back pain: an update of systematic reviews. J Manual Manipulative Ther. 2014;22(2):59-74. Excluded: relevant to background only. [pmid: 24976749].
Hides JA, Lambrecht G, Richardson CA, et al. The effects of rehabilitation on the muscles of the trunk following prolonged bed rest. [Erratum appears in Eur Spine J. 2011 May;20(5):819]. Eur Spine J. 2011;20(5):808-18. Excluded: wrong population. [pmid: 20593204].
Hilde G, Hagen BK, Jamtvedt G, et al. Advice to stay active as a single treatment for low-back pain and sciatica. Cochrane Database Syst Rev. 2006;(2). Excluded: not a study (letter, editorial, non-systematic review article).
Hirota S, et al. Trigger point acupuncture treatment for chronic low back pain in elderly patients. The Bulletin of Meiji University of Oriental Medicine. 2007;38:19-26. Excluded: not English language but possibly relevant.
Hofferberth B, Gottschaldt M, Grass H, et al. The usefulness of dexamethasonephosphate in the conservative treatment of lumbar pain--a double-blind study (author's transl). Arch Psychiatr Nervenkr. 1982;231(4):359-67. Excluded: not English language but possibly relevant. [pmid: 6214237].
Hoffman SL, Johnson MB, Zou D, et al. Effect of classification-specific treatment on lumbopelvic motion during hip rotation in people with low back pain. Manual Ther. 2011;16(4):344-50. Excluded: wrong outcome. [pmid: 21256073].
Hofmann J, Peters S, Geidl W, et al. Effects of behavioural exercise therapy on the effectiveness of a multidisciplinary rehabilitation for chronic non-specific low back pain: study protocol for a randomised controlled trial. BMC Musculoskelet Disord. 2013;14:89. Excluded: not a study (letter, editorial, non-systematic review article). [pmid: 23496822].
Holguin N, Muir J, Rubin C, et al. Short applications of very low-magnitude vibrations attenuate expansion of the intervertebral disc during extended bed rest. Spine J. 2009;9(6):470-7. Excluded: wrong intervention. [pmid: 19356986].
Holtzman S, Beggs RT. Yoga for chronic low back pain: a meta-analysis of randomized controlled trials. Pain Res Manag. 2013;18(5):267-72. Excluded: Pre-2007 systematic review or superseded by a more recent review. [pmid: 23894731].
Hoy D, Bain C, Williams G, et al. A systematic review of the global prevalence of low back pain. Arthritis Rheum. 2012;64(6):2028-37. Excluded: wrong outcome. [pmid: 22231424].
Hoy D, March L, Brooks P, et al. Measuring the global burden of low back pain. Best Pract Res Clin Rheumatol. 2010;24(2):155-65. Excluded: not a study (letter, editorial, non-systematic review article). [pmid: 20227638].
Huang C-Y, Choong M-Y, Li T-S. Effectiveness of cupping therapy for low back pain: a systematic review. Acupunct Med. 2013;31(3):336-7. Excluded: using original studies instead (e.g. meta-analysis, compiled study data, or data from another publication). [pmid: 23886511].
Huang T, Han B, Tian YY, et al. Low back pain of cold-damp pattern treated with electric-thermal Bian-stone therapy and traditional moxibustion: a randomized controlled trial. [Chinese]. Zhongguo zhen jiu. [Chinese acupuncture & moxibustion]. 2014;34(6):585-9. Excluded: not English language but possibly relevant. [pmid: 25112096].
Huang T, Han B, Tian Y-Y, et al. Low back pain of cold-damp pattern treated with electric-thermal Bian-stone therapy and traditional moxibustion: a randomized controlled trial. Zhongguo zhenjiu. 2014;34(6):585-9. Excluded: not English language but possibly relevant. [pmid: 25112096].
Hurley DA, Eadie J, O'Donoghue G, et al. Physiotherapy for sleep disturbance in chronic low back pain: a feasibility randomised controlled trial. BMC Musculoskelet Disord. 2010;11:70. Excluded: wrong outcome. [pmid: 20398349].
Hurley DA, O'Donoghue G, Tully MA, et al. A walking programme and a supervised exercise class versus usual physiotherapy for chronic low back pain: a single-blinded randomised controlled trial. (The Supervised Walking In comparison to Fitness Training for Back Pain (SWIFT) Trial). BMC Musculoskelet Disord. 2009;10:79. Excluded: wrong study deisgn for key question. [pmid: 19573247].
Hurwitz EL, Morgenstern H, Kominski GF, et al. A randomized trial of chiropractic and medical care for patients with low back pain: eighteen-month follow-up outcomes from the UCLA low back pain study. Spine (Phila Pa 1976). 2006;31(6):611-21. discussion 22. Excluded: wrong intervention. [pmid: 16540862].
Hurwitz EL, Morgenstern H, Vassilaki M, et al. Frequency and clinical predictors of adverse reactions to chiropractic care in the UCLA neck pain study. Spine (Phila Pa 1976). 2005;30(13):1477-84. Excluded: wrong outcome. [pmid: 15990659].
Hutchinson AJP, Ball S, Andrews JCH, et al. The effectiveness of acupuncture in treating chronic non-specific low back pain: a systematic review of the literature. J Orthop Surgery. 2012;7:36. Excluded: Pre-2007 systematic review or superseded by a more recent review. [pmid: 23111099].
Iles R, Taylor NF, Davidson M, et al. Telephone coaching can increase activity levels for people with non-chronic low back pain: a randomised trial. J Physiother. 2011;57(4):231-8. Excluded: wrong intervention. [pmid: 22093121].
Imamura M, Furlan AD, Dryden T, et al. Evidence-informed management of chronic low back pain with massage. Spine J. 2008;8(1):121-33. Excluded: using original studies instead (e.g. meta-analysis, compiled study data, or data from another publication). [pmid: 18164460].
Inoue M, et al. The comparison of the effectiveness between acupuncture treatment and local injection for low back pain- a randomized controlled trial. Journal of the Japanese Bio Electrical and Physical Stimulation Research Society. 2008;22:1-6. Excluded: not English language but possibly relevant.
Inoue M, Nakajima M, Itoi M, et al. Comparison of the effectiveness of acupuncture treatment and local injection for low back pain -- a randomized controlled clinical trial. [Japanese]. Journal of the Japanese Association of Physical Medicine, Balneology & Climatology. 2008;71(4):211-20. Excluded: not English language but possibly relevant.
Ionescu AM, Popa R, Manolescu BN, et al. Tramadol effects on exercise capacity in patients with low back pain. Ann Rheum Dis. 2014. Excluded: not a study (letter, editorial, non-systematic review article).
Itoh K, Kitakoji H. Acupuncture for chronic pain in Japan: a review. Evid Based Complement Alternat Med. 2007;4(4):431-8. Excluded: Pre-2007 systematic review or superseded by a more recent review. [pmid: 18227910].
Itoh S, et al. Effect of trigger point acupuncture treatment in older patients with chronic low back pain. J Jpn Soc Acupunct Moxibust. 2009;59(1):13-21. Excluded: not English language but possibly relevant.
Itz CJ, Geurts JW, van Kleef M, et al. Clinical course of non-specific low back pain: a systematic review of prospective cohort studies set in primary care. Eur J Pain. 2013;17(1):5-15. Excluded: wrong intervention. [pmid: 22641374].
Ivanova JI, Birnbaum HG, Schiller M, et al. Real-world practice patterns, health-care utilization, and costs in patients with low back pain: the long road to guideline-concordant care. Spine J. 2011;11(7):622-32. Excluded: wrong study deisgn for key question. [pmid: 21601533].
Iwakiri K, Kunisue R, Sotoyama M, et al. Postural support by a standing aid alleviating subjective discomfort among cooks in a forward-bent posture during food preparation. J Occup Health. 2008;50(1):57-62. Excluded: wrong intervention. [pmid: 18285645].
Iwamoto J, Sato Y, Takeda T, et al. Effectiveness of exercise in the treatment of lumbar spinal stenosis, knee osteoarthritis, and osteoporosis. Aging Clin Exp Res. 2010;22(2):116-22. Excluded: wrong population. [pmid: 19920410].
Jackson JK, Shepherd TR, Kell RT. The influence of periodized resistance training on recreationally active males with chronic nonspecific low back pain. J Strength Cond Res. 2011;25(1):242-51. Excluded: sample size too small. [pmid: 20093971].
Jaromi M, Nemeth A, Kranicz J, et al. Treatment and ergonomics training of work-related lower back pain and body posture problems for nurses. J Clin Nurs. 2012;21(11-12):1776-84. Excluded: wrong intervention. [pmid: 22594388].
Javadian Y, Behtash H, Akbari M, et al. The effects of stabilizing exercises on pain and disability of patients with lumbar segmental instability. J Back Musculoskeletal Rehabil. 2012;25(3):149-55. Excluded: sample size too small. [pmid: 22935853].
Jay K, Frisch D, Hansen K, et al. Kettlebell training for musculoskeletal and cardiovascular health: a randomized controlled trial. Scand J Work Environ Health. 2011;37(3):196-203. Excluded: wrong population. [pmid: 21107513].
Jensen C, Jensen OK, Christiansen DH, et al. One-year follow-up in employees sick-listed because of low back pain: randomized clinical trial comparing multidisciplinary and brief intervention. Spine. 2011;36(15):1180-9. Excluded: wrong intervention. [pmid: 21217456].
Jiang N, Guo J, Liu SB, et al. Short-term effectiveness observation of oxycodone and acetaminophen tablets for the treatment of lumbar disc heriation. [Chinese]. Chinese Journal of New Drugs. 2008;17(20):1798-801. Excluded: not English language but possibly relevant.
Jing H-T, Peng Y-Y, Chen M, et al. Clinical observation of lumbar spinal stenosis treated with deep puncture at Jiaji (EX-B 2). Zhongguo zhenjiu. 2011;31(9):791-4. Excluded: not English language but possibly relevant. [pmid: 21972625].
Johnson K, Chatterjee N, Noor N, et al. Effects of duloxetine and placebo in patients with chronic low back pain. J Pain. 2011;12(4 SUPPL. 1):49. Excluded: not a study (letter, editorial, non-systematic review article).
Johnston BC, Patrick DL, Thorlund K, et al. Patient-reported outcomes in meta-analyses-part 2: methods for improving interpretability for decision-makers. Health Qual Life Outcomes. 2013;11:211. Excluded: wrong intervention. [pmid: 24359184].
Johnstone R, Donaghy M, Martin D. A pilot study of a cognitive-behavioural therapy approach to physiotherapy, for acute low back pain patients, who show signs of developing chronic pain. Adv Physiother. 2002;4(4):182-8. Excluded: sample size too small.
Kader D, Radha S, Smith F, et al. Evaluation of perifacet injections and paraspinal muscle rehabilitation in treatment of low back pain. A randomised controlled trial. Ortop Tramatol Rehabil. 2012;14(3):251-9. Excluded: wrong intervention. [pmid: 22764337].
Kamali F, Panahi F, Ebrahimi S, et al. Comparison between massage and routine physical therapy in women with sub acute and chronic nonspecific low back pain. J Back Musculoskeletal Rehabil. 2014;27(4):475-80. Excluded: wrong comparison.
Kamali F, Shokri E. The effect of two manipulative therapy techniques and their outcome in patients with sacroiliac joint syndrome. J Bodywork Mov Ther. 2012;16(1):29-35. Excluded: wrong population. [pmid: 22196424].
Kamioka H, Tsutani K, Okuizumi H, et al. Effectiveness of aquatic exercise and balneotherapy: a summary of systematic reviews based on randomized controlled trials of water immersion therapies. J Epidemiol. 2010;20(1):2-12. Excluded: wrong intervention. [pmid: 19881230].
Kamper SJ, Apeldoorn AT, Chiarotto A, et al. Multidisciplinary biopsychosocial rehabilitation for chronic low back pain: Cochrane systematic review and meta-analysis. BMJ. 2015;350:h444. Excluded: using original studies instead (e.g. meta-analysis, compiled study data, or data from another publication). [pmid: 25694111].
Kantito S, Tantisiriwat N, Piravej K. Comparison of the effectiveness between generic and original form of gabapentin for pain relief in suspected neuropathic component of low back pain. Chotmaihet thangphaet. Journal of the Medical Association of Thailand. 2014;97(7):767-75. Excluded: not English language but possibly relevant. [pmid: 25265777].
Kapitza KP, Passie T, Bernateck M, et al. First non-contingent respiratory biofeedback placebo versus contingent biofeedback in patients with chronic low back pain: a randomized, controlled, double-blind trial. Appl Psychophysiol Biofeed. 2010;35(3):207-17. Excluded: wrong intervention. [pmid: 20237953].
Kasimcan O, Kaptan H. Efficacy of gabapentin for radiculopathy caused by lumbar spinal stenosis and lumbar disk hernia. Neurol Med Chir (Tokyo). 2010;50(12):1070-3. Excluded: wrong study deisgn for key question. [pmid: 21206180].
Katz N, Borenstein DG, Birbara C, et al. Efficacy and safety of tanezumab in the treatment of chronic low back pain. Pain. 2011;152(10):2248-58. Excluded: wrong intervention. [pmid: 21696889].
Kavanagh S, Kwong WJ, Hammond GC, et al. Pain relief and tolerability balance of immediate release tapentadol or oxycodone treatment for patients with moderate to severe osteoarthritis or low back pain. Pain Med. 2012;13(9):1110-20. Excluded: wrong population. [pmid: 22845494].
Kell RT, Asmundson GJG. A comparison of two forms of periodized exercise rehabilitation programs in the management of chronic nonspecific low-back pain. J Strength Cond Res. 2009;23(2):513-23. Excluded: sample size too small. [pmid: 19209082].
Keller A, Hayden J, Bombardier C, et al. Effect sizes of non-surgical treatments of non-specific low-back pain. Eur Spine J. 2007;16(11):1776-88. Excluded: Pre-2007 systematic review or superseded by a more recent review. [pmid: 17619914].
Kent P, Kjaer P. The efficacy of targeted interventions for modifiable psychosocial risk factors of persistent nonspecific low back pain - a systematic review. Manual Ther. 2012;17(5):385-401. Excluded: wrong study deisgn for key question. [pmid: 22421188].
Kent P, Mjosund HL, Petersen DHD. Does targeting manual therapy and/or exercise improve patient outcomes in nonspecific low back pain? A systematic review. BMC Med. 2010;8:22. Excluded: wrong comparison. [pmid: 20377854].
Kesiktas N, Karakas S, Gun K, et al. Balneotherapy for chronic low back pain: a randomized, controlled study. Rheumatol Int. 2012;32(10):3193-9. Excluded: wrong intervention. [pmid: 21960048].
Khadilkar A, Odebiyi DO, Brosseau L, et al. Transcutaneous electrical nerve stimulation (TENS) versus placebo for chronic low-back pain. Cochrane Database Syst Rev. 2008;(4). CD003008. Excluded: Pre-2007 systematic review or superseded by a more recent review. [pmid: 18843638].
Khadilkar A, Odebiyi OD, Brosseau L, et al. Transcutaneous electrical nerve stimulation (TENS) versus placebo for chronic low-back pain. Cochrane Database Syst Rev. 2013;(5). Excluded: Pre-2007 systematic review or superseded by a more recent review.
Kim J-I, Kim T-H, Lee MS, et al. Evaluation of wet-cupping therapy for persistent non-specific low back pain: a randomised, waiting-list controlled, open-label, parallel-group pilot trial. Trials. 2011;12:146. Excluded: wrong intervention. [pmid: 21663617].
Kim KH, Kim T-H, Lee BR, et al. Acupuncture for lumbar spinal stenosis: a systematic review and meta-analysis. Complement Ther Med. 2013;21(5):535-56. Excluded: Pre-2007 systematic review or superseded by a more recent review. [pmid: 24050593].
Kim SM, Kim HJ, Lee MJ, et al. Effects of local and Sa-am acupuncture on hypoadrenia and chronic low back pain. J Korean Orient Med. 2009;30(2):104-16. Excluded: not English language but possibly relevant.
Kivitz AJ, Gimbel JS, Bramson C, et al. Efficacy and safety of tanezumab versus naproxen in the treatment of chronic low back pain. Pain. 2013;154(7):1009-21. Excluded: wrong intervention. [pmid: 23628600].
Kladny B, Fischer FC, Haase I. Wertigkeit der muskulären segmentalen Stabilisierung zur Behandlung von Rückenschmerz und Bandscheibenerkrankungen im Rahmen der ambulanten Rehabilitation. Z Orthop Ihre Grenzgeb. 2003;141(04):401-5. PMID. Excluded: not English language but possibly relevant. [pmid: 12928996].
Kline JB, Krauss JR, Maher SF, et al. Core strength training using a combination of home exercises and a dynamic sling system for the management of low back pain in pre-professional ballet dancers: a case series. J Dance Med Sci. 2013;17(1):24-33. Excluded: wrong study deisgn for key question. [pmid: 23498354].
Koc Z, Ozcakir S, Sivrioglu K, et al. Effectiveness of physical therapy and epidural steroid injections in lumbar spinal stenosis. Spine. 2009;34(10):985-9. Excluded: wrong intervention. [pmid: 19404172].
Kofotolis ND, Vlachopoulos SP, Kellis E. Sequentially allocated clinical trial of rhythmic stabilization exercises and TENS in women with chronic low back pain. Clin Rehabil. 2008;22(2):99-111. Excluded: wrong study deisgn for key question. [pmid: 18212032].
Koldas Dogan S, Sonel Tur B, Kurtais Y, et al. Comparison of three different approaches in the treatment of chronic low back pain. Clin Rheumatol. 2008;27(7):873-81. Excluded: sample size too small. [pmid: 18188660].
Kominski GF, Heslin KC, Morgenstern H, et al. Economic evaluation of four treatments for low-back pain: results from a randomized controlled trial. Med Care. 2005;43(5):428-35. Excluded: wrong outcome. [pmid: 15838406].
Kong LJ, Fang M, Zhan HS, et al. Tuina-focused integrative chinese medical therapies for inpatients with low back pain: a systematic review and meta-analysis. Evid Based Complement Alternat Med. 2012;2012:578305. Excluded: Pre-2007 systematic review or superseded by a more recent review. [pmid: 23346207].
Konstantinou K, Foster N, Rushton A, et al. Flexion mobilizations with movement techniques: the immediate effects on range of movement and pain in subjects with low back pain. J Manipulative Physiol Ther. 2007;30(3):178-85. Excluded: wrong outcome. [pmid: 17416271].
Koopman JSHA, Vrinten DH, van Wijck AJM. Efficacy of microcurrent therapy in the treatment of chronic nonspecific back pain: a pilot study. Clin J Pain. 2009;25(6):495-9. Excluded: wrong intervention. [pmid: 19542797].
Koopmans GT, Meeuwesen L, Huyse FJ, et al. Effects of psychiatric consultation on medical consumption in medical outpatients with low back pain. Gen Hosp Psychiatry. 1996;18(3):145-54. Excluded: wrong intervention. [pmid: 8739008].
Kovacs F, Abraira V, Muriel A, et al. Prognostic factors for neuroreflexotherapy in the treatment of subacute and chronic neck and back pain: a study of predictors of clinical outcome in routine practice of the Spanish National Health Service. Spine. 2007;32(15):1621-8. Excluded: wrong population. [pmid: 17621209].
Kovacs FM, Urrutia G, Alarcon JD. Surgery versus conservative treatment for symptomatic lumbar spinal stenosis: a systematic review of randomized controlled trials. Spine. 2011;36(20):E1335-51. Excluded: wrong intervention. [pmid: 21311394].
Kovacs FM, Zanoli G, Yuan J, Purepong N, Kerr DP, et al. Effectiveness of acupuncture for low back pain. A systematic review. Spine. 2008;33:E887-E900. Spine. 2009;34(7):752-3; author reply 3. Excluded: not a study (letter, editorial, non-systematic review article). [pmid: 18978583].
Kown YD, Lee SG, Lee CW, et al. The short-term efficacy of acupuncture for chronic low back pain: randomized sham controlled trial. [Korean]. J Orient Rehab Med. 2007;17:123-32. Excluded: not English language but possibly relevant.
Krein SL, Kadri R, Hughes M, et al. Pedometer-based internet-mediated intervention for adults with chronic low back pain: randomized controlled trial. J Med Internet Res. 2013;15(8):e181. Excluded: wrong intervention. [pmid: 23969029].
Kriese M, Clijsen R, Taeymans J, et al. Segmental stabilization in low back pain: a systematic review. Sportverletz Sportschaden. 2010;24(1):17-25. Excluded: not English language but possibly relevant. [pmid: 20235009].
Kroenke K, Bair MJ, Damush TM, et al. Optimized antidepressant therapy and pain self-management in primary care patients with depression and musculoskeletal pain: a randomized controlled trial. Jama. 2009;301(20):2099-110. Excluded: wrong population. [pmid: 19470987].
Kuczynski JJ, Schwieterman B, Columber K, et al. Effectiveness of physical therapist administered spinal manipulation for the treatment of low back pain: a systematic review of the literature. Int J Sports Phys Ther. 2012;7(6):647-62. Excluded: Pre-2007 systematic review or superseded by a more recent review. [pmid: 23316428].
Kuijper B, Tans JT, Beelen A, et al. Cervical collar or physiotherapy versus wait and see policy for recent onset cervical radiculopathy: randomised trial. BMJ. 2009;339:b3883. Excluded: wrong population. [pmid: 19812130].
Kulisch A, Bender T, Nemeth A, et al. Effect of thermal water and adjunctive electrotherapy on chronic low back pain: a double-blind, randomized, follow-up study. J Rehabil Med. 2009;41(1):73-9. Excluded: wrong intervention. [pmid: 19197573].
Kumar S, Beaton K, Hughes T. The effectiveness of massage therapy for the treatment of nonspecific low back pain: a systematic review of systematic reviews. Int J Gen Med. 2013;6:733-41. Excluded: Pre-2007 systematic review or superseded by a more recent review. [pmid: 24043951].
Kumar S, Sharma VP, Negi MPS. Efficacy of dynamic muscular stabilization techniques (DMST) over conventional techniques in rehabilitation of chronic low back pain. J Strength Cond Res. 2009;23(9):2651-9. Excluded: wrong intervention. [pmid: 19858754].
Kwon YD, Lee SG, Lee CW, et al. The short-term efficacy of acupuncture for chronic low back pain: randomised sham controlled trial. J Oriental Rehab Med. 2007;17(2):123-32. Excluded: not English language but possibly relevant.
Kwong WJ, Hammond G, Upmalis D, et al. Bowel function after tapentadol and oxycodone immediate release (IR) treatment in patients with low back or osteoarthritis pain. Clin J Pain. 2013;29(8):664-72. Excluded: wrong population. [pmid: 23835764].
La Touche R, Escalante K, Linares MT. Treating non-specific chronic low back pain through the Pilates Method. J Bodyw Mov Ther. 2008;12(4):364-70. Excluded: Pre-2007 systematic review or superseded by a more recent review. [pmid: 19083695].
Laiq N, Khan MN, Iqbal MJ, et al. Comparison of Epidural Steroid Injections with conservative management in patients with lumbar radiculopathy. J Coll Physicians Surg Pak. 2009;19(9):539-43. Excluded: wrong intervention. [pmid: 19728936].
Laird RA, Kent P, Keating JL. Modifying patterns of movement in people with low back pain -does it help? A systematic review. BMC Musculoskelet Disord. 2012;13:169. Excluded: relevant to background only. [pmid: 22958597].
Lamb SE, Lall R, Hansen Z, et al. A multicentred randomised controlled trial of a primary care-based cognitive behavioural programme for low back pain. The Back Skills Training (BeST) trial. Health Technol Assess. 2010;14(41):1-253. iii. iv. Excluded: using original studies instead (e.g. meta-analysis, compiled study data, or data from another publication). [pmid: 20807469].
Lange B, Kuperwasser B, Okamoto A, et al. Efficacy and safety of tapentadol prolonged release for chronic osteoarthritis pain and low back pain. [Erratum appears in Adv Ther. 2010 Dec;27(12):981]. Adv Ther. 2010;27(6):381-99. Excluded: wrong population. [pmid: 20556560].
Lasko B, Levitt RJ, Rainsford KD, et al. Extended-release tramadol/paracetamol in moderate-to-severe pain: a randomized, placebo-controlled study in patients with acute low back pain. Curr Med Res Opin. 2012;28(5):847-57. Excluded: inadequate duration. [pmid: 22458917].
Lau PMY, Chow DHK, Pope MH. Early physiotherapy intervention in an Accident and Emergency Department reduces pain and improves satisfaction for patients with acute low back pain: a randomised trial. Aust J Physiother. 2008;54(4):243-9. Excluded: wrong intervention. [pmid: 19025504].
Lauche R, Wubbeling K, Ludtke R, et al. Randomized controlled pilot study: pain intensity and pressure pain thresholds in patients with neck and low back pain before and after traditional East Asian “gua sha” therapy. Am J Chin Med. 2012;40(5):905-17. Excluded: wrong intervention. [pmid: 22928824].
Lawrence DJ, Meeker W, Branson R, et al. Chiropractic management of low back pain and low back-related leg complaints: a literature synthesis. J Manipulative Physiol Ther. 2008;31(9):659-74. Excluded: Pre-2007 systematic review or superseded by a more recent review. [pmid: 19028250].
Learman KE, Showalter C, O'Halloran B, et al. Thrust and nonthrust manipulation for older adults with low back pain: an evaluation of pain and disability. J Manipulative Physiol Ther. 2013;36(5):284-91. Excluded: using original studies instead (e.g. meta-analysis, compiled study data, or data from another publication). [pmid: 23769265].
Lecybyl R, Acosta J, Ghoshdastidar J, et al. Validation, reproducibility and safety of trans dermal electrical stimulation in chronic pain patients and healthy volunteers. BMC Neurol. 2010;10:5. Excluded: wrong study deisgn for key question. [pmid: 20070896].
Lee JB, Im JG, Lee HG, et al. Comparison of effectiveness between acupuncture and its cotreatment with foot acupuncture on low back pain. J Korean Acupunct & Mox Med Sci. 2011;28(4):1-7. Excluded: not English language but possibly relevant.
Lee MS, Ernst E. Acupuncture for pain: an overview of Cochrane reviews. Chin J Integr Med. 2011;17(3):187-9. Excluded: wrong study deisgn for key question. [pmid: 21359919].
Lee MS, Pittler MH, Ernst E. Internal qigong for pain conditions: a systematic review. J Pain. 2009;10(11):1121-7.e14. Excluded: using original studies instead (e.g. meta-analysis, compiled study data, or data from another publication). [pmid: 19559656].
Lee T, Kim YH, Sung PS. A comparison of pain level and entropy changes following core stability exercise intervention. Med Sci Monit. 2011;17(7):CR362-8. Excluded: wrong population. [pmid: 21709629].
Lee T, Shin J, Ha I, et al. Immediate effects of motion style acupuncture treatment (MSAT) in acute low back pain with severe disability: A multicenter, randomized, controlled trial. J Pain. Conference: 31st Annual Scientific Meeting of the American Pain Society. Honolulu, HI United States. Conference Start: 20120516 Conference End: 20120519. Conference Publication:(4). 2012:S60. Excluded: wrong study deisgn for key question.
Lee Y-H, Kim J-H, Jeong J-Y, et al. Clinical Review of the Effects of Chukyu (spinehealing) Pharmacopuncture in the Treatment of Lumbago and Skelalgia Patients. J. 2012;15(3):39-44. Excluded: wrong intervention. [pmid: 25780646].
Leininger B, Bronfort G, Evans R, et al. Spinal manipulation or mobilization for radiculopathy: a systematic review. Phys Med Rehabil Clin N Am. 2011;22(1):105-25. Excluded: using original studies instead (e.g. meta-analysis, compiled study data, or data from another publication). [pmid: 21292148].
Lemaster C, Keosaian J, Dorman E, et al. Qualitative study in a randomized trial comparing Yoga, physical therapy, and education for low back pain in a predominantly minority population. J Altern Complement Med. Conference: International Research Congress on Integrative Medicine and Health, IRCIMH 2014. Miami, FL United States. Conference Start: 20140513 Conference End: 20140516. Conference Publication:(var.pagings). 2014:A59. Excluded: not a study (letter, editorial, non-systematic review article).
Leslie H, Shapiro DY, Okamoto A, et al. Tapentadol ER for chronic low back pain: Brief pain inventory (BPI) results. Ann Neurol. 66(3, Supplement 13):S5. Excluded: not a study (letter, editorial, non-systematic review article).
Lewis A, Morris ME, Walsh C. Are physiotherapy exercises effective in reducing chronic low back pain?. Phys Ther Rev. 2008;13:37-44. Excluded: Pre-2007 systematic review or superseded by a more recent review.
Lewis C, Souvlis T, Sterling M. Strain-Counterstrain therapy combined with exercise is not more effective than exercise alone on pain and disability in people with acute low back pain: a randomised trial. J Physiother. 2011;57(2):91-8. Excluded: wrong intervention. [pmid: 21684490].
Lewis K, Abdi S. Acupuncture for lower back pain: a review. Clin J Pain. 2010;26(1):60-9. Excluded: not a study (letter, editorial, non-systematic review article). [pmid: 20026956].
Li C, Ni J, Wang Z, et al. Analgesic efficacy and tolerability of flupirtine vs. tramadol in patients with subacute low back pain: a double-blind multicentre trial*. Curr Med Res Opin. 2008;24(12):3523-30. Excluded: wrong intervention. [pmid: 19032134].
Licciardone JC, Kearns CM, Hodge LM, et al. Osteopathic manual treatment in patients with diabetes mellitus and comorbid chronic low back pain: subgroup results from the OSTEOPATHIC Trial. J Am Osteopath Assoc. 2013;113(6):468-78. Excluded: wrong population. [pmid: 23739758].
Liddle SD, Gracey JH, Baxter GD. Advice for the management of low back pain: a systematic review of randomised controlled trials. Manual Ther. 2007;12(4):310-27. Excluded: Pre-2007 systematic review or superseded by a more recent review. [pmid: 17395522].
Lie H, Frey S. Mobilizing or stabilizing exercise in degenerative disk disease in the lumbar region?. Tidsskr Nor Laegeforen. 1999;119(14):2051-3. Excluded: not English language but possibly relevant. [pmid: 10394282].
Lim EC, Poh RL, Low AY, et al. Effects of Pilates-based exercises on pain and disability in individuals with persistent nonspecific low back pain: a systematic review with meta-analysis. J Orthop Sports Phys Ther. 2011;41(2):70-80. Excluded: Pre-2007 systematic review or superseded by a more recent review. [pmid: 20972339].
Lin ML, Wu HC, Hsieh YH, et al. Evaluation of the effect of laser acupuncture and cupping with Ryodoraku and visual analog scale on low back pain. Evid Based Complement Alternat Med. 2012;2012(521612). Excluded: wrong intervention. [pmid: 23118792].
Linde K, Niemann K, Meissner K. Are sham acupuncture interventions more effective than (other) placebos? A re-analysis of data from the Cochrane review on placebo effects. Forsch Komplementarmed. 2010;17(5):259-64. Excluded: wrong study deisgn for key question. [pmid: 20980765].
Linde K, Witt CM, Streng A, et al. The impact of patient expectations on outcomes in four randomized controlled trials of acupuncture in patients with chronic pain. Pain. 2007;128(3):264-71. Excluded: wrong population. [pmid: 17257756].
Little P, Roberts L, Blowers H, et al. Should we give detailed advice and information booklets to patients with back pain? A randomized controlled factorial trial of a self-management booklet and doctor advice to take exercise for back pain. Spine (Phila Pa 1976). 2001;26(19):2065-72. Excluded: wrong intervention. [pmid: 11698879].
Liu L, Skinner M, McDonough S, et al. Acupuncture for low back pain: an overview of systematic reviews. Evid Based Complement Alternat Med. 2015;2015:328196. Excluded: Pre-2007 systematic review or superseded by a more recent review. [pmid: 25821485].
Long A, Donelson R, Fung T. Does it matter which exercise? A randomized control trial of exercise for low back pain. Spine (Phila Pa 1976). 2004;29(23):2593-602. Excluded: wrong intervention. [pmid: 15564907].
Longo L, Tamburini A, Monti A. Treatment with 904 nm and 10600 nm laser of acute lumbago-double blind control-laser. JEMLA. 1991;3(1):16-9. Excluded: using original studies instead (e.g. meta-analysis, compiled study data, or data from another publication).
Luijsterburg PAJ, Lamers LM, Verhagen AP, et al. Cost-effectiveness of physical therapy and general practitioner care for sciatica. Spine. 2007;32(18):1942-8. Excluded: wrong outcome. [pmid: 17700438].
Luijsterburg PAJ, Verhagen AP, Ostelo RWJG, et al. Effectiveness of conservative treatments for the lumbosacral radicular syndrome: a systematic review. Eur Spine J. 2007;16(7):881-99. Excluded: Pre-2007 systematic review or superseded by a more recent review. [pmid: 17415595].
Lumpkin KJ. The effect of low level laser therapy and exercise on perceived pain and activities of daily living in low back pain patients. MTSU. 2007. Excluded: not a study (letter, editorial, non-systematic review article).
Macedo LG, Hum A, Kuleba L, et al. Physical therapy interventions for degenerative lumbar spinal stenosis: a systematic review. Phys Ther. 2013;93(12):1646-60. Excluded: using original studies instead (e.g. meta-analysis, compiled study data, or data from another publication). [pmid: 23886845].
Macedo LG, Maher CG, Hancock MJ, et al. Predicting response to motor control exercises and graded activity for patients with low back pain: preplanned secondary analysis of a randomized controlled trial. Phys Ther. 2014;94(11):1543-54. Excluded: wrong outcome. [pmid: 25013000].
Macedo LG, Maher CG, Latimer J, et al. Motor control exercise for persistent, nonspecific low back pain: a systematic review. Phys Ther. 2009;89(1):9-25. Excluded: using original studies instead (e.g. meta-analysis, compiled study data, or data from another publication). [pmid: 19056854].
Macedo LG, Smeets RJEM, Maher CG, et al. Graded activity and graded exposure for persistent nonspecific low back pain: a systematic review. Phys Ther. 2010;90(6):860-79. Excluded: Pre-2007 systematic review or superseded by a more recent review. [pmid: 20395306].
Machado LAC, Kamper SJ, Herbert RD, et al. Analgesic effects of treatments for non-specific low back pain: a meta-analysis of placebo-controlled randomized trials. Rheumatology (Oxford). 2009;48(5):520-7. Excluded: Pre-2007 systematic review or superseded by a more recent review. [pmid: 19109315].
MacPherson H, Thomas K. Traditional acupuncture for low back pain: developing high-quality evidence while maintaining the integrity of the treatment process. J Accupunct Assoc Chartered Phys. 2008;1:39-46. Excluded: wrong study deisgn for key question.
Madhusudhan SK. Novel analgesic combination of tramadol, paracetamol, caffeine and taurine in the management of moderate to moderately severeacute low back pain. J Orthop. 2013;10(3):144-8. Excluded: wrong intervention. [pmid: 24396231].
Magnusson ML, Chow DH, Diamandopoulos Z, et al. Motor control learning in chronic low back pain. Spine. 2008;33(16):E532-8. Excluded: wrong study deisgn for key question. [pmid: 18628693].
Maiers M, Bronfort G, Evans R, et al. Spinal manipulative therapy and exercise for seniors with chronic neck pain. Spine J. 2014;14(9):1879-89. Excluded: wrong population. [pmid: 24225010].
Maizels M, McCarberg B. Antidepressants and antiepileptic drugs for chronic non-cancer pain. Am Fam Physician. 2005;71(3):483-90. Excluded: wrong population. [pmid: 15712623].
Malanga G, Reiter RD, Garay E. Update on tizanidine for muscle spasticity and emerging indications. Expert Opin Pharmacother. 2008;9(12):2209-15. Excluded: wrong population. [pmid: 18671474].
Malanga GA, Ruoff GE, Weil AJ, et al. Cyclobenzaprine ER for muscle spasm associated with low back and neck pain: two randomized, double-blind, placebo-controlled studies of identical design. Curr Med Res Opin. 2009;25(5):1179-96. Excluded: wrong population. [pmid: 19323613].
Malmivaara A, Slatis P, Heliovaara M, et al. Surgical or nonoperative treatment for lumbar spinal stenosis? A randomized controlled trial. Spine (Phila Pa 1976). 2007;32(1):1-8. Excluded: wrong intervention. [pmid: 17202885].
Mannion AF, Helbling D, Pulkovski N, et al. Spinal segmental stabilisation exercises for chronic low back pain: programme adherence and its influence on clinical outcome. Eur Spine J. 2009;18(12):1881-91. Excluded: wrong study deisgn for key question. [pmid: 19609785].
Mannion AF, Junge A, Grob D, et al. Development of a German version of the Oswestry Disability Index. Part 2: sensitivity to change after spinal surgery. Eur Spine J. 2006;15(1):66-73. Excluded: wrong study deisgn for key question. [pmid: 15856340].
Marignan M. Auriculotherapy treatment protocol for low-back pain: A randomized trial. Med Acupunct. 2014;26(3):154-60. Excluded: wrong intervention.
Marshall P, Murphy B. Self-report measures best explain changes in disability compared with physical measures after exercise rehabilitation for chronic low back pain. Spine. 2008;33(3):326-38. Excluded: sample size too small. [pmid: 18303467].
Marshall PW, Desai I, Robbins DW. Core stability exercises in individuals with and without chronic nonspecific low back pain. J Strength Cond Res. 2011;25(12):3404-11. Excluded: wrong population. [pmid: 22080309].
Marshall PW, Murphy BA. Muscle activation changes after exercise rehabilitation for chronic low back pain. Arch Phys Med Rehabil. 2008;89(7):1305-13. Excluded: wrong study deisgn for key question. [pmid: 18586132].
Masharawi Y, Nadaf N. The effect of non-weight bearing group-exercising on females with non-specific chronic low back pain: a randomized single blind controlled pilot study. J Back Musculoskeletal Rehabil. 2013;26(4):353-9. Excluded: sample size too small. [pmid: 23948819].
Masse-Alarie H, Flamand VH, Moffet H, et al. Peripheral neurostimulation and specific motor training of deep abdominal muscles improve posturomotor control in chronic low back pain. Clin J Pain. 2013;29(9):814-23. Excluded: wrong population. [pmid: 23370067].
Mathews JA, Mills SB, Jenkins VM, et al. Back pain and sciatica: controlled trials of manipulation, traction, sclerosant and epidural injections. Br J Rheumatol. 1987;26(6):416-23. Excluded: wrong outcome. [pmid: 2961394].
Matsudaira K, Seichi A, Kunogi J, et al. The efficacy of prostaglandin E1 derivative in patients with lumbar spinal stenosis. Spine. 2009;34(2):115-20. Excluded: wrong intervention. [pmid: 19112336].
Mayer J, Mooney V, Dagenais S. Evidence-informed management of chronic low back pain with lumbar extensor strengthening exercises. Spine J. 2008;8(1):96-113. Excluded: not a study (letter, editorial, non-systematic review article). [pmid: 18164458].
Mayyas F, Fayers P, Kaasa S, et al. A systematic review of oxymorphone in the management of chronic pain. J Pain Symptom Manage. 2010;39(2):296-308. Excluded: Pre-2007 systematic review or superseded by a more recent review. [pmid: 20152592].
McCarberg BH. Acute back pain: benefits and risks of current treatments. Curr Med Res Opin. 2010;26(1):179-90. Excluded: not a study (letter, editorial, non-systematic review article). [pmid: 19919374].
McCarberg BH. NSAIDs in the older patient: balancing benefits and harms. Pain Med. Suppl 1. 2013;14:S43-4. Excluded: not a study (letter, editorial, non-systematic review article). [pmid: 24373111].
McDonough SM, Tully MA, Boyd A, et al. Pedometer-driven walking for chronic low back pain: a feasibility randomized controlled trial. Clin J Pain. 2013;29(11):972-81. Excluded: sample size too small. [pmid: 23446066].
McDonough SM, Tully MA, O'Connor SR, et al. The back 2 activity trial: education and advice versus education and advice plus a structured walking programme for chronic low back pain. BMC Musculoskelet Disord. 2010;11:163. Excluded: not a study (letter, editorial, non-systematic review article). [pmid: 20633256].
McIlveen B, Robertson VJ. A randomised controlled study of the outcome of hydrotherapy for subjects with low back or back and leg pain. Physiotherapy. 1998;84(1):17-26. Excluded: wrong intervention.
McIntosh G, Hall H. Low back pain (acute). Clin Evid (Online). 2011. Excluded: not a study (letter, editorial, non-systematic review article). [pmid: 21549023].
Meeuwesen L, Huyse FJ, Koopmans GT, et al. Supervised integrated screening of low-back pain patients by a neurologist. A randomized clinical trial. Gen Hosp Psychiatry. 1996;18(6):385-94. Excluded: wrong intervention. [pmid: 8937904].
Meng K, Seekatz B, Roband H, et al. Intermediate and long-term effects of a standardized back school for inpatient orthopedic rehabilitation on illness knowledge and self-management behaviors: a randomized controlled trial. Clin J Pain. 2011;27(3):248-57. Excluded: wrong intervention. [pmid: 21178600].
Meng K, Seekatz B, Rossband H, et al. Development of a standardized back school for in-patient orthopaedic rehabilitation. Rehabilitation (Stuttg). 2009;48(6):335-44. Excluded: not English language but possibly relevant. [pmid: 20069517].
Menke JM. Do manual therapies help low back pain? A comparative effectiveness meta-analysis. Spine. 2014;39(7):E463-72. Excluded: Pre-2007 systematic review or superseded by a more recent review. [pmid: 24480940].
Merchant S, Provenzano D, Mody S, et al. Composite measure to assess efficacy/gastrointestinal tolerability of tapentadol ER versus oxycodone CR for chronic pain: pooled analysis of randomized studies. J Opioid Manag. 2013;9(1):51-61. Excluded: using original studies instead (e.g. meta-analysis, compiled study data, or data from another publication). [pmid: 23709304].
Merepeza A. Effects of spinal manipulation versus therapeutic exercise on adults with chronic low back pain: a literature review. J Can Chiropractic Assoc. 2014;58(4):456-66. Excluded: Pre-2007 systematic review or superseded by a more recent review. [pmid: 25550671].
Mibielli MA, Geller M, Cohen JC, et al. Diclofenac plus B vitamins versus diclofenac monotherapy in lumbago: the DOLOR study. Curr Med Res Opin. 2009;25(11):2589-99. Excluded: wrong intervention. [pmid: 19731994].
Michaleff ZA, Kamper SJ, Maher CG, et al. Low back pain in children and adolescents: a systematic review and meta-analysis evaluating the effectiveness of conservative interventions. Eur Spine J. 2014;23(10):2046-58. Excluded: wrong population. [pmid: 25070788].
Mika J, Zychowska M, Makuch W, et al. Neuronal and immunological basis of action of antidepressants in chronic pain - clinical and experimental studies. Pharmacol Rep. 2013;65(6):1611-21. Excluded: wrong study deisgn for key question. [pmid: 24553009].
Miller K, Yarlas A, Wen W, et al. Buprenorphine transdermal system and quality of life in opioid-experienced patients with chronic low back pain. Expert Opin Pharmacother. 2013;14(3):269-77. Excluded: wrong comparison. [pmid: 23374027].
Miyazaki S, Hagihara A, Kanda R, et al. Applicability of press needles to a double-blind trial: a randomized, double-blind, placebo-controlled trial. Clin J Pain. 2009;25(5):438-44. Excluded: wrong outcome. [pmid: 19454879].
Mohseni-Bandpei MA, Rahmani N, Behtash H, et al. The effect of pelvic floor muscle exercise on women with chronic non-specific low back pain. J Bodywork Mov Ther. 2011;15(1):75-81. Excluded: sample size too small. [pmid: 21147422].
Monticone M, Ferrante S, Teli M, et al. Management of catastrophising and kinesiophobia improves rehabilitation after fusion for lumbar spondylolisthesis and stenosis. A randomised controlled trial. Eur Spine J. 2014;23(1):87-95. Excluded: wrong population. [pmid: 23836299].
Moon T-W, Choi T-Y, Park T-Y, et al. Chuna therapy for musculoskeletal pain: a systematic review of randomized clinical trials in Korean literature. Chin J Integr Med. 2013;19(3):228-32. Excluded: Pre-2007 systematic review or superseded by a more recent review. [pmid: 22903444].
Moore N, Van Ganse E, Le Parc J-M, et al. The PAIN study: paracetamol, aspirin and ibuprofen new tolerability study. Clin Drug Invest. 1999;18(2):89-98. Excluded: wrong population.
Moore RA, Cai N, Skljarevski V, et al. Duloxetine use in chronic painful conditions--individual patient data responder analysis. Eur J Pain. 2014;18(1):67-75. Excluded: using original studies instead (e.g. meta-analysis, compiled study data, or data from another publication). [pmid: 23733529].
Moore RA, Derry S, McQuay HJ. Discontinuation rates in clinical trials in musculoskeletal pain: meta-analysis from etoricoxib clinical trial reports. Arthritis Res Ther. 2008;10(3):R53. Excluded: wrong population. [pmid: 18466615].
Moradi B, Benedetti J, Zahlten-Hinguranage A, et al. The value of physical performance tests for predicting therapy outcome in patients with subacute low back pain: a prospective cohort study. Eur Spine J. 2009;18(7):1041-9. Excluded: wrong study deisgn for key question. [pmid: 19363624].
Moritz S, Liu MF, Rickhi B, et al. Reduced health resource use after acupuncture for low-back pain. J Altern Complement Med. 2011;17(11):1015-9. Excluded: wrong study deisgn for key question. [pmid: 22070438].
Morlion B. Pharmacotherapy of low back pain: targeting nociceptive and neuropathic pain components. Curr Med Res Opin. 2011;27(1):11-33. Excluded: using original studies instead (e.g. meta-analysis, compiled study data, or data from another publication). [pmid: 21083513].
Morone NE, Greco CM. Mind-body interventions for chronic pain in older adults: a structured review. Pain Med. 2007;8(4):359-75. Excluded: Pre-2007 systematic review or superseded by a more recent review. [pmid: 17610459].
Morone NE, Greco CM, Weiner DK. Mindfulness meditation for the treatment of chronic low back pain in older adults: a randomized controlled pilot study. Pain. 2008;134(3):310-9. Excluded: wrong intervention. [pmid: 17544212].
Morone NE, Rollman BL, Moore CG, et al. A mind-body program for older adults with chronic low back pain: results of a pilot study. Pain Med. 2009;10(8):1395-407. Excluded: wrong intervention. [pmid: 20021599].
Mostafavifar M, Wertz J, Borchers J. A systematic review of the effectiveness of kinesio taping for musculoskeletal injury. Phys Sportsmed. 2012;40(4):33-40. Excluded: using original studies instead (e.g. meta-analysis, compiled study data, or data from another publication). [pmid: 23306413].
Murotani K, Kawai N, Sato M, et al. Erratum to: Optimum CT reconstruction parameters for vascular and hepatocellular carcinoma models in a liver phantom with multi-level dynamic computed tomography with 64 detector rows: a basic study. Radiological Physics and Technology. 2013;1. Excluded: not a study (letter, editorial, non-systematic review article).
Murray CJ, Vos T, Lozano R, et al. Disability-adjusted life years (DALYs) for 291 diseases and injuries in 21 regions, 1990-2010: a systematic analysis for the Global Burden of Disease Study 2010. Lancet. 2012;380(9859):2197-223. Excluded: using original studies instead (e.g. meta-analysis, compiled study data, or data from another publication). [pmid: 23245608].
Murtezani A, Hundozi H, Orovcanec N, et al. A comparison of high intensity aerobic exercise and passive modalities for the treatment of workers with chronic low back pain: a randomized, controlled trial. Eur J Phys Rehabil Med. 2011;47(3):359-66. Excluded: wrong intervention. [pmid: 21602759].
Myers SS, Phillips RS, Davis RB, et al. Patient expectations as predictors of outcome in patients with acute low back pain. J Gen Intern Med. 2008;23(2):148-53. Excluded: wrong intervention. [pmid: 18066631].
Nalamachu S, Rauck RL, Hale ME, et al. A long-term, open-label safety study of single-entity hydrocodone bitartrate extended release for the treatment of moderate to severe chronic pain. J Pain Res. 2014;7:669-78. Excluded: wrong population. [pmid: 25473308].
Nassif H, Brosset N, Guillaume M, et al. Evaluation of a randomized controlled trial in the management of chronic lower back pain in a French automotive industry: an observational study. Arch Phys Med Rehabil. 2011;92(12):1927-36.e4. Excluded: sample size too small. [pmid: 22133239].
Nazzal ME, Saadah MA, Saadah LM, et al. Management options of chronic low back pain. A randomized blinded clinical trial. Neurosciences. 2013;18(2):152-9. Excluded: wrong intervention. [pmid: 23545614].
Neblett R, Mayer TG, Brede E, et al. Correcting abnormal flexion-relaxation in chronic lumbar pain: responsiveness to a new biofeedback training protocol. Clin J Pain. 2010;26(5):403-9. Excluded: wrong intervention. [pmid: 20473047].
Negrini S, Imperio G, Villafane JH, et al. Systematic reviews of physical and rehabilitation medicine Cochrane contents. Part 1. Disabilities due to spinal disorders and pain syndromes in adults. Eur J Phys Rehabil Med. 2013;49(4):597-609. Excluded: wrong population. [pmid: 24084418].
Nelson-Wong E, Callaghan JP. Changes in muscle activation patterns and subjective low back pain ratings during prolonged standing in response to an exercise intervention. J Electromyogr Kinesiol. 2010;20(6):1125-33. Excluded: wrong outcome. [pmid: 20674390].
Nemcic T, Budisin V, Vrabec-Matkovic D, et al. Comparison of the effects of land-based and water-based therapeutic exercises on the range of motion and physical disability in patients with chronic low-back pain: single-blinded randomized study. Acta Clin. 2013;52(3):321-7. Excluded: wrong intervention. [pmid: 24558764].
Nemes D, Amaricai E, Tanase D, et al. Physical therapy vs. medical treatment of musculoskeletal disorders in dentistry--a randomised prospective study. Ann Agric Environ Med. 2013;20(2):301-6. Excluded: wrong population. [pmid: 23772581].
Netchanok S, Wendy M, Marie C, et al. The effectiveness of Swedish massage and traditional Thai massage in treating chronic low back pain: a review of the literature. Complement Ther Clin Pract. 2012;18(4):227-34. Excluded: Pre-2007 systematic review or superseded by a more recent review. [pmid: 23059437].
Newcomer KL, Vickers Douglas KS, Shelerud RA, et al. Is a videotape to change beliefs and behaviors superior to a standard videotape in acute low back pain? A randomized controlled trial. Spine J. 2008;8(6):940-7. Excluded: wrong intervention. [pmid: 18037355].
Ngowsiri K, Tanmahasamut P, Sukonthasab S. Rusie Dutton traditional Thai exercise promotes health related physical fitness and quality of life in menopausal women. Complement Ther Clin Pract. 2014;20(3):164-71. Excluded: wrong population. [pmid: 25066942].
Nigg BM, Davis E, Lindsay D, et al. The effectiveness of an unstable sandal on low back pain and golf performance. Clin J Sport Med. 2009;19(6):464-70. Excluded: wrong intervention. [pmid: 19898073].
Nnoaham KE, Kumbang J. Transcutaneous electrical nerve stimulation (TENS) for chronic pain. Cochrane Database Syst Rev. 2008;(3). CD003222. Excluded: wrong population. [pmid: 18646088].
Nolet PS, Kristman VL, Cote P, et al. Is low back pain associated with worse health-related quality of life 6 months later?. Eur Spine J. 2015;24(3):458-66. Excluded: wrong intervention. [pmid: 25391622].
Noori S, Ghasemi G, Khayambashi K, et al. Effect of exercise therapy and physiotherapy on patients with chronic low back pain. J Korean Orient Med. 2011;29(151). Excluded: not English language but possibly relevant.
Norlund A, Ropponen A, Alexanderson K. Multidisciplinary interventions: review of studies of return to work after rehabilitation for low back pain. J Rehabil Med. 2009;41(3):115-21. Excluded: Pre-2007 systematic review or superseded by a more recent review. [pmid: 19229442].
Norris C, Matthews M. The role of an integrated back stability program in patients with chronic low back pain. Complement Ther Clin Pract. 2008;14(4):255-63. Excluded: sample size too small. [pmid: 18940712].
O'Connell NE, Wand BM, Bausell RB. Acupuncture for low back pain: interpretive leaps of faith. Re: Yuan J, Purepong N, Kerr DP, et al. Effectiveness of acupuncture for low back pain. A systematic review. 2008;33:23:E887-900. Spine. 2009;34(7):752. author reply 3. Excluded: not a study (letter, editorial, non-systematic review article). [pmid: 19333116].
O'Connell NE, Wand BM, Goldacre B. Interpretive bias in acupuncture research?: A case study. Eval Health Prof. 2009;32(4):393-409. Excluded: wrong study deisgn for key question. [pmid: 19942631].
O'Connor SR, Tully MA, Ryan B, et al. Walking exercise for chronic musculoskeletal pain: systematic review and meta-analysis. Arch Phys Med Rehabil. 2015;96(4):724-34 e3. Excluded: wrong population. [pmid: 25529265].
Oguzhan H, Ozyurek S, Kaya E. Effectiveness of back school program to quality of life and disability in patients with chronic low back pain. Eur J Pain Suppl. 2011;5(1). Excluded: wrong intervention.
Oh C, Biondi DM, Xiang J, et al. The efficacy and tolerability of tapentadol Immediate Release (IR) Versus Oxycodone IR for moderate to severe acute low back pain with radicular leg pain. Pain Med. 2012. Excluded: not English language but possibly relevant.
Oh MJ, Song HS. Effect of Sa-Am acupuncture bladder reinforcing method to Ryodoraku on the patients with chronic low back pain. J Korean Acupunct & Mox Med Sci. 2012;29(2):37-42. Excluded: not English language but possibly relevant.
Oh MJ, Song HS. Effect of acupuncture treatment on Pyodoraku score of the patients with chronic low back pain. J Korean Acupunct & Mox Med Sci. 2012;29(3):115-20. Excluded: not English language but possibly relevant.
Oke KI, Umebese PFA. Evaluation of the efficacy of pulsed electromagnetic therapy in the treatment of back pain: a randomized controlled trial in a tertiary hospital in Nigeria. West Indian Med J. 2013;62(3):205-9. Excluded: wrong intervention. [pmid: 24564041].
Okoro T, Tafazal SI, Longworth S, et al. Tumor necrosis alpha-blocking agent (etanercept): a triple blind randomized controlled trial of its use in treatment of sciatica. J Spinal Disord Tech. 2010;23(1):74-7. Excluded: wrong intervention. [pmid: 20072036].
Olivier N, Lepretre A, Caby I, et al. Does exercise therapy for chronic lower-back pain require daily isokinetic reinforcement of the trunk muscles?. Ann Readapt Med Phys. 2008;51(4):284-91. Excluded: not English language but possibly relevant. [pmid: 18394742].
Onda A, Kikuchi S-I, Yabuki S, et al. Limaprost alfadex and nonsteroidal anti-inflammatory drugs for sciatica due to lumbar spinal stenosis. Eur Spine J. 2013;22(4):794-801. Excluded: wrong intervention. [pmid: 23090093].
Ono R, Higashi T, Suzukamo Y, et al. Higher internality of health locus of control is associated with the use of complementary and alternative medicine providers among patients seeking care for acute low-back pain. Clin J Pain. 2008;24(8):725-30. Excluded: wrong study deisgn for key question. [pmid: 18806538].
Oosterhuis T, Costa LO, Maher CG, et al. Rehabilitation after lumbar disc surgery. Cochrane Database Syst Rev. 2014;3. CD003007. Excluded: wrong population. [pmid: 24627325].
Orrock PJ, Myers SP. Osteopathic intervention in chronic non-specific low back pain: a systematic review. BMC Musculoskelet Disord. 2013;14:129. Excluded: Pre-2007 systematic review or superseded by a more recent review. [pmid: 23570655].
Oyemade GA, Onadeko BO. A controlled clinical study comparing sulindac with ibuprofen and aspirin in the treatment of musculo-skeletal diseases. J Int Med Res. 1979;7(6):556-9. Excluded: wrong outcome. [pmid: 160348].
Pabst H, Schaefer A, Staiger C, et al. Combination of comfrey root extract plus methyl nicotinate in patients with conditions of acute upper or low back pain: a multicentre randomised controlled trial. Phytother Res. 2013;27(6):811-7. Excluded: wrong intervention. [pmid: 22887778].
Pach D, Yang-Strobel X, Ludtke R, et al. Standardized versus Individualized Acupuncture for Chronic Low Back Pain: A Randomized Controlled Trial. Evid Based Complement Alternat Med. 2013;2013:125937. Excluded: wrong study deisgn for key question. [pmid: 24288556].
Padua R, Bondi R, Ceccarelli E, et al. Re: A randomized study of back school in women with chronic low back pain. Quality of life at three, six, and twelve months follow-up. Spine. 2009;34(12):1336. Excluded: not a study (letter, editorial, non-systematic review article). [pmid: 19455011].
Paolucci T, Fusco A, Iosa M, et al. The efficacy of a perceptive rehabilitation on postural control in patients with chronic nonspecific low back pain. Int J Rehabil Res. 2012;35(4):360-6. Excluded: wrong intervention. [pmid: 22842780].
Paolucci T, Morone G, Iosa M, et al. Psychological features and outcomes of the Back School treatment in patients with chronic non-specific low back pain. A randomized controlled study. Eur J Phys Rehabil Med. 2012;48(2):245-53. Excluded: wrong intervention. [pmid: 22095057].
Parker J, Heinking KP, Kappler RE. Efficacy of osteopathic manipulative treatment for low back pain in euhydrated and hypohydrated conditions: a randomized crossover trial. J Am Osteopath Assoc. 2012;112(5):276-84. Excluded: wrong comparison. [pmid: 22582197].
Parkin-Smith GF, Norman IJ, Briggs E, et al. A structured protocol of evidence-based conservative care compared with usual care for acute nonspecific low back pain: a randomized clinical trial. Arch Phys Med Rehabil. 2012;93(1):11-20. Excluded: not a study (letter, editorial, non-systematic review article). [pmid: 22200382].
Parkinson L, Sibbritt D, Bolton P, et al. Well-being outcomes of chiropractic intervention for lower back pain: a systematic review. Clin Rheumatol. 2013;32(2):167-80. Excluded: using original studies instead (e.g. meta-analysis, compiled study data, or data from another publication). [pmid: 23149906].
Peniston JH, Gould E. Oxymorphone extended release for the treatment of chronic low back pain: a retrospective pooled analysis of enriched-enrollment clinical trial data stratified according to age, sex, and prior opioid use. Clin Ther. 2009;31(2):347-59. Excluded: wrong study deisgn for key question. [pmid: 19302907].
Peniston JH, Hu X, Potts SL, et al. Tolerability of concomitant use of selective serotonin reuptake inhibitors or serotonin-norepinephrine reuptake inhibitors and oxymorphone extended release. Postgrad Med. 2012;124(2):114-22. Excluded: wrong study deisgn for key question. [pmid: 22437221].
Peniston JH, Xiang Q, Wieman MS. Safety of oxymorphone extended release for chronic low back pain in patients with diabetes, hypertension, or cardiovascular disease (CVD). Consult Pharm. 2011;26(10):747. Excluded: not a study (letter, editorial, non-systematic review article).
Pereira LM, Obara K, Dias JM, et al. Comparing the Pilates method with no exercise or lumbar stabilization for pain and functionality in patients with chronic low back pain: systematic review and meta-analysis. Clin Rehabil. 2012;26(1):10-20. Excluded: Pre-2007 systematic review or superseded by a more recent review. [pmid: 21856719].
Pergolizzi JV Jr., Raffa RB, Taylor R Jr., et al. A review of duloxetine 60 mg once-daily dosing for the management of diabetic peripheral neuropathic pain, fibromyalgia, and chronic musculoskeletal pain due to chronic osteoarthritis pain and low back pain. Pain pract. 2013;13(3):239-52. Excluded: using original studies instead (e.g. meta-analysis, compiled study data, or data from another publication). [pmid: 22716295].
Perrot S, Javier RM, Marty M, et al. Is there any evidence to support the use of anti-depressants in painful rheumatological conditions? Systematic review of pharmacological and clinical studies. Rheumatology (Oxford). 2008;47(8):1117-23. Excluded: using original studies instead (e.g. meta-analysis, compiled study data, or data from another publication). [pmid: 18445628].
Persson LC, Moritz U, Brandt L, et al. Cervical radiculopathy: pain, muscle weakness and sensory loss in patients with cervical radiculopathy treated with surgery, physiotherapy or cervical collar. A prospective, controlled study. Eur Spine J. 1997;6(4):256-66. Excluded: wrong intervention. [pmid: 9294750].
Peterson CK, Bolton J, Humphreys BK. Predictors of improvement in patients with acute and chronic low back pain undergoing chiropractic treatment. J Manipulative Physiol Ther. 2012;35(7):525-33. Excluded: wrong study deisgn for key question. [pmid: 22858233].
Peterson CK, Humphreys BK, Hodler J, et al. Gender differences in pain levels before and after treatment: a prospective outcomes study on 3,900 Swiss patients with musculoskeletal complaints. BMC Musculoskelet Disord. 2012;13:241. Excluded: wrong study deisgn for key question. [pmid: 23217116].
Peul WC, van den Hout WB, Brand R, et al. Prolonged conservative care versus early surgery in patients with sciatica caused by lumbar disc herniation: two year results of a randomised controlled trial. BMJ. 2008;336(7657):1355-8. Excluded: wrong population. [pmid: 18502911].
Pingot J, Pingot M, Labecka M, et al. The use of Saunders lumbar traction in physiotherapy of patients with chronic lower back pain. Pol Merkuriusz Lek. 2014;36(215):330-5. Excluded: not English language but possibly relevant. [pmid: 24964511].
Podichetty VK, Varley ES. Re: Oleske D M, Lavender S A, Andersson G B, et al. Are back supports plus education more effective than education alone in promoting recovery from low back pain? Results from a randomized clinical trial. Spine 2007;32:2050-7. Spine. 2008;33(3):349-50. Excluded: not a study (letter, editorial, non-systematic review article). [pmid: 18303469].
Podichetty VK, Varley ES, Secic M. Role of patient-based health status outcome measurements in opioid management for low back pain. J Opioid Manag. 2008;4(3):153-62. Excluded: wrong study deisgn for key question. [pmid: 18717510].
Poiraudeau S, Rannou F, Revel M. Functional restoration programs for low back pain: a systematic review. Ann Readapt Med Phys. 2007;50(6):425-9. Excluded: Pre-2007 systematic review or superseded by a more recent review. [pmid: 17512079].
Poitras S, Brosseau L. Evidence-informed management of chronic low back pain with transcutaneous electrical nerve stimulation, interferential current, electrical muscle stimulation, ultrasound, and thermotherapy. Spine J. 2008;8(1):226-33. Excluded: Pre-2007 systematic review or superseded by a more recent review. [pmid: 18164470].
Pop T, Austrup H, Preuss R, et al. Effect of TENS on pain relief in patients with degenerative disc disease in lumbosacral spine. Ortop Tramatol Rehabil. 2010;12(4):289-300. Excluded: wrong comparison. [pmid: 20876922].
Popovic DB, Bijelic G, Miler V, et al. Lumbar stimulation belt for therapy of low-back pain. Artif Organs. 2009;33(1):54-60. Excluded: wrong intervention. [pmid: 19178441].
Portenoy RK, Messina J, Xie F, et al. Fentanyl buccal tablet (FBT) for relief of breakthrough pain in opioid-treated patients with chronic low back pain: a randomized, placebo-controlled study. Curr Med Res Opin. 2007;23(1):223-33. Excluded: wrong population. [pmid: 17207304].
Posadzki P. Is spinal manipulation effective for pain? An overview of systematic reviews. Pain Med. 2012;13(6):754-61. Excluded: wrong population. [pmid: 22621391].
Posadzki P, Ernst E. Spinal manipulation: an update of a systematic review of systematic reviews. N Z Med J. 2011;124(1340):55-71. Excluded: using original studies instead (e.g. meta-analysis, compiled study data, or data from another publication). [pmid: 21952385].
Posadzki P, Ernst E. Yoga for low back pain: a systematic review of randomized clinical trials. Clin Rheumatol. 2011;30(9):1257-62. Excluded: Pre-2007 systematic review or superseded by a more recent review. [pmid: 21590293].
Posadzki P, Lizis P, Hagner-Derengowska M. Pilates for low back pain: a systematic review. Complement Ther Clin Pract. 2011;17(2):85-9. Excluded: Pre-2007 systematic review or superseded by a more recent review. [pmid: 21457897].
Pota V. Association of buprenorphine TDS and pregabalin in the treatment of low back pain. Eur J Pain. 2007;11(S1):S83. Excluded: wrong study deisgn for key question.
Prady SL, Thomas K, Esmonde L, et al. The natural history of back pain after a randomised controlled trial of acupuncture vs usual care--long term outcomes. Acupunct Med. 2007;25(4):121-9. Excluded: using original studies instead (e.g. meta-analysis, compiled study data, or data from another publication). [pmid: 18160922].
Pua Y-H, Cai C-C, Lim K-C. Treadmill walking with body weight support is no more effective than cycling when added to an exercise program for lumbar spinal stenosis: a randomised controlled trial. Aust J Physiother. 2007;53(2):83-9. Excluded: sample size too small for exercise. [pmid: 17535143].
Quinn F, Hughes CM, Baxter GD. Reflexology in the management of low back pain: a pilot randomised controlled trial. Complement Ther Med. 2008;16(1):3-8. Excluded: wrong intervention. [pmid: 18346622].
Ralha L, Oliveira LG, Chahade WH, et al. Efficacy and tolerability of celecoxib versus diclofenac: Results of a multicenter, randomized, double-blind, noninferiority study in subjects with acute low back pain. [Portuguese]. Rev Bras Med. 2008;65(11):378-87. Excluded: not English language but possibly relevant.
Rampp T, Michalsen A, Ludtke R, et al. Pain-relieving effect of cantharidin blister on lumbar spinal stenosis. Forsch Komplementarmed. 2009;16(4):246-50. Excluded: not English language but possibly relevant. [pmid: 19729935].
Ratajczak B, Hawrylak A, Demidas A, et al. Effectiveness of diadynamic currents and transcutaneous electrical nerve stimulation in disc disease lumbar part of spine. J Back Musculoskeletal Rehabil. 2011;24(3):155-9. Excluded: wrong study deisgn for key question. [pmid: 21849729].
Rauck RL, Bookbinder SA, Bunker TR, et al. A randomized, open-label, multicenter trial comparing once-a-day AVINZA (morphine sulfate extended-release capsules) versus twice-a-day OxyContin (oxycodone hydrochloride controlled-release tablets) for the treatment of chronic, moderate to severe low back pain: improved physical functioning in the ACTION trial. J Opioid Manag. 2007;3(1):35-43. Excluded: wrong comparison. [pmid: 17367093].
Reese C, Mittag O. Psychological interventions in the rehabilitation of patients with chronic low back pain: evidence and recommendations from systematic reviews and guidelines. Int J Rehabil Res. 2013;36(1):6-12. Excluded: using original studies instead (e.g. meta-analysis, compiled study data, or data from another publication). [pmid: 23168359].
Rhee HS, Kim YH, Sung PS. A randomized controlled trial to determine the effect of spinal stabilization exercise intervention based on pain level and standing balance differences in patients with low back pain. Med Sci Monit. 2012;18(3):CR174-81. Excluded: sample size too small. [pmid: 22367128].
Ribeiro DC, Sole G, Abbott JH, et al. Extrinsic feedback and management of low back pain: A critical review of the literature. Manual Ther. 2011;16(3):231-9. Excluded: using original studies instead (e.g. meta-analysis, compiled study data, or data from another publication). [pmid: 21269869].
Ribeiro LH, Jennings F, Jones A, et al. Effectiveness of a back school program in low back pain. Clin Exp Rheumatol. 2008;26(1):81-8. Excluded: wrong intervention. [pmid: 18328151].
Richards MC, Ford JJ, Slater SL, et al. The effectiveness of physiotherapy functional restoration for post-acute low back pain: a systematic review. Manual Ther. 2013;18(1):4-25. Excluded: using original studies instead (e.g. meta-analysis, compiled study data, or data from another publication). [pmid: 22796390].
Roche-Leboucher G, Petit-Lemanac'h A, Bontoux L, et al. Multidisciplinary intensive functional restoration versus outpatient active physiotherapy in chronic low back pain: a randomized controlled trial. Spine. 2011;36(26):2235-42. Excluded: wrong intervention. [pmid: 21415807].
Roelofs DDMP, Deyo RA, Koes BW, et al. Non-steroidal anti-inflammatory drugs for low back pain. Cochrane Database Syst Rev. 2011;(2). Excluded: using original studies instead (e.g. meta-analysis, compiled study data, or data from another publication).
Roelofs PDDM, Deyo RA, Koes BW, et al. Nonsteroidal anti-inflammatory drugs for low back pain: an updated Cochrane review. Spine. 2008;33(16):1766-74. Excluded: Pre-2007 systematic review or superseded by a more recent review. [pmid: 18580547].
Roelofs PDDM, Deyo RA, Koes BW, et al. Non-steroidal anti-inflammatory drugs for low back pain. Cochrane Database Syst Rev. 2008;(1). CD000396. Excluded: Pre-2007 systematic review of superceded by a more recent review for the intervention of acetaminophen, but included for the intervention of NSAIDs. [pmid: 18253976].
Romano CL, Romano D, Lacerenza M. Antineuropathic and antinociceptive drugs combination in patients with chronic low back pain: a systematic review. Pain Res Treat. 2012;2012:154781. Excluded: using original studies instead (e.g. meta-analysis, compiled study data, or data from another publication). [pmid: 22619711].
Rosner AL, Conable KM, Edelmann T. Influence of foot orthotics upon duration of effects of spinal manipulation in chronic back pain patients: a randomized clinical trial. J Manipulative Physiol Ther. 2014;37(2):124-40. Excluded: wrong intervention. [pmid: 24412249].
Rossi M, Ianigro G, Liberatoscioli G, et al. Eperisone versus tizanidine for treatment of chronic low back pain. Minerva Med. 2012;103(3):143-9. Excluded: wrong intervention. [pmid: 22653094].
Rossignol M, Abenhaim L, Seguin P, et al. Coordination of primary health care for back pain. A randomized controlled trial. Spine (Phila Pa 1976). 2000;25(2):251-8. discussion 8-9. Excluded: wrong intervention. [pmid: 10685491].
Rubinstein SM, Terwee CB, Assendelft WJJ, et al. Spinal manipulative therapy for acute low back pain: an update of the cochrane review. Spine. 2013;38(3):E158-77. Excluded: using original studies instead (e.g. meta-analysis, compiled study data, or data from another publication). [pmid: 23169072].
Rubinstein SM, van Middelkoop M, Assendelft JJW, et al. Spinal manipulative therapy for chronic low-back pain. Cochrane Database Syst Rev. 2013;(1). Excluded: using original studies instead (e.g. meta-analysis, compiled study data, or data from another publication).
Rubinstein SM, van Middelkoop M, Assendelft WJJ, et al. Spinal manipulative therapy for chronic low-back pain: an update of a Cochrane review. Spine. 2011;36(13):E825-46. Excluded: using original studies instead (e.g. meta-analysis, compiled study data, or data from another publication). [pmid: 21593658].
Rubinstein SM, van Middelkoop M, Kuijpers T, et al. A systematic review on the effectiveness of complementary and alternative medicine for chronic non-specific low-back pain. Eur Spine J. 2010;19(8):1213-28. Excluded: Pre-2007 systematic review or superseded by a more recent review. [pmid: 20229280].
Rusinyol FC, Perice RV, Boronat ER, et al. Effects of two different doses of eperisone in the treatment of acute low back pain. J Appl Res. 2009;9(1-2):23-9. Excluded: wrong intervention.
Ryan CG, Gray HG, Newton M, et al. Pain biology education and exercise classes compared to pain biology education alone for individuals with chronic low back pain: a pilot randomised controlled trial. Manual Ther. 2010;15(4):382-7. Excluded: wrong intervention. [pmid: 20359937].
Sahar T, Cohen MJ, Ne'eman V, et al. Insoles for prevention and treatment of back pain. Cochrane Database Syst Rev. 2007;(4). CD005275. Excluded: Pre-2007 systematic review or superseded by a more recent review. [pmid: 17943845].
Sahin F, Yilmaz F, Kotevoglu N, et al. The efficacy of physical therapy and physical therapy plus calcitonin in the treatment of lumbar spinal stenosis. Yonsei Med J. 2009;50(5):683-8. Excluded: wrong population. [pmid: 19881973].
Sahin N, Albayrak I, Durmus B, et al. Effectiveness of back school for treatment of pain and functional disability in patients with chronic low back pain: a randomized controlled trial. J Rehabil Med. 2011;43(3):224-9. Excluded: wrong intervention. [pmid: 21305238].
Sakai Y, Matsuyama Y, Nakamura H, et al. The effect of muscle relaxant on the paraspinal muscle blood flow: a randomized controlled trial in patients with chronic low back pain. Spine. 2008;33(6):581-7. Excluded: wrong intervention. [pmid: 18344850].
Sakalauskiene G. Nonpharmacological correction of low back pain by single or integrated means of medical rehabilitation and the evaluation of their effectiveness. Medicina (Kaunas). 2009;45(9):739-49. Excluded: not English language but possibly relevant. [pmid: 19834312].
Saldana MT, Navarro A, Perez C, et al. Patient-reported-outcomes in subjects with painful lumbar or cervical radiculopathy treated with pregabalin: evidence from medical practice in primary care settings. Rheumatol Int. 2010;30(8):1005-15. Excluded: wrong study deisgn for key question. [pmid: 19798503].
Salerno SM, Browning R, Jackson JL. The effect of antidepressant treatment on chronic back pain: a meta-analysis. Arch Intern Med. 2002;162(1):19-24. Excluded: relevant to background only. [pmid: 11784215].
Salomonowitz G, Salfinger H, Hahne J, et al. Impact of magnetic resonance therapy on sickness absence of patients with nerve root irritation following a lumbar disc problem. Z Orthop Unfall. 2011;149(5):575-81. Excluded: not English language but possibly relevant. [pmid: 21984428].
Santaella Da Fonseca Lopes De Sousa K, Garcia Orfale A, Mara Meireles S, et al. Assessment of a biofeedback program to treat chronic low back pain. J Musculoskelet Pain. 2009;17(4):369-77. Excluded: wrong intervention.
Santaguida PL, Gross A, Busse J, et al. Complementary and alternative medicine in back pain utilization report. Evid rep/technol assess. 2009;(177):1-221. Excluded: wrong outcome. [pmid: 20629474].
Sawazaki K, Mukaino Y, Kinoshita F, et al. Acupuncture can reduce perceived pain, mood disturbances and medical expenses related to low back pain among factory employees. Ind Health. 2008;46(4):336-40. Excluded: wrong population. [pmid: 18716381].
Scharrer M, Ebenbichler G, Pieber K, et al. A systematic review on the effectiveness of medical training therapy for subacute and chronic low back pain. Eur J Phys Rehabil Med. 2012;48(3):361-70. Excluded: using original studies instead (e.g. meta-analysis, compiled study data, or data from another publication). [pmid: 22820818].
Schell E, Theorell T, Hasson D, et al. Impact of a web-based stress management and health promotion program on neck-shoulder-back pain in knowledge workers? 12 month prospective controlled follow-up. J Occup Environ Med. 2008;50(6):667-76. Excluded: wrong intervention. [pmid: 18545094].
Schenkman ML, Jordan S, Akuthota V, et al. Functional movement training for recurrent low back pain: lessons from a pilot randomized controlled trial. Pm R. 2009;1(2):137-46. Excluded: sample size too small. [pmid: 19627887].
Schiltenwolf M, Akbar M, Hug A, et al. Evidence of specific cognitive deficits in patients with chronic low back pain under long-term substitution treatment of opioids. Pain physician. 2014;17(1):9-20. Excluded: wrong study deisgn for key question. [pmid: 24452649].
Schneider M, Haas M, Stevans J, et al. A comparison of chiropractic manipulation methods and usual medical care for low back pain: A randomized controlled clinical trial. J Altern Complement Med. 20(5):A22-A3. Excluded: not a study (letter, editorial, non-systematic review article).
Schneider MJ, Haas M, Glick RM, et al. A comparison of spinal manipulation methods and usual medical care for low back pain: A randomized clinical trial. Spine J. 14(11 SUPPL. 1):S46-S7. Excluded: not a study (letter, editorial, non-systematic review article).
Schnitzer TJ, Ferraro A, Hunsche E, et al. A comprehensive review of clinical trials on the efficacy and safety of drugs for the treatment of low back pain. J Pain Sympt Mgmt. 2004;28(1):72-95. Excluded: relevant to background only. [pmid: 15223086].
Schukro RP, Oehmke M, Reitinger C, et al. Efficacy of duloxetine versus placebo in patients with chronic low back pain and a neuropathic component. Eur J Anaesthesiol. Conference: European Anaesthesiology Congress, EUROANAESTHESIA 2014. Stockholm Sweden. Conference Start: 20140531 Conference End: 20140603. Conference Publication:(var.pagings). 2014:215. Excluded: not a study (letter, editorial, non-systematic review article).
Schwittay A, Baron R, Binder A, et al. Effects of tapentadol prolonged release (pr) versus oxycodone/naloxone pr on quality-of-life/function measures in patients with severe, chronic low back pain with a neuropathic pain component. Pain pract. Conference: 7th World Congress of the World Institute of Pain, WIP 2014. Maastricht Netherlands. Conference Start: 20140507 Conference End: 20140510. Conference Publication:(var.pagings). 2014:62. Excluded: not a study (letter, editorial, non-systematic review article).
Seco J, Kovacs FM, Urrutia G. The efficacy, safety, effectiveness, and cost-effectiveness of ultrasound and shock wave therapies for low back pain: a systematic review. Spine J. 2011;11(10):966-77. Excluded: relevant to background only. [pmid: 21482199].
Sertpoyraz F, Eyigor S, Karapolat H, et al. Comparison of isokinetic exercise versus standard exercise training in patients with chronic low back pain: a randomized controlled study. Clin Rehabil. 2009;23(3):238-47. Excluded: sample size too small. [pmid: 19218298].
Shapiro D, Buynak R, Okamoto A, et al. Results of a randomized, double-blind, placebo- and active-controlled trial of tapentadol extended release for chronic low back pain. Rheumatology (Oxford). Conference: Rheumatology 2010 - British Society for Rheumatology, BSR and British Health Professionals in Rheumatology, BHPR Annual Meeting 2010. Birmingham United Kingdom. Conference Start: 20100420 Conference End: 20100423. Conference Publication:(var.pagings). 2010;49:i78-i79. 2010. Date of Publication: April 2010.):-i79. Excluded: not a study (letter, editorial, non-systematic review article).
Sheets C, Machado LAC, Hancock M, et al. Can we predict response to the McKenzie method in patients with acute low back pain? A secondary analysis of a randomized controlled trial. Eur Spine J. 2012;21(7):1250-6. Excluded: not a study (letter, editorial, non-systematic review article). [pmid: 22109566].
Shell WE, Charuvastra EH, DeWood MA, et al. A double-blind controlled trial of a single dose naproxen and an amino acid medical food theramine for the treatment of low back pain. Am J Ther. 2012;19(2):108-14. Excluded: wrong intervention. [pmid: 20861716].
Sherman KJ, Cherkin DC, Ichikawa L, et al. Characteristics of patients with chronic back pain who benefit from acupuncture. BMC Musculoskelet Disord. 2009;10:114. Excluded: using original studies instead (e.g. meta-analysis, compiled study data, or data from another publication). [pmid: 19772583].
Sherman KJ, Cherkin DC, Ichikawa L, et al. Treatment expectations and preferences as predictors of outcome of acupuncture for chronic back pain. Spine. 2010;35(15):1471-7. Excluded: using original studies instead (e.g. meta-analysis, compiled study data, or data from another publication). [pmid: 20535051].
Shete KM, Suryawanshi P, Gandhi N. Management of low back pain in computer users: A multidisciplinary approach. J Craniovertebr Junction Spine. 2012;3(1):7-10. Excluded: wrong population. [pmid: 23741122].
Shin BC, Kong JC, Park TY, et al. Bee venom acupuncture for chronic low back pain: A randomised, sham-controlled, triple-blind clinical trial. Eur J Int Med. 2012;4(3):e271-e80. Excluded: wrong intervention.
Shin J-S, Ha I-H, Lee J, et al. Effects of motion style acupuncture treatment in acute low back pain patients with severe disability: a multicenter, randomized, controlled, comparative effectiveness trial. Pain. 2013;154(7):1030-7. Excluded: wrong intervention. [pmid: 23639822].
Shostak NA, Pravdiuk NG, Koriakina IN. Low back pain in young subjects: a new approach to therapy. Terapevticheskii arkhiv. 2009;81(10):52-6. Excluded: not English language but possibly relevant. [pmid: 19947442].
Shutov AA, Panasiuk II. Efficacy of rehabilitation of patients with chronic primary low back pain at the spa Klyuchi using balneopelotherapy and transcranial electrostimulation. Vopr Kurortol Fizioter Lech Fiz Kult. 2007;(2):16-8. Excluded: not English language but possibly relevant. [pmid: 17563982].
Sicras-Mainar A, Rejas-Gutierrez J, Navarro-Artieda R, et al. Cost comparison of adding pregabalin or gabapentin for the first time to the therapy of patients with painful axial radiculopathy treated in Spain. Clin Exp Rheumatol. 2013;31(3):372-81. Excluded: wrong study deisgn for key question. [pmid: 23432967].
Silva Parreira P, Menezes Costa Lda C, Takahashi R, et al. Do convolutions in Kinesio Taping matter? Comparison of two Kinesio Taping approaches in patients with chronic non-specific low back pain: protocol of a randomised trial. J Physiother. 2013;59(1):52. discussion. Excluded: not a study (letter, editorial, non-systematic review article). [pmid: 23419916].
Simmerman SM, Sizer PS, Dedrick GS, et al. Immediate changes in spinal height and pain after aquatic vertical traction in patients with persistent low back symptoms: a crossover clinical trial. Pm R. 2011;3(5):447-57. Excluded: wrong intervention. [pmid: 21570033].
Sjogren T, Long N, Storay I, et al. Group hydrotherapy versus group land-based treatment for chronic low back pain. Physiother Res Int. 1997;2(4):212-22. Excluded: wrong intervention. [pmid: 9408932].
Skljarevski V, Bair MJ, Ossanna MJ, et al. OMERACT responder analysis of patients treated with duloxetine for chronic low back pain. [abstract]. Arthritis Rheum. Conference: American College of Rheumatology/Association of Rheumatology Health Professionals Annual Scientific Meeting, ACR/ARHP. Atlanta, Georgia. Nov. 6-11, 2010. 2010;(62 Suppl 10):175. Excluded: not a study (letter, editorial, non-systematic review article).
Skljarevski V, Desaiah D, Liu-Seifert H, et al. Efficacy of duloxetine in chronic low back pain. Eur J Neurol. 2008;15(Suppl 3):320. Excluded: not a study (letter, editorial, non-systematic review article). [pmid: 18353123].
Skljarevski V, Liu P, Zhang S, et al. Efficacy and Safety of Duloxetine in Patients with Chronic Low Back Pain Who Used versus Did Not Use Concomitant Nonsteroidal Anti-Inflammatory Drugs or Acetaminophen: A Post Hoc Pooled Analysis of 2 Randomized, Placebo-Controlled Trials. Pain Res Treat. 2012;2012:296710. Excluded: wrong study deisgn for key question. [pmid: 22550577].
Skljarevski V, Zhang S, Chappell AS, et al. Maintenance of effect of duloxetine in patients with chronic low back pain: a 41-week uncontrolled, dose-blinded study. Pain Med. 2010;11(5):648-57. Excluded: wrong study deisgn for key question. [pmid: 20546509].
Skljarevski V, Zhang S, Desaiah D, et al. Effect of duloxetine 60 mg once daily versus placebo in patients with chronic low back pain: A 12-week, randomized, double-blind trial. Pain Med. 2010;11(2):322. Excluded: not a study (letter, editorial, non-systematic review article).
Slade SC, Keating JL. Unloaded movement facilitation exercise compared to no exercise or alternative therapy on outcomes for people with nonspecific chronic low back pain: a systematic review. J Manipulative Physiol Ther. 2007;30(4):301-11. Excluded: Pre-2007 systematic review or superseded by a more recent review. [pmid: 17509439].
Slade SC, Keating JL. Effects of preferred-exercise prescription compared to usual exercise prescription on outcomes for people with non-specific low back pain: a randomized controlled trial [ACTRN12608000524392]. BMC Musculoskeletal Disorders. 2009;10:14. Excluded: not a study (letter, editorial, non-systematic review article). [pmid: 19173747].
Slater MA, Weickgenant AL, Greenberg MA, et al. Preventing progression to chronicity in first onset, subacute low back pain: an exploratory study. Arch Phys Med Rehabil. 2009;90(4):545-52. Excluded: wrong outcome. [pmid: 19345767].
Slater SL, Ford JJ, Richards MC, et al. The effectiveness of sub-group specific manual therapy for low back pain: a systematic review. Manual Ther. 2012;17(3):201-12. Excluded: Pre-2007 systematic review or superseded by a more recent review. [pmid: 22386046].
Sleptsova M, Woessmer B, Grossman P, et al. Culturally sensitive group therapy for Turkish patients suffering from chronic pain: a randomised controlled intervention trial. Swiss Med Wkly. 2013;143:w13875. Excluded: wrong population. [pmid: 24222526].
Smeets RJ, Vlaeyen JW, Kester AD, et al. Reduction of pain catastrophizing mediates the outcome of both physical and cognitive-behavioral treatment in chronic low back pain. J Pain. 2006;7(4):261-71. Excluded: using original studies instead (e.g. meta-analysis, compiled study data, or data from another publication). [pmid: 16618470].
Smeets RJEM, Maher CG, Nicholas MK, et al. Do psychological characteristics predict response to exercise and advice for subacute low back pain?. Arthritis Rheum. 2009;61(9):1202-9. Excluded: wrong outcome. [pmid: 19714601].
Smith D, Bissell G, Bruce-Low S, et al. The effect of lumbar extension training with and without pelvic stabilization on lumbar strength and low back pain. J Back Musculoskeletal Rehabil. 2011;24(4):241-9. Excluded: sample size too small. [pmid: 22142713].
Sogaard R, Bunger CE, Laurberg I, et al. Cost-effectiveness evaluation of an RCT in rehabilitation after lumbar spinal fusion: a low-cost, behavioural approach is cost-effective over individual exercise therapy. Eur Spine J. 2008;17(2):262-71. Excluded: wrong outcome. [pmid: 17713794].
Soonawalla DF, Joshi N. Efficacy of thiocolchicoside in Indian patients suffering from low back pain associated with muscle spasm. J Indian Med Assoc. 2008;106(5):331-5. Excluded: wrong intervention. [pmid: 18839644].
Sorensen PH, Bendix T, Manniche C, et al. An educational approach based on a non-injury model compared with individual symptom-based physical training in chronic LBP. A pragmatic, randomised trial with a one-year follow-up. BMC Musculoskelet Disord. 2010;11:212. Excluded: wrong intervention. [pmid: 20849601].
Staal BJ, de Bie R, de Vet CWH, et al. Injection therapy for subacute and chronic low-back pain. Cochrane Database Syst Rev. 2011;(2). Excluded: wrong intervention.
Staal JB, de Bie R, de Vet HC, et al. Injection therapy for subacute and chronic low-back pain. Cochrane Database Syst Rev. 2008;(3). CD001824. Excluded: wrong intervention. [pmid: 18646078].
Staal JB, de Bie RA, de Vet HCW, et al. Injection therapy for subacute and chronic low back pain: an updated Cochrane review. Spine. 2009;34(1):49-59. Excluded: wrong intervention. [pmid: 19127161].
Staal JB, Hlobil H, Koke AJA, et al. Graded activity for workers with low back pain: who benefits most and how does it work?. Arthritis Rheum. 2008;59(5):642-9. Excluded: wrong outcome. [pmid: 18438894].
Staiger TO, Gaster B, Sullivan MD, et al. Systematic review of antidepressants in the treatment of chronic low back pain. Spine. 2003;28(22):2540-5. Excluded: relevant to background only. [pmid: 14624092].
Standaert CJ, Friedly J, Erwin MW, et al. Comparative effectiveness of exercise, acupuncture, and spinal manipulation for low back pain. Spine. 2011;36(21 Suppl):S120-30. Excluded: Pre-2007 systematic review or superseded by a more recent review. [pmid: 21952184].
Standaert CJ, Weinstein SM, Rumpeltes J. Evidence-informed management of chronic low back pain with lumbar stabilization exercises. Spine Journal: Official Journal of the North American Spine Society. 2008;8:114-20. Excluded: wrong study deisgn for key question.
Stankovic R, Johnell O. Conservative treatment of acute low back pain. A 5-year follow-up study of two methods of treatment. Spine (Phila Pa 1976). 1995;20(4):469-72. Excluded: wrong study deisgn for key question. [pmid: 7747231].
Stapelfeldt CM, Christiansen DH, Jensen OK, et al. Subgroup analyses on return to work in sick-listed employees with low back pain in a randomised trial comparing brief and multidisciplinary intervention. BMC Musculoskelet Disord. 2011;12:112. Excluded: wrong study deisgn for key question. [pmid: 21612625].
Starkweather AR, Coyne P, Lyon DE, et al. Decreased low back pain intensity and differential gene expression following Calmare: results from a double-blinded randomized sham-controlled study. Res Nurs Health. 2015;38(1):29-38. Excluded: wrong intervention. [pmid: 25572279].
Steele J, Bruce-Low S, Smith D, et al. A randomized controlled trial of limited range of motion lumbar extension exercise in chronic low back pain. Spine. 2013;38(15):1245-52. Excluded: sample size too small. [pmid: 23514876].
Steiger F, Wirth B, de Bruin ED, et al. Is a positive clinical outcome after exercise therapy for chronic non-specific low back pain contingent upon a corresponding improvement in the targeted aspect(s) of performance? A systematic review. Eur Spine J. 2012;21(4):575-98. Excluded: wrong outcome. [pmid: 22072093].
Steigerwald I, Muller M, Davies A, et al. Effectiveness and safety of tapentadol prolonged release for severe, chronic low back pain with or without a neuropathic pain component: results of an open-label, phase 3b study. Curr Med Res Opin. 2012;28(6):911-36. Excluded: wrong study deisgn for key question. [pmid: 22443293].
Steiner D, Munera C, Hale M, et al. Efficacy and safety of buprenorphine transdermal system (BTDS) for chronic moderate to severe low back pain: a randomized, double-blind study. J Pain. 2011;12(11):1163-73. Excluded: using original studies instead (e.g. meta-analysis, compiled study data, or data from another publication). [pmid: 21807566].
Steinmetz MP, Patel R, Traynelis V, et al. Cervical disc arthroplasty compared with fusion in a workers' compensation population. Neurosurgery. 2008;63(4):741-7. discussion 7. Excluded: wrong intervention. [pmid: 18981885].
Streitparth F, Hartwig T, Walter T, et al. MR guidance and thermometry of percutaneous laser disc decompression in open MRI: an initial clinical investigation. Eur Radiol. 2013;23(10):2739-46. Excluded: wrong intervention. [pmid: 23657288].
Stuber KJ, Smith DL. Chiropractic treatment of pregnancy-related low back pain: a systematic review of the evidence. J Manipulative Physiol Ther. 2008;31(6):447-54. Excluded: wrong population. [pmid: 18722200].
Stuge B, Laerum E, Kirkesola G, et al. The efficacy of a treatment program focusing on specific stabilizing exercises for pelvic girdle pain after pregnancy: a randomized controlled trial. Spine (Phila Pa 1976). 2004;29(4):351-9. Excluded: wrong population. [pmid: 15094530].
Subin B, Saleemi S, Morgan GA, et al. Teatment of Chronic Low Back Pain by Local Injection of Botulinum Toxin-A. Internet Journal of Anesthesiology. 2003;6(2). Excluded: wrong intervention.
Suen LKP, Wong EMC. Longitudinal changes in the disability level of the elders with low back pain after auriculotherapy. Complementary Therapies in Medicine. 2008;16:28-35. Excluded: wrong intervention. [pmid: 18346626].
Suen LKP, Wong TKS, Chung JWY, et al. Auriculotherapy on low back pain in the elderly. Complement Ther Clin Pract. 2007;13(1):63-9. Excluded: wrong intervention. [pmid: 17210513].
Sullivan MD, Howe CQ. Opioid therapy for chronic pain in the United States: promises and perils. Pain. Suppl 1. 2013;154:S94-100. Excluded: not a study (letter, editorial, non-systematic review article). [pmid: 24036286].
Sumpton JE, Moulin DE. Treatment of neuropathic pain with venlafaxine. Ann Pharmacother. 2001;35(5):557-9. Excluded: wrong study deisgn for key question. [pmid: 11346061].
Sun G-P. Clinical observation on auricular point magnetotherapy for treatment of senile low back pain. Zhongguo zhenjiu. 2007;27(2):112-4. Excluded: not English language but possibly relevant. [pmid: 17370493].
Sun Y-Z, Li D-Y. Observation on lower back myofascitis treated with penetration needling on yang meridians of the back and electroacupuncture as compared with Western medication. Zhongguo zhenjiu. 2010;30(10):816-8. Excluded: not English language but possibly relevant. [pmid: 21058477].
Suni JH, Taanila H, Mattila VM, et al. Neuromuscular exercise and counseling decrease absenteeism due to low back pain in young conscripts: a randomized, population-based primary prevention study. Spine. 2013;38(5):375-84. Excluded: wrong outcome. [pmid: 22941095].
Surkitt LD, Ford JJ, Hahne AJ, et al. Efficacy of directional preference management for low back pain: a systematic review. Phys Ther. 2012;92(5):652-65. Excluded: wrong intervention. [pmid: 22247407].
Suzan E, Eisenberg E, Treister R, et al. A negative correlation between hyperalgesia and analgesia in patients with chronic radicular pain: is hydromorphone therapy a double-edged sword?. Pain physician. 2013;16(1):65-76. Excluded: wrong study deisgn for key question. [pmid: 23340535].
Szczurko O, Cooley K, Busse JW, et al. Naturopathic care for chronic low back pain: a randomized trial. PLoS ONE. 2007;2(9):e919. Excluded: wrong intervention. [pmid: 17878954].
Tafazal S, Ng L, Chaudhary N, et al. Corticosteroids in peri-radicular infiltration for radicular pain: a randomised double blind controlled trial. One year results and subgroup analysis. Eur Spine J. 2009;18(8):1220-5. Excluded: wrong intervention. [pmid: 19387704].
Tafazal SI, Ng L, Sell P. Randomised placebo-controlled trial on the effectiveness of nasal salmon calcitonin in the treatment of lumbar spinal stenosis. Eur Spine J. 2007;16(2):207-12. Excluded: wrong intervention. [pmid: 16865379].
Takahashi N, Arai I, Kayama S, et al. Therapeutic efficacy of pregabalin in patients with leg symptoms due to lumbar spinal stenosis. Fukushima J Med Sci. 2014;60(1):35-42. Excluded: wrong study deisgn for key question. [pmid: 25030722].
Tan G, Fukui T, Jensen MP, et al. Hypnosis treatment for chronic low back pain. Int J Clin Exp Hypn. 2010;58(1):53-68. Excluded: wrong study deisgn for key question. [pmid: 20183738].
Tavafian SS, Jamshidi A, Mohammad K, et al. Low back pain education and short term quality of life: a randomized trial. BMC Musculoskelet Disord. 2007;8:21. Excluded: wrong intervention. [pmid: 17328809].
Thackeray A, Fritz JM, Brennan GP, et al. A pilot study examining the effectiveness of physical therapy as an adjunct to selective nerve root block in the treatment of lumbar radicular pain from disk herniation: a randomized controlled trial. Phys Ther. 2010;90(12):1717-29. Excluded: wrong intervention. [pmid: 20864600].
Thiese MS, Hughes M, Biggs J. Electrical stimulation for chronic non-specific low back pain in a working-age population: a 12-week double blinded randomized controlled trial. BMC Musculoskelet Disord. 2013;14:117. Excluded: not a study (letter, editorial, non-systematic review article). [pmid: 23537462].
Thompson JW, Bower S, Tyrer SP. A double blind randomised controlled clinical trial on the effect of transcutaneous spinal electroanalgesia (TSE) on low back pain. Eur J Pain. 2008;12(3):371-7. Excluded: wrong intervention. [pmid: 17826201].
Tive L, Schnitzer TJ, Katz N, et al. Tanezumab, a humanized anti-nerve growth factor antibody in the treatment of three chronic pain types. Pain Med. 2010;11(2). Excluded: not a study (letter, editorial, nonsystematic review article).
Tolle TR, Baron R, Freynhagen R, et al. The efficacy and safety of pregabalin in the treatment of neuropathic pain associated with lumbo-sacral radiculopathy. Eur J Neurol. 2008;15(Suppl 3):171. Excluded: not a study (letter, editorial, non-systematic review article).
Tonev D, Radeva S, Toncheva A. non-pharmacological treatment of subacute and chronic low back pain without radiculopathy: acupuncture versus physiotherapy. Rheumatology[Bulgarian]. 2010;6p(2):46-50. Excluded: not English language but possibly relevant.
Tozzi P, Bongiorno D, Vitturini C. Fascial release effects on patients with non-specific cervical or lumbar pain. J Bodywork Mov Ther. 2011;15(4):405-16. Excluded: wrong population. [pmid: 21943614].
Trigkilidas D. Acupuncture therapy for chronic lower back pain: a systematic review. Ann R Coll Surg Engl. 2010;92(7):595-8. Excluded: using original studies instead (e.g. meta-analysis, compiled study data, or data from another publication). [pmid: 20529520].
Tsao H, Hodges PW. Persistence of improvements in postural strategies following motor control training in people with recurrent low back pain. J Electromyogr Kinesiol. 2008;18(4):559-67. Excluded: wrong study deisgn for key question. [pmid: 17336546].
Tsauo J-Y, Chen W-H, Liang H-W, et al. The effectiveness of a functional training programme for patients with chronic low back pain--a pilot study. Disabil Rehabil. 2009;31(13):1100-6. Excluded: sample size too small. [pmid: 19802926].
Tutzschke R, Anders C, Borys C, et al. Evaluation of the German new back school: muscular physiological characteristics. Schmerz. 2014;28(2):166-74. Excluded: not English language but possibly relevant. [pmid: 24643752].
Underwood M, Mistry D, Lall R, et al. Predicting response to a cognitive-behavioral approach to treating low back pain: Secondary analysis of the BeST data set. Arthritis Care Res (Hoboken). 2011;63(9):1271-9. Excluded: wrong study deisgn for key question. [pmid: 21671419].
Underwood MR, Morton V, Farrin A, et al. Do baseline characteristics predict response to treatment for low back pain? Secondary analysis of the UK BEAM dataset [ISRCTN32683578]. Rheumatology (Oxford). 2007;46(8):1297-302. Excluded: wrong study deisgn for key question. [pmid: 17522096].
Unsgaard-Tondel M, Lund Nilsen TI, Magnussen J, et al. Is activation of transversus abdominis and obliquus internus abdominis associated with long-term changes in chronic low back pain? A prospective study with 1-year follow-up. BJSM online. 2012;46(10):729-34. Excluded: wrong study deisgn for key question. [pmid: 21791459].
Urquhart DM, Hoving JL, Assendelft WWJJ, et al. Antidepressants for non-specific low back pain. Cochrane Database Syst Rev. 2008;(1). CD001703. Excluded: Pre-2007 systematic review or superseded by a more recent review. [pmid: 18253994].
Urrutia G, Burton KA, Morral Fernandez A, et al. Neuroreflexotherapy for non-specific low-back pain. Cochrane Database Syst Rev. 2011;(2). Excluded: Pre-2007 systematic review or superseded by a more recent review.
Vallejo R, Zevallos LM, Lowe J, et al. Is spinal cord stimulation an effective treatment option for discogenic pain?. Pain pract. 2012;12(3):194-201. Excluded: wrong study deisgn for key question. [pmid: 21797964].
van der Giessen RN, Speksnijder CM, Helders PJM. The effectiveness of graded activity in patients with non-specific low-back pain: a systematic review. Disabil Rehabil. 2012;34(13):1070-6. Excluded: using original studies instead (e.g. meta-analysis, compiled study data, or data from another publication). [pmid: 22148906].
van Geen J-W, Edelaar MJA, Janssen M, et al. The long-term effect of multidisciplinary back training: a systematic review. Spine. 2007;32(2):249-55. Excluded: using original studies instead (e.g. meta-analysis, compiled study data, or data from another publication). [pmid: 17224822].
van Hooff ML, Ter Avest W, Horsting PP, et al. A short, intensive cognitive behavioral pain management program reduces health-care use in patients with chronic low back pain: two-year follow-up results of a prospective cohort. Eur Spine J. 2012;21(7):1257-64. Excluded: wrong study deisgn for key question. [pmid: 22139049].
Van K, Hides JA, Richardson CA. The use of real-time ultrasound imaging for biofeedback of lumbar multifidus muscle contraction in healthy subjects. J Orthop Sports Phys Ther. 2006;36(12):920-5. Excluded: wrong population. [pmid: 17193869].
van Tulder MW, Jellema P, van Poppel MNM, et al. Lumbar supports for prevention and treatment of low-back pain. Cochrane Database Syst Rev. 2000;(3). Art. No.: CD001823. Excluded: Pre-2007 systematic review or superseded by a more recent review. [pmid: 17636685].
van Tulder MW, Scholten RJ, Koes BW, et al. Nonsteroidal anti-inflammatory drugs for low back pain: a systematic review within the framework of the Cochrane Collaboration Back Review Group. Spine (Phila Pa 1976). 2000;25(19):2501-13. Excluded: Pre-2007 systematic review or superseded by a more recent review. [pmid: 11013503].
van Tulder MW, Scholten RJ, Koes BW, et al. Non-steroidal anti-inflammatory drugs for low back pain. Cochrane Database Syst Rev. 2000;(2). CD000396. Excluded: Pre-2007 systematic review or superseded by a more recent review. [pmid: 10796356].
Vanelderen P, Van Zundert J, Kozicz T, et al. Effect of minocycline on lumbar radicular neuropathic pain: a randomized, placebo-controlled, double-blind clinical trial with amitriptyline as a comparator. Anesthesiology. 2015;122(2):399-406. Excluded: wrong intervention. [pmid: 25373391].
Vanti C, Bertozzi L, Gardenghi I, et al. Effect of taping on spinal pain and disability: systematic review and meta-analysis of randomized trials. Phys Ther. 2015;95(4):493-506. Excluded: using original studies instead (e.g. meta-analysis, compiled study data, or data from another publication). [pmid: 25413622].
Vasseljen O, Unsgaard-Tondel M, Westad C, et al. Effect of core stability exercises on feed-forward activation of deep abdominal muscles in chronic low back pain: a randomized controlled trial. Spine. 2012;37(13):1101-8. Excluded: wrong outcome. [pmid: 22146280].
Vavrek D, Sharma R, Haas M. Cost-analysis related to dose-response for spinal manipulative therapy for chronic low back pain: Outcomes from a randomized controlled trial. J Altern Complement Med. 20(5):A18. Excluded: not a study (letter, editorial, non-systematic review article).
Vavrek DA, Sharma R, Haas M. Cost analysis related to dose-response of spinal manipulative therapy for chronic low back pain: outcomes from a randomized controlled trial. J Manipulative Physiol Ther. 2014;37(5):300-11. Excluded: wrong outcome. [pmid: 24928639].
Verrills P, Vivian D, Mitchell B, et al. Peripheral nerve field stimulation for chronic pain: 100 cases and review of the literature. Pain Med. 2011;12(9):1395-405. Excluded: wrong study deisgn for key question. [pmid: 21812906].
Vibe Fersum K, O'Sullivan P, Skouen JS, et al. Efficacy of classification-based cognitive functional therapy in patients with non-specific chronic low back pain: a randomized controlled trial. Eur J Pain. 2013;17(6):916-28. Excluded: wrong comparison. [pmid: 23208945].
Vickers AJ, Maschino AC. The Acupuncture Trialists' Collaboration: individual patient data meta-analysis of chronic pain trials. Acupunct Med. 2009;27(3):126-7. Excluded: not a study (letter, editorial, non-systematic review article). [pmid: 19734384].
Vieira-Pellenz F, Oliva-Pascual-Vaca A, Rodriguez-Blanco C, et al. Short-term effect of spinal manipulation on pain perception, spinal mobility, and full height recovery in male subjects with degenerative disk disease: a randomized controlled trial. Arch Phys Med Rehabil. 2014;95(9):1613-9. Excluded: inadequate duration. [pmid: 24862763].
Vismara L, Cimolin V, Menegoni F, et al. Osteopathic manipulative treatment in obese patients with chronic low back pain: a pilot study. Manual Ther. 2012;17(5):451-5. Excluded: wrong population. [pmid: 22658268].
Vlachojannis J, Roufogalis BD, Chrubasik S. Systematic review on the safety of Harpagophytum preparations for osteoarthritic and low back pain. Phytother Res. 2008;22(2):149-52. Excluded: wrong intervention. [pmid: 18236448].
Vlachojannis JE, Cameron M, Chrubasik S. A systematic review on the effectiveness of willow bark for musculoskeletal pain. Phytother Res. 2009;23(7):897-900. Excluded: wrong population. [pmid: 19140170].
Vondrackova D, Leyendecker P, Meissner W, et al. Analgesic efficacy and safety of oxycodone in combination with naloxone as prolonged release tablets in patients with moderate to severe chronic pain. J Pain. 2008;9(12):1144-54. Excluded: wrong outcome. [pmid: 18708300].
Vora RN, Barron BA, Almudevar A, et al. Work-related chronic low back pain-return-to-work outcomes after referral to interventional pain and spine clinics. Spine. 2012;37(20):E1282-9. Excluded: wrong study deisgn for key question. [pmid: 22739674].
Vorsanger G, Xiang J, Okamoto A, et al. Evaluation of study discontinuations with tapentadol inmmediate release and oxycodone immediate release in patients with low back or osteoarthritis pain. J Opioid Manag. 2010;6(3):169-79. Excluded: wrong population. [pmid: 20642246].
Vos T, Flaxman AD, Naghavi M, et al. Years lived with disability (YLDs) for 1160 sequelae of 289 diseases and injuries 1990-2010: a systematic analysis for the Global Burden of Disease Study 2010. Lancet. 2012;380(9859):2163-96. Excluded: using original studies instead (e.g. meta-analysis, compiled study data, or data from another publication). [pmid: 23245607].
Wai EK, Rodriguez S, Dagenais S, et al. Evidence-informed management of chronic low back pain with physical activity, smoking cessation, and weight loss. Spine J. 2008;8(1):195-202. Excluded: Pre-2007 systematic review or superseded by a more recent review. [pmid: 18164467].
Walker BF, French SD, Grant W, et al. Combined chiropractic interventions for low-back pain. Cochrane Database Syst Rev. 2010;(4). CD005427. Excluded: wrong intervention. [pmid: 20393942].
Walker BF, French SD, Grant W, et al. A Cochrane review of combined chiropractic interventions for low-back pain. Spine. 2011;36(3):230-42. Excluded: using original studies instead (e.g. meta-analysis, compiled study data, or data from another publication). [pmid: 21248591].
Walker BF, French SD, Grant W, et al. Combined chiropractic interventions for low-back pain. Cochrane Database Syst Rev. 2011;(2). Excluded: wrong intervention.
Wallace M, Skowronski R, Khanna S, et al. Efficacy and safety evaluation of once-daily OROS hydromorphone in patients with chronic low back pain: a pilot open-label study (DO-127). Curr Med Res Opin. 2007;23(5):981-9. Excluded: wrong study deisgn for key question. [pmid: 17519065].
Wallace M, Thipphawong J. Open-label study on the long-term efficacy, safety, and impact on quality of life of OROS hydromorphone ER in patients with chronic low back pain. Pain Med. 2010;11(10):1477-88. Excluded: wrong study deisgn for key question. [pmid: 21199302].
Waller B, Lambeck J, Daly D. Therapeutic aquatic exercise in the treatment of low back pain: a systematic review. Clin Rehabil. 2009;23(1):3-14. Excluded: relevant to background only. [pmid: 19114433].
Wand BM, Abbaszadeh S, Smith AJ, et al. Acupuncture applied as a sensory discrimination training tool decreases movement-related pain in patients with chronic low back pain more than acupuncture alone: a randomised cross-over experiment. BJSM online. 2013;47(17):1085-9. Excluded: wrong intervention. [pmid: 24021562].
Wand BM, Tulloch VM, George PJ, et al. Seeing it helps: movement-related back pain is reduced by visualization of the back during movement. Clin J Pain. 2012;28(7):602-8. Excluded: wrong intervention. [pmid: 22699134].
Wang X-Q, Zheng J-J, Yu Z-W, et al. A meta-analysis of core stability exercise versus general exercise for chronic low back pain. PLoS ONE. 2012;7(12):e52082. Excluded: relevant to background only. [pmid: 23284879].
Wasan AD, Jamison RN, Pham L, et al. Psychopathology predicts the outcome of medial branch blocks with corticosteroid for chronic axial low back or cervical pain: a prospective cohort study. BMC Musculoskelet Disord. 2009;10:22. Excluded: wrong study deisgn for key question. [pmid: 19220916].
Wasan AD, Kong J, Pham L-D, et al. The impact of placebo, psychopathology, and expectations on the response to acupuncture needling in patients with chronic low back pain. J Pain. 2010;11(6):555-63. Excluded: wrong comparison. [pmid: 20075014].
Waseem Z, Boulias C, Gordon A, et al. Botulinum toxin injections for low-back pain and sciatica. Cochrane Database Syst Rev. 2011;(1). CD008257. Excluded: wrong intervention. [pmid: 21249702].
Webster BS, Verma SK, Gatchel RJ. Relationship between early opioid prescribing for acute occupational low back pain and disability duration, medical costs, subsequent surgery and late opioid use. Spine. 2007;32(19):2127-32. Excluded: wrong study deisgn for key question. [pmid: 17762815].
Weidenhammer W, Linde K, Streng A, et al. Acupuncture for chronic low back pain in routine care: a multicenter observational study. Clin J Pain. 2007;23(2):128-35. Excluded: wrong study deisgn for key question. [pmid: 17237661].
Weinstein JN, Lurie JD, Tosteson TD, et al. Surgical versus nonsurgical treatment for lumbar degenerative spondylolisthesis. N Engl J Med. 2007;356(22):2257-70. Excluded: wrong intervention. [pmid: 17538085].
Wells C, Kolt GS, Marshall P, et al. Effectiveness of Pilates exercise in treating people with chronic low back pain: a systematic review of systematic reviews. BMC Med Res Methodol. 2013;13:7. Excluded: relevant to background only. [pmid: 23331384].
Werneke M, Hart DL, Cook D. A descriptive study of the centralization phenomenon. A prospective analysis. Spine (Phila Pa 1976). 1999;24(7):676-83. Excluded: wrong intervention. [pmid: 10209797].
Werneke MW, Deutscher D, Hart DL, et al. McKenzie lumbar classification: inter-rater agreement by physical therapists with different levels of formal McKenzie postgraduate training. Spine (Phila Pa 1976). 2014;39(3):E182-90. Excluded: wrong population. [pmid: 24253786].
Wessels T, Ewert T, Limm H, et al. Change factors explaining reductions of “interference” in a multidisciplinary and an exercise prevention program for low back pain. Clin J Pain. 2007;23(7):629-34. Excluded: wrong outcome. [pmid: 17710014].
Wetherell JL, Afari N, Rutledge T, et al. A randomized, controlled trial of acceptance and commitment therapy and cognitive-behavioral therapy for chronic pain. Pain. 2011;152(9):2098-107. Excluded: wrong intervention. [pmid: 21683527].
Wetzel L, Zadrazil M, Paternostro-Sluga T, et al. Intravenous nonopioid analgesic drugs in chronic low back pain patients on chronic opioid treatment: a crossover, randomised, double-blinded, placebo-controlled study. Eur J Anaesthesiol. 2014;31(1):35-40. Excluded: wrong intervention. [pmid: 24141646].
Wheeler WJ, Gever LN. Functional status of patients with acute low back pain following treatment with carisoprodol 250-mg tablets assessed by the roland-morris disability questionnaire (RMDQ). Pain Med. 2010;11(2). Excluded:not a study (letter, editorial, non-systematic review article).
Whitehurst DGT, Lewis M, Yao GL, et al. A brief pain management program compared with physical therapy for low back pain: results from an economic analysis alongside a randomized clinical trial. Arthritis Rheum. 2007;57(3):466-73. Excluded: wrong intervention. [pmid: 17394176].
Whitfill T, Haggard R, Bierner SM, et al. Early intervention options for acute low back pain patients: a randomized clinical trial with one-year follow-up outcomes. J Occup Rehabil. 2010;20(2):256-63. Excluded: wrong population. [pmid: 20369277].
Whitman JM, Flynn TW, Childs JD, et al. A comparison between two physical therapy treatment programs for patients with lumbar spinal stenosis: a randomized clinical trial. Spine (Phila Pa 1976). 2006;31(22):2541-9. Excluded: wrong intervention. [pmid: 17047542].
Wielage R, Bansal M, Wilson K, et al. Cost-effectiveness of duloxetine in chronic low back pain: a Quebec societal perspective. Spine. 2013;38(11):936-46. Excluded: wrong outcome. [pmid: 23250234].
Wiese M, Kramer J, Becker C, et al. Back school - an update. Z Orthop Unfall. 2009;147(2):194-8. Excluded: not English language but possibly relevant. [pmid: 19358074].
Wild JE, Grond S, Kuperwasser B, et al. Long-term safety and tolerability of tapentadol extended release for the management of chronic low back pain or osteoarthritis pain. Pain pract. 2010;10(5):416-27. Excluded: wrong population. [pmid: 20602712].
Williams NH, Hendry M, Lewis R, et al. Psychological response in spinal manipulation (PRISM): a systematic review of psychological outcomes in randomised controlled trials. Complement Ther Med. 2007;15(4):271-83. Excluded: Pre-2007 systematic review or superseded by a more recent review. [pmid: 18054729].
Williams RM, Westmorland MG, Lin CA, et al. Effectiveness of workplace rehabilitation interventions in the treatment of work-related low back pain: a systematic review. Disabil Rehabil. 2007;29(8):607-24. Excluded: using original studies instead (e.g. meta-analysis, compiled study data, or data from another publication). [pmid: 17453982].
Williamson OD, Schroer M, Ruff DD, et al. Onset of response with duloxetine treatment in patients with osteoarthritis knee pain and chronic low back pain: a post hoc analysis of placebo-controlled trials. Clin Ther. 2014;36(4):544-51. Excluded: using original studies instead (e.g. meta-analysis, compiled study data, or data from another publication). [pmid: 24650448].
Witenko C, Moorman-Li R, Motycka C, et al. Considerations for the appropriate use of skeletal muscle relaxants for the management of acute low back pain. P T. 2014;39(6):427-35. Excluded: not a study (letter, editorial, non-systematic review article). [pmid: 25050056].
Woods MP, Asmundson GJG. Evaluating the efficacy of graded in vivo exposure for the treatment of fear in patients with chronic back pain: a randomized controlled clinical trial. Pain. 2008;136:271-80. Excluded: wrong intervention. [pmid: 17716819].
Wu D, Guo X. Is the sham acupuncture group a real sham control group? Comments on “Vas J et al. Acupuncture in patients with acute low back pain: a multicentre randomised controlled clinical trial [PAIN 2012;153(9):1883-9]”. Pain. 2013;154(11):2575-6. Excluded: not a study (letter, editorial, non-systematic review article). [pmid: 23962589].
Xu M, Yan S, Yin X, et al. Acupuncture for chronic low back pain in long-term follow-up: a meta-analysis of 13 randomized controlled trials. Am J Chin Med. 2013;41(1):1-19. Excluded: Pre-2007 systematic review or superseded by a more recent review. [pmid: 23336503].
Yang EJ, Park WB, Shin, et al. The effect of back school integrated with core strengthening in patients with chronic low-back pain. Am J Phys Med Rehabil. 2010;89(9):744-54. Excluded: wrong intervention. [pmid: 20581648].
Yang D-L, Zhou W-Q, Li J, et al. Comparative study on function and surface electromyograpgy in patients of lumbar disc herniation treated with acupunctrue and moxibustion. Zhongguo zhenjiu. 2014;34(4):341-6. Excluded: not English language but possibly relevant. [pmid: 24946631].
Yang J-H. The effects of hand acupuncture therapy on pain, ROM, ADL and depression among elders with low back pain and knee joint pain. Journal Korean acad. 2009;39(1):10-20. Excluded: not English language but possibly relevant. [pmid: 19265308].
Yardley L, Dennison L, Coker R, et al. Patients' views of receiving lessons in the Alexander technique and an exercise prescription for managing back pain in the ATEAM trial. Fam Pract. 2010;27(2):198-204. Excluded: wrong outcome. [pmid: 20032168].
Yarlas A, Miller K, Wen W, et al. A randomized, placebo-controlled study of the impact of the 7-day buprenorphine transdermal system on health-related quality of life in opioid-naive patients with moderate-to-severe chronic low back pain. J Pain. 2013;14(1):14-23. Excluded: wrong study deisgn for key question. [pmid: 23200931].
Yildirim K, Deniz O, Gureser G, et al. Gabapentin monotherapy in patients with chronic radiculopathy: the efficacy and impact on life quality. J Back Musculoskeletal Rehabil. 2009;22(1):17-20. Excluded: wrong study deisgn for key question. [pmid: 20023359].
Yildirim Y, Soyunov S. Relationship between learning strategies of patients and proper perception of the home exercise program with non-specific low back pain. J Back Musculoskeletal Rehabil. 2010;23(3):137-42. Excluded: wrong comparison. [pmid: 20858943].
Yip YB, Tse H-MS, Wu KK. An experimental study comparing the effects of combined transcutaneous acupoint electrical stimulation and electromagnetic millimeter waves for spinal pain in Hong Kong. Complement Ther Clin Pract. 2007;13(1):4-14. Excluded: wrong population. [pmid: 17210506].
Yousefi-Nooraie R, Schonstein E, Heidari K, et al. Low level laser therapy for nonspecific low-back pain. Cochrane Database Syst Rev. 2011;(2). Excluded: using original studies instead (e.g. meta-analysis, compiled study data, or data from another publication).
Yuan J, Kerr D, Park J, et al. Treatment regimens of acupuncture for low back pain--a systematic review. Complement Ther Med. 2008;16(5):295-304. Excluded: Pre-2007 systematic review or superseded by a more recent review. [pmid: 19186345].
Yuan J, Purepong N, Kerr DP, et al. Effectiveness of acupuncture for low back pain: a systematic review. Spine. 2008;33(23):E887-900. Excluded: Pre-2007 systematic review or superseded by a more recent review. [pmid: 18978583].
Yue Y-S, Wang X-D, Xie B, et al. Sling exercise for chronic low back pain: a systematic review and meta-analysis. PLoS ONE. 2014;9(6):e99307. Excluded: relevant to background only. [pmid: 24919119].
Yurtkuran M, Kahraman Z, Sivrioglu K, et al. Balneotherapy in low back pain. Eur J Phys Med Rehabil. 1997;7(4):120-3. Excluded: wrong intervention.
Zambito A. Interferential and horizontal therapies in chronic low back pain: a randomized, double blind, clinical study. Clin Exp Rheumatol. 2006;24:534-9. Excluded: wrong population. [pmid: 17181922].
Zambito A, Bianchini D, Gatti D, et al. Interferential and horizontal therapies in chronic low back pain due to multiple vertebral fractures: a randomized, double blind, clinical study. Osteoporos Int. 2007;18(11):1541-5. Excluded: wrong population. [pmid: 17609842].
Zarghooni K, Beyer F, Siewe J, et al. The orthotic treatment of acute and chronic disease of the cervical and lumbar spine. Dtsch. 2013;110(44):737-42. Excluded: using original studies instead (e.g. meta-analysis, compiled study data, or data from another publication). [pmid: 24280429].
Zhang J, Malisali E. Laser and electrical stimulation of acupuncture points on low back pain, a pilot study. JCE. 2009;23(1):119-20. Excluded: wrong study deisgn for key question.
Zhang Y, Chen F, Wu S. Clinical observation on O3 acupoint injection for treatment of low back pain. Zhongguo zhenjiu. 2007;27(2):115-6. Excluded: not English language but possibly relevant. [pmid: 17370494].
Zhao F, Cao D-b, Yuan Y-q, et al. Efficacy observation of nonspecific low back pain treated with the dragon-tiger fighting needling method. Zhongguo zhenjiu. 2012;32(6):507-10. Excluded: not English language but possibly relevant. [pmid: 22741256].
Zippel H, Wagenitz A. A multicentre, randomised, double-blind study comparing the efficacy and tolerability of intramuscular dexketoprofen versus diclofenac in the symptomatic treatment of acute low back pain. Clin Drug Invest. 2007;27(8):533-43. Excluded: wrong intervention. [pmid: 17638394].