# Included Studies

Ahmed MS, Shakoor MA, Khan AA. Evaluation of the effects of shortwave diathermy in patients with chronic low back pain. Bangladesh Med Res Counc Bull. 2009;35(1):18-20. [pmid: 19637541].
Ajimsha MS, Daniel B, Chithra S. Effectiveness of myofascial release in the management of chronic low back pain in nursing professionals. J Bodywork Mov Ther. 2014;18(2):273-81. [pmid: 24725797].
Albaladejo C, Kovacs FM, Royuela A, et al. The efficacy of a short education program and a short physiotherapy program for treating low back pain in primary care: a cluster randomized trial. Spine. 2010;35(5):483-96. [pmid: 20147875].
Albert HB, Manniche C. The efficacy of systematic active conservative treatment for patients with severe sciatica: a single-blind, randomized, clinical, controlled trial. Spine. 2012;37(7):531-42. [pmid: 21494193].
Aluko A, DeSouza L, Peacock J. The effect of core stability exercises on variations in acceleration of trunk movement, pain, and disability during an episode of acute nonspecific low back pain: a pilot clinical trial. J Manipulative Physiol Ther. 2013;36(8):497-504.e1-3. [pmid: 23948426].
Ay S, Dogan SK, Evcik D. Is low-level laser therapy effective in acute or chronic low back pain?. [Erratum appears in Clin Rheumatol. 2010 Aug;29(8):911]. Clin Rheumatol. 2010;29(8):905-10. [pmid: 20414695].
Bae SH, Lee JH, Oh KA, et al. The effects of kinesio taping on potential in chronic low back pain patients anticipatory postural control and cerebral cortex. J Phys Ther Sci. 2013;25(11):1367-71. [pmid: 24396190].
Balthazard P, de Goumoens P, Rivier G, et al. Manual therapy followed by specific active exercises versus a placebo followed by specific active exercises on the improvement of functional disability in patients with chronic non specific low back pain: a randomized controlled trial. BMC Musculoskelet Disord. 2012;13:162. [pmid: 22925609].
Baron R, Freynhagen R, Tolle TR, et al. The efficacy and safety of pregabalin in the treatment of neuropathic pain associated with chronic lumbosacral radiculopathy. Pain. 2010;150(3):420-7. [pmid: 20493632].
Baron R, Martin-Mola E, Muller M, et al. Effectiveness and Safety of Tapentadol Prolonged Release (PR) Versus a Combination of Tapentadol PR and Pregabalin for the Management of Severe, Chronic Low Back Pain With a Neuropathic Component: A Randomized, Double-blind, Phase 3b Study. Pain pract. 2014. [pmid: 24738609].
Bicalho E, Setti JAP, Macagnan J, et al. Immediate effects of a high-velocity spine manipulation in paraspinal muscles activity of nonspecific chronic low-back pain subjects. Manual Ther. 2010;15(5):469-75. [pmid: 20447857].
Borges TP, Kurebayashi LFS, Silva MJPd. Occupational low back pain in nursing workers: massage versus pain. Rev Esc Enferm USP. 2014;48(4):669-75. [pmid: 25338248].
Bronfort G, Evans RL, Maiers M, et al. Spinal manipulation, epidural injections, and self-care for sciatica: a pilot study for a randomized clinical trial. J Manipulative Physiol Ther. 2004;27(8):503-8. [pmid: 15510093].
Bronfort G, Maiers MJ, Evans RL, et al. Supervised exercise, spinal manipulation, and home exercise for chronic low back pain: a randomized clinical trial. Spine J. 2011;11(7):585-98. [pmid: 21622028].
Brotz D, Maschke E, Burkard S, et al. Is there a role for benzodiazepines in the management of lumbar disc prolapse with acute sciatica?. Pain. 2010;149(3):470-5. [pmid: 20362397].
Buchmuller A, Navez M, Milletre-Bernardin M, et al. Value of TENS for relief of chronic low back pain with or without radicular pain. Eur J Pain. 2012;16(5):656-65. [pmid: 22337531].
Burton AK, Tillotson KM, Cleary J. Single-blind randomised controlled trial of chemonucleolysis and manipulation in the treatment of symptomatic lumbar disc herniation. Eur Spine J. 2000;9(3):202-7. [pmid: 10905437].
Bystrom MG, Rasmussen-Barr E, Grooten WJA. Motor control exercises reduces pain and disability in chronic and recurrent low back pain: a meta-analysis. Spine. 2013;38(6):E350-8. [pmid: 23492976].
Calmels P, Queneau P, Hamonet C, et al. Effectiveness of a lumbar belt in subacute low back pain: an open, multicentric, and randomized clinical study. Spine. 2009;34(3):215-20. [pmid: 19179915].
Carson S, Thakurta S, Low A, et al. Drug Class Review: Long-Acting Opioid Analgesics: Final Update 6 Report [Internet]. Drug Class Reviews. 2011. [pmid: 21977550].
Castro-Sanchez AM, Lara-Palomo IC, Mataran-Penarrocha GA, et al. Kinesio Taping reduces disability and pain slightly in chronic non-specific low back pain: a randomised trial. [Erratum appears in J Physiother. 2012;58(3):143]. J Physiother. 2012;58(2):89-95. [pmid: 22613238].
Cecchi F, Molino-Lova R, Chiti M, et al. Spinal manipulation compared with back school and with individually delivered physiotherapy for the treatment of chronic low back pain: a randomized trial with one-year follow-up. Clin Rehabil. 2010;24(1):26-36. [pmid: 20053720].
Chaparro EL, Furlan AD, Deshpande A, et al. Opioids compared to placebo or other treatments for chronic low-back pain. Cochrane Database Syst Rev. 2014;(5).
Chen S-M, Alexander R, Lo SK, et al. Effects of Functional Fascial Taping on pain and function in patients with non-specific low back pain: a pilot randomized controlled trial. Clin Rehabil. 2012;26(10):924-33. [pmid: 22492922].
Cherkin DC, Sherman KJ, Kahn J, et al. A comparison of the effects of 2 types of massage and usual care on chronic low back pain: a randomized, controlled trial. [Summary for patients in Ann Intern Med. 2011 Jul 5;155(1):I28; PMID: 21727286]. Ann Intern Med. 2011;155(1):1-9. [pmid: 21727288].
Cho Y-J, Song Y-K, Cha Y-Y, et al. Acupuncture for chronic low back pain: a multicenter, randomized, patient-assessor blind, sham-controlled clinical trial. Spine. 2013;38(7):549-57. [pmid: 23026870].
Chou R, Huffman L. Guideline for the evaluation and management of low back pain: evidence review. Glenview IL: American Pain Society. 2007.
Cloutier C, Taliano J, O'Mahony W, et al. Controlled-release oxycodone and naloxone in the treatment of chronic low back pain: a placebo-controlled, randomized study. Pain Res Manag. 2013;18(2):75-82. [pmid: 23662289].
Cox H, Tilbrook H, Aplin J, et al. A randomised controlled trial of yoga for the treatment of chronic low back pain: results of a pilot study. Complement Ther Clin Pract. 2010;16(4):187-93. [pmid: 20920800].
Cramer H, Lauche R, Haller H, et al. A systematic review and meta-analysis of yoga for low back pain. Clin J Pain. 2013;29(5):450-60. [pmid: 23246998].
de Oliveira RF, Liebano RE, Costa LdCM, et al. Immediate effects of region-specific and non-region-specific spinal manipulative therapy in patients with chronic low back pain: a randomized controlled trial. Phys Ther. 2013;93(6):748-56. [pmid: 23431209].
Dehghan M, Farahbod F. The efficacy of thermotherapy and cryotherapy on pain relief in patients with acute low back pain, a clinical trial study. J Clin Diagn Res. 2014;8(9):LC01-4. [pmid: 25386469].
Diab AA, Moustafa IM. Lumbar lordosis rehabilitation for pain and lumbar segmental motion in chronic mechanical low back pain: a randomized trial. J Manipulative Physiol Ther. 2012;35(4):246-53. [pmid: 22632584].
Diab AAM, Moustafa IM. The efficacy of lumbar extension traction for sagittal alignment in mechanical low back pain: a randomized trial. J Back Musculoskeletal Rehabil. 2013;26(2):213-20. [pmid: 23640324].
Djavid GE, Mehrdad R, Ghasemi M, et al. In chronic low back pain, low level laser therapy combined with exercise is more beneficial than exercise alone in the long term: a randomised trial. [Erratum appears in Aust J Physiother. 2007;53(4):216]. Aust J Physiother. 2007;53(3):155-60. [pmid: 17725472].
Durmus D, Akyol Y, Alayli G, et al. Effects of electrical stimulation program on trunk muscle strength, functional capacity, quality of life, and depression in the patients with low back pain: a randomized controlled trial. Rheumatol Int. 2009;29(8):947-54. [pmid: 19099308].
Durmus D, Durmaz Y, Canturk F. Effects of therapeutic ultrasound and electrical stimulation program on pain, trunk muscle strength, disability, walking performance, quality of life, and depression in patients with low back pain: a randomized-controlled trial. Rheumatol Int. 2010;30(7):901-10. [pmid: 19644691].
Ebadi S, Henschke N, Nakhostin Ansari N, et al. Therapeutic ultrasound for chronic low-back pain. Cochrane Database Syst Rev. 2014;3. CD009169. [pmid: 24627326].
Eisenberg DM, Buring JE, Hrbek AL, et al. A model of integrative care for low-back pain. J Altern Complement Med. 2012;18(4):354-62. [pmid: 22455544].
Eskin B, Shih RD, Fiesseler FW, et al. Prednisone for emergency department low back pain: a randomized controlled trial. J Emerg Med. 2014;47(1):65-70. [pmid: 24739318].
Facci LM, Nowotny JP, Tormem F, et al. Effects of transcutaneous electrical nerve stimulation (TENS) and interferential currents (IFC) in patients with nonspecific chronic low back pain: randomized clinical trial. Sao Paulo Med J. 2011;129(4):206-16. [pmid: 21971895].
Farajirad S, Behdani F, Hebrani P, et al. Comparison between the effects of amitriptyline and bupropione on the quality of life and the reduction in the severity of pain in patients with chronic low-back pain. Neurosurgery quarterly. 2013;23(4):227-9.
Fiore P, Panza F, Cassatella G, et al. Short-term effects of high-intensity laser therapy versus ultrasound therapy in the treatment of low back pain: a randomized controlled trial. Eur J Phys Rehabil Med. 2011;47(3):367-73. [pmid: 21654616].
French S, Cameron M, Walker B, et al. Superficial heat or cold for low back pain. Cochrane Database Syst Rev. 2006;(1). Art. No.: CD004750.
French SD, Cameron M, Walker BF, et al. Superficial heat or cold for low back pain. Cochrane Database Syst Rev. 2011;(2). [pmid: 16437495].
Friedman BW, Esses D, Solorzano C, et al. A randomized placebo-controlled trial of single-dose IM corticosteroid for radicular low back pain. Spine. 2008;33(18):E624-9. [pmid: 18665021].
Furlan AD, Imamura M, Dryden T, et al. Massage for low-back pain. Cochrane Database Syst Rev. 2010;(6).
Garcia AN, Costa LdCM, da Silva TM, et al. Effectiveness of back school versus McKenzie exercises in patients with chronic nonspecific low back pain: a randomized controlled trial. Phys Ther. 2013;93(6):729-47. [pmid: 23431213].
Gatchel RJ, Polatin PB, Noe C, et al. Treatment- and cost-effectiveness of early intervention for acute low-back pain patients: a one-year prospective study. J Occup Rehabil. 2003;13(1):1-9. [pmid: 12611026].
George SZ, Zeppieri G Jr., Cere AL, et al. A randomized trial of behavioral physical therapy interventions for acute and sub-acute low back pain (NCT00373867). Pain. 2008;140(1):145-57. [pmid: 18786762].
Glaser JA, Baltz MA, Nietert PJ, et al. Electrical muscle stimulation as an adjunct to exercise therapy in the treatment of nonacute low back pain: a randomized trial. J Pain. 2001;2(5):295-300. [pmid: 14622808].
Goertz CM, Long CR, Hondras MA, et al. Adding chiropractic manipulative therapy to standard medical care for patients with acute low back pain: results of a pragmatic randomized comparative effectiveness study. Spine. 2013;38(8):627-34. [pmid: 23060056].
Goren A, Yildiz N, Topuz O, et al. Efficacy of exercise and ultrasound in patients with lumbar spinal stenosis: a prospective randomized controlled trial. Clin Rehabil. 2010;24(7):623-31. [pmid: 20530650].
Haas M, Vavrek D, Peterson D, et al. Dose-response and efficacy of spinal manipulation for care of chronic low back pain: a randomized controlled trial. Spine J. 2014;14(7):1106-16. [pmid: 24139233].
Hagen EM, Odelien KH, Lie SA, et al. Adding a physical exercise programme to brief intervention for low back pain patients did not increase return to work. Scand J Public Health. 2010;38(7):731-8. [pmid: 20817653].
Hall AM, Maher CG, Lam P, et al. Tai chi exercise for treatment of pain and disability in people with persistent low back pain: a randomized controlled trial. Arthritis Care Res (Hoboken). 2011;63(11):1576-83. [pmid: 22034119].
Hamza MA, Ghoname EA, White PF, et al. Effect of the duration of electrical stimulation on the analgesic response in patients with low back pain. Anesthesiology. 1999;91(6):1622-7. [pmid: 10598602].
Hartvigsen J, Morso L, Bendix T, et al. Supervised and non-supervised Nordic walking in the treatment of chronic low back pain: a single blind randomized clinical trial. BMC Musculoskelet Disord. 2010;11:30. [pmid: 20146793].
Hasegawa TM, Baptista AS, de Souza MC, et al. Acupuncture for acute non-specific low back pain: a randomised, controlled, double-blind, placebo trial. Acupunct Med. 2014;32(2):109-15. [pmid: 24316509].
Hedeboe J, Buhl M, Ramsing P. Effects of using dexamethasone and placebo in the treatment of prolapsed lumbar disc. Acta Neurol Scand. 1982;65(1):6-10. [pmid: 7039210].
Helmhout PH, Harts CC, Viechtbauer W, et al. Isolated lumbar extensor strengthening versus regular physical therapy in an army working population with nonacute low back pain: a randomized controlled trial. Arch Phys Med Rehabil. 2008;89(9):1675-85. [pmid: 18675396].
Henchoz Y, de Goumoens P, Norberg M, et al. Role of physical exercise in low back pain rehabilitation: a randomized controlled trial of a three-month exercise program in patients who have completed multidisciplinary rehabilitation. Spine. 2010;35(12):1192-9. [pmid: 20098350].
Henschke N, Ostelo WJGR, van Tulder MW, et al. Behavioural treatment for chronic low-back pain. Cochrane Database Syst Rev. 2011;(2).
Herrmann WA, Geertsen MS. Efficacy and safety of lornoxicam compared with placebo and diclofenac in acute sciatica/lumbo-sciatica: an analysis from a randomised, double-blind, multicentre, parallel-group study. Int J Clin Pract. 2009;63(11):1613-21. [pmid: 19832818].
Hofstee DJ, Gijtenbeek JM, Hoogland PH, et al. Westeinde sciatica trial: randomized controlled study of bed rest and physiotherapy for acute sciatica. J Neurosurg. 2002;96(1 Suppl):45-9. [pmid: 11797655].
Holve RL, Barkan H. Oral steroids in initial treatment of acute sciatica. J Am Board Fam Med. 2008;21(5):469-74. [pmid: 18772303].
Hsieh RL, Lee WC. Short-term therapeutic effects of 890-nanometer light therapy for chronic low back pain: a double-blind randomized placebo-controlled study. Lasers Med Sci. 2014;29(2):671-9. [pmid: 23820974].
Hurley DA, Tully MA, Lonsdale C, et al. Supervised walking in comparison with fitness training for chronic back pain in physiotherapy: results of the SWIFT single-blinded randomized controlled trial (ISRCTN17592092). Pain. 2015;156(1):131-47. [pmid: 25599309].
Hyup Lee J, Lee C-S, Ultracet ERSG. A randomized, double-blind, placebo-controlled, parallel-group study to evaluate the efficacy and safety of the extended-release tramadol hydrochloride/acetaminophen fixed-dose combination tablet for the treatment of chronic low back pain. Clin Ther. 2013;35(11):1830-40. [pmid: 24183364].
Inani SB, Selkar SP. Effect of core stabilization exercises versus conventional exercises on pain and functional status in patients with non-specific low back pain: a randomized clinical trial. J Back Musculoskeletal Rehabil. 2013;26(1):37-43. [pmid: 23411647].
Jensen RK, Leboeuf-Yde C, Wedderkopp N, et al. Rest versus exercise as treatment for patients with low back pain and Modic changes. A randomized controlled clinical trial. BMC Med. 2012;10:22. [pmid: 22376791].
Jovicic M, Konstantinovic L, Lazovic M, et al. Clinical and functional evaluation of patients with acute low back pain and radiculopathy treated with different energy doses of low level laser therapy. Vojnosanit Pregl. 2012;69(8):656-62. [pmid: 22924260].
Kachanathu SJ, Alenazi AM, Seif HE, et al. Comparison between Kinesio Taping and a Traditional Physical Therapy Program in Treatment of Nonspecific Low Back Pain. J Phys Ther Sci. 2014;26(8):1185-8. [pmid: 25202177].
Kalita J, Kohat AK, Misra UK, et al. An open labeled randomized controlled trial of pregabalin versus amitriptyline in chronic low backache. J Neurol Sci. 2014;342(1-2):127-32. [pmid: 24857356].
Kamper SJ, Apeldoorn AT, Chiarotto A, et al. Multidisciplinary biopsychosocial rehabilitation for chronic low back pain. Cochrane Database Syst Rev. 2014;9. CD000963. [pmid: 25180773].
Kell RT, Risi AD, Barden JM. The response of persons with chronic nonspecific low back pain to three different volumes of periodized musculoskeletal rehabilitation. J Strength Cond Res. 2011;25(4):1052-64. [pmid: 20647943].
Kettenmann B, Wille C, Lurie-Luke E, et al. Impact of continuous low level heatwrap therapy in acute low back pain patients: subjective and objective measurements. Clin J Pain. 2007;23(8):663-8. [pmid: 17885344].
Khan M, Akhter S, Soomro RR, et al. The effectiveness of Cognitive Behavioral Therapy (CBT) with general exercises versus general exercises alone in the management of chronic low back pain. Pak. 2014;27(4 Suppl):1113-6. [pmid: 25016276].
Kong LJ, Fang M, Zhan HS, et al. Chinese massage combined with herbal ointment for athletes with nonspecific low back pain: a randomized controlled trial. Evid Based Complement Alternat Med. 2012;2012:695726. [pmid: 23258996].
Konstantinovic LM, Kanjuh ZM, Milovanovic AN, et al. Acute low back pain with radiculopathy: a double-blind, randomized, placebo-controlled study. Photomed Laser Surg. 2010;28(4):553-60. [pmid: 20001318].
Lam M, Galvin R, Curry P. Effectiveness of acupuncture for nonspecific chronic low back pain: a systematic review and meta-analysis. Spine. 2013;38(24):2124-38. [pmid: 24026151].
Lamb SE, Hansen Z, Lall R, et al. Group cognitive behavioural treatment for low-back pain in primary care: a randomised controlled trial and cost-effectiveness analysis. Lancet. 2010;375(9718):916-23. [pmid: 20189241].
Lamb SE, Mistry D, Lall R, et al. Group cognitive behavioural interventions for low back pain in primary care: extended follow-up of the Back Skills Training Trial (ISRCTN54717854). Pain. 2012;153(2):494-501. [pmid: 22226729].
Lara-Palomo IC, Aguilar-Ferrandiz ME, Mataran-Penarrocha GA, et al. Short-term effects of interferential current electro-massage in adults with chronic non-specific low back pain: a randomized controlled trial. Clin Rehabil. 2013;27(5):439-49. [pmid: 23035006].
Lee J-H, Choi T-Y, Lee MS, et al. Acupuncture for acute low back pain: a systematic review. Clin J Pain. 2013;29(2):172-85. [pmid: 23269281].
Licciardone JC, Minotti DE, Gatchel RJ, et al. Osteopathic manual treatment and ultrasound therapy for chronic low back pain: a randomized controlled trial. Ann Fam Med. 2013;11(2):122-9. [pmid: 23508598].
Little P, Lewith G, Webley F, et al. Randomised controlled trial of Alexander technique lessons, exercise, and massage (ATEAM) for chronic and recurrent back pain. Br J Sports Med. 2008;42(12):965-8. [pmid: 19096019].
Macedo LG, Latimer J, Maher CG, et al. Effect of motor control exercises versus graded activity in patients with chronic nonspecific low back pain: a randomized controlled trial. [Erratum appears in Phys Ther. 2012 Apr;92(4):631]. Phys Ther. 2012;92(3):363-77. [pmid: 22135712].
Machado LAC, Maher CG, Herbert RD, et al. The effectiveness of the McKenzie method in addition to first-line care for acute low back pain: a randomized controlled trial. BMC Med. 2010;8:10. [pmid: 20102596].
Majchrzycki M, Kocur P, Kotwicki T. Deep tissue massage and nonsteroidal anti-inflammatory drugs for low back pain: a prospective randomized trial. ScientificWorldJournal. 2014;2014:287597. [pmid: 24707200].
Markman JD, Frazer ME, Rast SA, et al. Double-blind, randomized, controlled, crossover trial of pregabalin for neurogenic claudication. Neurology. 2014. [pmid: 25503625].
Mazza M, Mazza O, Pazzaglia C, et al. Escitalopram 20 mg versus duloxetine 60 mg for the treatment of chronic low back pain. Expert Opin Pharmacother. 2010;11(7):1049-52. [pmid: 20402551].
Mbada CE, Ayanniyi O, Ogunlade SO, et al. Influence of Mckenzie protocol and two modes of endurance exercises on health-related quality of life of patients with long-term mechanical low-back pain. Pan Afr Med J. Suppl 1. 2014;17:5. [pmid: 24624241].
Monticone M, Ambrosini E, Rocca B, et al. A multidisciplinary rehabilitation programme improves disability, kinesiophobia and walking ability in subjects with chronic low back pain: results of a randomised controlled pilot study. Eur Spine J. 2014;23(10):2105-13. [pmid: 25064093].
Moore SR, Shurman J. Combined neuromuscular electrical stimulation and transcutaneous electrical nerve stimulation for treatment of chronic back pain: a double-blind, repeated measures comparison. Arch Phys Med Rehabil. 1997;78(1):55-60. [pmid: 9014958].
Morrisette DC, Cholewicki J, Logan S, et al. A randomized clinical trial comparing extensible and inextensible lumbosacral orthoses and standard care alone in the management of lower back pain. Spine (Phila Pa 1976). 2014;39(21):1733-42. [pmid: 25054648].
Moustafa IM, Diab AA. Extension traction treatment for patients with discogenic lumbosacral radiculopathy: a randomized controlled trial. Clin Rehabil. 2013;27(1):51-62. [pmid: 22684211].
Nambi GS, Inbasekaran D, Khuman R, et al. Changes in pain intensity and health related quality of life with Iyengar yoga in nonspecific chronic low back pain: A randomized controlled study. Int. 2014;7(1):48-53. [pmid: 25035607].
Oesch P, Kool J, Hagen KB, et al. Effectiveness of exercise on work disability in patients with non-acute non-specific low back pain: Systematic review and meta-analysis of randomised controlled trials. J Rehabil Med. 2010;42(3):193-205. [pmid: 20411212].
Oleske DM, Lavender SA, Andersson GBJ, et al. Are back supports plus education more effective than education alone in promoting recovery from low back pain?: Results from a randomized clinical trial. Spine. 2007;32(19):2050-7. [pmid: 17762804].
Paatelma M, Kilpikoski S, Simonen R, et al. Orthopaedic manual therapy, McKenzie method or advice only for low back pain in working adults: a randomized controlled trial with one year follow-up. J Rehabil Med. 2008;40(10):858-63. [pmid: 19242624].
Paoloni M, Bernetti A, Fratocchi G, et al. Kinesio Taping applied to lumbar muscles influences clinical and electromyographic characteristics in chronic low back pain patients. Eur J Phys Rehabil Med. 2011;47(2):237-44. [pmid: 21430611].
Pareek A, Chandurkar N, Chandanwale AS, et al. Aceclofenac-tizanidine in the treatment of acute low back pain: a double-blind, double-dummy, randomized, multicentric, comparative study against aceclofenac alone. Eur Spine J. 2009;18(12):1836-42. [pmid: 19421791].
Pengel LHM, Refshauge KM, Maher CG, et al. Physiotherapist-directed exercise, advice, or both for subacute low back pain: a randomized trial. [Summary for patients in Ann Intern Med. 2007 Jun 5;146(11):I56; PMID: 17548406]. Ann Intern Med. 2007;146(11):787-96. [pmid: 17548410].
Perez-Palomares S, Olivan-Blazquez B, Magallon-Botaya R, et al. Percutaneous electrical nerve stimulation versus dry needling: effectiveness in the treatment of chronic low back pain. Journal of musculoskeletal pain. 2010;18(1):23-30.
Petersen T, Larsen K, Nordsteen J, et al. The McKenzie method compared with manipulation when used adjunctive to information and advice in low back pain patients presenting with centralization or peripheralization: a randomized controlled trial. Spine. 2011;36(24):1999-2010. [pmid: 21358492].
Pope MH, Phillips RB, Haugh LD, et al. A prospective randomized three-week trial of spinal manipulation, transcutaneous muscle stimulation, massage and corset in the treatment of subacute low back pain. Spine (Phila Pa 1976). 1994;19(22):2571-7. [pmid: 7855683].
Pota V, Barbarisi M, Sansone P, et al. Combination therapy with transdermal buprenorphine and pregabalin for chronic low back pain. Pain manag. 2012;2(1):23-31. [pmid: 24654615].
Prasad KSM, Gregson BA, Hargreaves G, et al. Inversion therapy in patients with pure single level lumbar discogenic disease: a pilot randomized trial. Disabil Rehabil. 2012;34(17):1473-80. [pmid: 22263648].
Ralph L, Look M, Wheeler W, et al. Double-blind, placebo-controlled trial of carisoprodol 250-mg tablets in the treatment of acute lower-back spasm. Curr Med Res Opin. 2008;24(2):551-8. [pmid: 18194591].
Rauck RL, Nalamachu S, Wild JE, et al. Single-entity hydrocodone extended-release capsules in opioid-tolerant subjects with moderate-to-severe chronic low back pain: a randomized double-blind, placebo-controlled study. Pain Med. 2014;15(6):975-85. [pmid: 24517082].
Roelofs PDDM, Deyo RA, Koes BW, et al. Non-steroidal anti-inflammatory drugs for low back pain. Cochrane Database Syst Rev. 2008;(1). CD000396. [pmid: 18253976].
Romano CL, Romano D, Bonora C, et al. Pregabalin, celecoxib, and their combination for treatment of chronic low-back pain. J. 2009;10(4):185-91. [pmid: 19921480].
Romanowski M, Romanowska J, Grzeskowiak M. A comparison of the effects of deep tissue massage and therapeutic massage on chronic low back pain. Stud Health Technol Inform. 2012;176:411-4. [pmid: 22744541].
Rubinstein SM, Terwee CB, Assendelft WJJ, et al. Spinal manipulative therapy for acute low-back pain. Cochrane Database Syst Rev. 2012;9. CD008880. [pmid: 22972127].
Rubinstein SM, van Middelkoop M, Assendelft WJ, et al. Spinal manipulative therapy for chronic low-back pain. Cochrane Database Syst Rev. 2011;(2). CD008112. [pmid: 21328304].
Santilli V, Beghi E, Finucci S. Chiropractic manipulation in the treatment of acute back pain and sciatica with disc protrusion: a randomized double-blind clinical trial of active and simulated spinal manipulations. Spine J. 2006;6(2):131-7. [pmid: 16517383].
Saper RB, Boah AR, Keosaian J, et al. Comparing Once- versus Twice-Weekly Yoga Classes for Chronic Low Back Pain in Predominantly Low Income Minorities: A Randomized Dosing Trial. Evid Based Complement Alternat Med. 2013;2013:658030. [pmid: 23878604].
Sato N, Sekiguchi M, Kikuchi S, et al. Effects of long-term corset wearing on chronic low back pain. Fukushima J Med Sci. 2012;58(1):60-5. [pmid: 22790893].
Schiphorst Preuper HR, Geertzen JHB, van Wijhe M, et al. Do analgesics improve functioning in patients with chronic low back pain? An explorative triple-blinded RCT. Eur Spine J. 2014;23(4):800-6. [pmid: 24526247].
Schneider M, Haas M, Glick R, et al. Comparison of spinal manipulation methods and usual medical care for acute and subacute low back pain: a randomized clinical trial. Spine. 2015;40(4):209-17. [pmid: 25423308].
Senna MK, Machaly SA. Does maintained spinal manipulation therapy for chronic nonspecific low back pain result in better long-term outcome?. Spine. 2011;36(18):1427-37. [pmid: 21245790].
Shakoor MA, Rahman MS, Moyeenuzzaman M. Effects of deep heat therapy on the patients with chronic low back pain. Mymensingh Med J. 2008;17(2 Suppl):S32-8. [pmid: 18946448].
Shimoji K, Takahashi N, Nishio Y, et al. Pain relief by transcutaneous electric nerve stimulation with bidirectional modulated sine waves in patients with chronic back pain: a randomized, double-blind, sham-controlled study. Neuromodulation. 2007;10(1):42-51. [pmid: 22151811].
Shirado O, Doi T, Akai M, et al. Multicenter randomized controlled trial to evaluate the effect of home-based exercise on patients with chronic low back pain: the Japan low back pain exercise therapy study. Spine. 2010;35(17):E811-9. [pmid: 20628332].
Siemonsma PC, Stuive I, Roorda LD, et al. Cognitive treatment of illness perceptions in patients with chronic low back pain: a randomized controlled trial. Phys Ther. 2013;93(4):435-48. [pmid: 23162040].
Silva Parreira PdC, Costa LC, Takahashi R, et al. Kinesio Taping to generate skin convolutions is not better than sham taping for people with chronic non-speci fi c low back pain: a randomised trial. J Physiother. 2014;60(2):90-6. [pmid: 24952836].
Skljarevski V, Desaiah D, Liu-Seifert H, et al. Efficacy and safety of duloxetine in patients with chronic low back pain. Spine. 2010;35(13):E578-85. [pmid: 20461028].
Skljarevski V, Ossanna M, Liu-Seifert H, et al. A double-blind, randomized trial of duloxetine versus placebo in the management of chronic low back pain. Eur J Neurol. 2009;16(9):1041-8. [pmid: 19469829].
Skljarevski V, Zhang S, Desaiah D, et al. Duloxetine versus placebo in patients with chronic low back pain: a 12-week, fixed-dose, randomized, double-blind trial. J Pain. 2010;11(12):1282-90. [pmid: 20472510].
Sritoomma N, Moyle W, Cooke M, et al. The effectiveness of Swedish massage with aromatic ginger oil in treating chronic low back pain in older adults: a randomized controlled trial. Complement Ther Med. 2014;22(1):26-33. [pmid: 24559813].
Stark J, Petrofsky J, Berk L, et al. Continuous low-level heatwrap therapy relieves low back pain and reduces muscle stiffness. Phys Sportsmed. 2014;42(4):39-48. [pmid: 25419887].
Tao XG, Bernacki EJ. A randomized clinical trial of continuous low-level heat therapy for acute muscular low back pain in the workplace. J Occup Environ Med. 2005;47(12):1298-306. [pmid: 16340712].
Tekur P, Nagarathna R, Chametcha S, et al. A comprehensive yoga programs improves pain, anxiety and depression in chronic low back pain patients more than exercise: an RCT. Complement Ther Med. 2012;20(3):107-18. [pmid: 22500659].
Tsukayama H, Yamashita H, Amagai H, et al. Randomised controlled trial comparing the effectiveness of electroacupuncture and TENS for low back pain: a preliminary study for a pragmatic trial. Acupunct Med. 2002;20(4):175-80. [pmid: 12512791].
Unlu Z, Tasci S, Tarhan S, et al. Comparison of 3 physical therapy modalities for acute pain in lumbar disc herniation measured by clinical evaluation and magnetic resonance imaging. J Manipulative Physiol Ther. 2008;31(3):191-8. [pmid: 18394495].
Urquhart DM, Hoving JL, Assendelft JJW, et al. Antidepressants for non-specific low back pain. Cochrane Database Syst Rev. 2010;(10).
van Duijvenbode I, Jellema P, van Poppel M, et al. Lumbar supports for prevention and treatment of low back pain. Cochrane Database Syst Rev. 2011;(2).
van Middelkoop M, Rubinstein SM, Kuijpers T, et al. A systematic review on the effectiveness of physical and rehabilitation interventions for chronic non-specific low back pain. European Spine Journal. 2011;20:19-39. [pmid: 20640863].
van Middelkoop M, Rubinstein SM, Verhagen AP, et al. Exercise therapy for chronic nonspecific low-back pain. Baillieres Best Pract Res Clin Rheumatol. 2010;24(2):193-204. [pmid: 20227641].
Vas J, Aranda JM, Modesto M, et al. Acupuncture in patients with acute low back pain: a multicentre randomised controlled clinical trial. Pain. 2012;153(9):1883-9. [pmid: 22770838].
von Heymann WJ, Schloemer P, Timm J, et al. Spinal high-velocity low amplitude manipulation in acute nonspecific low back pain: a double-blinded randomized controlled trial in comparison with diclofenac and placebo. Spine. 2013;38(7):540-8. [pmid: 23026869].
Vong SK, Cheing GL, Chan F, et al. Motivational enhancement therapy in addition to physical therapy improves motivational factors and treatment outcomes in people with low back pain: a randomized controlled trial. Arch Phys Med Rehabil. 2011;92(2):176-83. [pmid: 21272712].
Wegner I, Widyahening IS, van Tulder MW, et al. Traction for low-back pain with or without sciatica. Cochrane Database Syst Rev. 2013;8. CD003010. [pmid: 23959683].
Weifen W, Muheremu A, Chaohui C, et al. Effectiveness of tai chi practice for non-specific chronic low back pain on retired athletes: A randomized controlled study. Journal of musculoskeletal pain. 2013;21(1):37-45.
Weiner DK, Perera S, Rudy TE, et al. Efficacy of percutaneous electrical nerve stimulation and therapeutic exercise for older adults with chronic low back pain: a randomized controlled trial. Pain. 2008;140(2):344-57. [pmid: 18930352].
Weiss J, Quante S, Xue F, et al. Effectiveness and acceptance of acupuncture in patients with chronic low back pain: results of a prospective, randomized, controlled trial. J Altern Complement Med. 2013;19(12):935-41. [pmid: 23738680].
Wells C, Kolt GS, Marshall P, et al. The effectiveness of pilates exercise in people with chronic low back pain: a systematic review. PLoS ONE. 2014;9(7):e100402. [pmid: 24984069].
Williams CM, Maher CG, Latimer J, et al. Efficacy of paracetamol for acute low-back pain: a double-blind, randomised controlled trial. Lancet. 2014;384(9954):1586-96. [pmid: 25064594].
Yaksi A, Ozgonenel L, Ozgonenel B. The efficiency of gabapentin therapy in patients with lumbar spinal stenosis. Spine. 2007;32(9):939-42. [pmid: 17450066].
Yun M, Xiong N, Guo M, et al. Acupuncture at the back-pain-acupoints for chronic low back pain of Peacekeepers in Lebanon: A randomized controlled trial. Journal of musculoskeletal pain. 2012;20(2):107-15.
Zhang Y, Tang S, Chen G, et al. Chinese massage combined with core stability exercises for nonspecific low back pain: A randomized controlled trial. Complement Ther Med. 2015;23(1):1-6. [pmid: 25637146].
Zheng Z, Wang J, Gao Q, et al. Therapeutic evaluation of lumbar tender point deep massage for chronic non-specific low back pain. J Tradit Chin Med. 2012;32(4):534-7. [pmid: 23427384].