# Inclusion and Exclusion Criteria

Table B Inclusion and exclusion criteria

PICOTS | Include | Exclude
Population | Adults with acute, subacute, or chronic nonradicular low back pain, radicular low back pain, or symptomatic spinal stenosis. | Children, pregnant women Patients with low back pain related to cancer, infection, inflammatory arthropathy, high velocity trauma, fracture; or low back pain associated with severe or progressive neurological deficits
Interventions | KQ 1: Nonsteroidal anti-inflammatory drugs (NSAIDs) Nonopioid analgesics, such as acetaminophen Opioid analgesics, such as oxycodone, hydrocodone, hydromorphone, morphine, fentanyl Antidepressants, such as tricyclic antidepressants, serotonin-norepinephrine reuptake inhibitors (SNRIs), and selective serotonin-reuptake inhibitors (SSRIs), or serotonin antagonist and reuptake inhibitors (SARIs) Skeletal muscle relaxants, including benzodiazepines Corticosteroids, such as prednisone or prednisolone Anti-epileptic drugs, such as gabapentin or pregabalin Capsaicin or topical lidocaine | Parenterally administered medications
Interventions | KQ 2: Interdisciplinary or multicomponent rehabilitation Psychological therapies, such as cognitive behavioral therapy Exercise and related interventions, such as yoga or Tai Chi Complementary and alternative medicine therapies: spinal manipulation, acupuncture, massage Passive physical modalities: heat, cold, ultrasound, transcutaneous electrical nerve stimulation (TENS), electrical muscle stimulation (EMS), interferential therapy (IFT), traction, low level laser therapy, lumbar supports/braces Back schools Other noninvasive treatments, such as taping | Invasive, nonsurgical therapies (e.g., injections) and surgical therapies
Comparators | Any included intervention(s) versus any other included intervention(s); noninvasive, nonsurgical treatment options, alone or in combination (which may include both nonpharmacological and pharmacological) components. Other possible comparators include placebo (drug trials), sham (functionally-inert) treatments, or no treatment.
Outcomes | Benefits (effectiveness): Reduction or elimination of low back pain, including related leg symptoms Improvement in back-specific and overall function Improvement in health-related quality of life (HRQOL) Reduction in work disability/return to work Global improvement Number of back pain episodes or time between episodes Patient satisfaction Harms: Pharmaceutical: serious (anaphylaxis, death) and nonserious (mild allergic or untoward) drug reactions or effects; opioid addiction or overdose Nonpharmaceutical: serious (death, neurological including cauda equine syndrome, fracture, local skin burns, etc.) and nonserious (mild transient local or general soreness, stiffness, aching; local skin irritation, etc.)
Timing | Duration of followup: short term (up to 6 months) and long term (at least 1 year)
Setting | Any nonhospital setting or in self-directed care