# Search Strategies

## Database: Ovid MEDLINE(R) Without Revisions 1996 to April Week 3 2015, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations <April 27, 2015>

Population
1. Low Back Pain/
2. Spinal Stenosis/
3. Radiculopathy/
4. Back Injuries/
5. Spinal Injuries/
6. (“low back pain” or (spinal adj3 stenosis) or radiculopathy or radicular).ti,ab.
7. or/1-6

Pharmacologic interventions
8 nsaids.mp. or Anti-Inflammatory Agents, Non-Steroidal/
9 (acetaminophen or paracetamol or aspirin or diflunisal or “choline magnesium trisalicylate” or salsalate or naproxen or ibuprofen or ketoprofen or flurbiprofen or oxaprzin or diclofenac or etodolac or tolmetin of sulindac or meloxicam or piroxicam or meclofenamate or nabumetone or celecoxib).mp.
10 opioids.mp. or Analgesics, Opioid/
11 (alfentanil or alphaprodine or beta-casomorphin$ or buprenorphine or carfentanil or codeine or deltorphin or dextromethorphan or dezocine or dihydrocodeine or dihydromorphine or enkephalin$ or ethylketocyclazocine or ethylmorphine or etorphine or fentanyl or heroin or hydrocodone or hydromorphone or ketobemidone or levorphanol or lofentanil or meperidine or meptazinol or methadone or methadyl acetate or morphine or nalbuphine or opium or oxycodone or oxymorphone or pentazocine or phenazocine or phenoperidine or pirinitramide or promedol or propoxyphene or remifentanil or sufentanil or tilidine or tapentadol or tramadol).mp.
12 antidepressants.mp. or Antidepressive Agents/
13 Antidepressive Agents, Second-Generation/ or Antidepressive Agents, Tricyclic/
14 Serotonin Uptake Inhibitors/
15 (amitriptyline or clomipramine or desipramine or doxepin or imipramine or nortriptyline or citalopram or escitalopram or fluoxetine or paroxetine or sertraline or venlafaxine or duloxetine).mp.
16 skeletal muscle relaxants.mp. or Neuromuscular Agents/
17 (baclofen or carisoprodol or chlorzoxazone or cyclobenzaprine or dantrolene or metaxalone or methocarbamol or orphenadrine or tizanidine).mp.
18 corticosteroids.mp. or Adrenal Cortex Hormones/
19 (prednisone or prednisolone).mp.
20 anticonvulsants.mp. or Anticonvulsants/
21 (gabapentin or pregabalin).mp.
22 Anesthetics, Local/
23 (capsaisin or lidocaine).mp.
24 (22 or 23) and topical.mp.
25 or/8-21
26 24 or 25

Nonpharmacologic interventions
27 Rehabilitation/
28 Physical Therapy Modalities/
29 (rehabilitation adj3 multicomponent).mp.
30 (rehabilitation adj3 interdisciplinary).mp.
31 Cognitive Therapy/
32 exp Psychotherapy/
33 exercise therapy.mp. or Exercise Therapy/
34 exp Complementary Therapies/
35 yoga.mp. or Yoga/
36 tai chi.mp. or Tai Ji/
37 Acupuncture Therapy/ or Acupuncture/ or acupuncture.mp.
38 Massage/ or massage.mp.
39 spinal manipulation.mp. or Manipulation, Spinal/
40 tens.mp. or Transcutaneous Electric Nerve Stimulation/
41 Hot Temperature/tu
42 Cryotherapy/
43 Electric Stimulation Therapy/
44 Traction/ or traction.mp.
45 laser therapy.mp. or Laser Therapy/
46 orthotic devices/ or athletic tape/ or braces/
47 Patient Education as Topic/
48 47 and back pain/
49 “back school$”.mp.
50 or/27-46
51 or/48-50
52 7 and (26 or 51)
53 limit 52 to yr=“2007 - 2015”

Limit to RCTs
54 randomized controlled trial.mp. or exp Randomized Controlled Trial/
55 randomized controlled trial.pt.
56 controlled clinical trial.mp. or exp Controlled Clinical Trial/
57 controlled clinical trial.pt.
58 clinical trial.mp. or exp Clinical Trial/
59 clinical trial.pt.
60 or/54-59
61 limit 60 to humans

Limit to systematic reviews
62 53 and 61
63 meta-analysis.mp. or exp Meta-Analysis/
64 (cochrane or medline).tw.
65 search$.tw.
66 63 or 64 or 65
67 “Review Literature as Topic”/ or systematic review.mp.
68 66 or 67
69 53 and 68

Limit to controlled observational studies
70 53 and (cohort or control$).mp

Combined searches
71 62 or 69 or 70
72 limit 71 to english language
73 limit 71 to abstracts
74 72 or 73

## Database: EBM Reviews - Cochrane Central Register of Controlled Trials <March 2015>

Population
1. Low Back Pain/
2. Spinal Stenosis/
3. Radiculopathy/
4. Back Injuries/
5. Spinal Injuries/
6. (“low back pain” or (spinal adj3 stenosis) or radiculopathy or radicular).ti,ab.
7. or/1-6

Pharmacologic interventions
8 nsaids.mp. or Anti-Inflammatory Agents, Non-Steroidal/
9 (acetaminophen or paracetamol or aspirin or diflunisal or “choline magnesium trisalicylate” or salsalate or naproxen or ibuprofen or ketoprofen or flurbiprofen or oxaprzin or diclofenac or etodolac or tolmetin of sulindac or meloxicam or piroxicam or meclofenamate or nabumetone or celecoxib).mp.
10 opioids.mp. or Analgesics, Opioid/
11 (alfentanil or alphaprodine or beta-casomorphin$ or buprenorphine or carfentanil or codeine or deltorphin or dextromethorphan or dezocine or dihydrocodeine or dihydromorphine or enkephalin$ or ethylketocyclazocine or ethylmorphine or etorphine or fentanyl or heroin or hydrocodone or hydromorphone or ketobemidone or levorphanol or lofentanil or meperidine or meptazinol or methadone or methadyl acetate or morphine or nalbuphine or opium or oxycodone or oxymorphone or pentazocine or phenazocine or phenoperidine or pirinitramide or promedol or propoxyphene or remifentanil or sufentanil or tilidine or tapentadol or tramadol).mp.
12 antidepressants.mp. or Antidepressive Agents/
13 Antidepressive Agents, Second-Generation/ or Antidepressive Agents, Tricyclic/
14 Serotonin Uptake Inhibitors/
15 (amitriptyline or clomipramine or desipramine or doxepin or imipramine or nortriptyline or citalopram or escitalopram or fluoxetine or paroxetine or sertraline or venlafaxine or duloxetine).mp.
16 skeletal muscle relaxants.mp. or Neuromuscular Agents/
17 (baclofen or carisoprodol or chlorzoxazone or cyclobenzaprine or dantrolene or metaxalone or methocarbamol or orphenadrine or tizanidine).mp.
18 corticosteroids.mp. or Adrenal Cortex Hormones/
19 (prednisone or prednisolone).mp.
20 anticonvulsants.mp. or Anticonvulsants/
21 (gabapentin or pregabalin).mp.
22 Anesthetics, Local/
23 (capsaisin or lidocaine).mp.
24 (22 or 23) and topical.mp.
25 or/8-21
26 24 or 25

Nonpharmacologic interventions
27 Rehabilitation/
28 Physical Therapy Modalities/
29 (rehabilitation adj3 multicomponent).mp.
30 (rehabilitation adj3 interdisciplinary).mp.
31 Cognitive Therapy/
32 exp Psychotherapy/
33 exercise therapy.mp. or Exercise Therapy/
34 exp Complementary Therapies/
35 yoga.mp. or Yoga/
36 tai chi.mp. or Tai Ji/
37 Acupuncture Therapy/ or Acupuncture/ or acupuncture.mp.
38 Massage/ or massage.mp.
39 spinal manipulation.mp. or Manipulation, Spinal/
40 tens.mp. or Transcutaneous Electric Nerve Stimulation/
41 Hot Temperature/tu
42 Cryotherapy/
43 Electric Stimulation Therapy/
44 Traction/ or traction.mp.
45 laser therapy.mp. or Laser Therapy/
46 orthotic devices/ or athletic tape/ or braces/
47 Patient Education as Topic/
48 47 and back pain/
49 “back school$”.mp.

Combined searches
50 or/27-46
51 or/48-50
52 7 and (26 or 51)
53 limit 52 to yr=“2007 - 2015”

## Database: EBM Reviews - Cochrane Database of Systematic Reviews <2005 to March 2015>

1. “low back pain”.ti.
2. limit 1 to full systematic reviews