# Abbreviations

Abbreviation: Term
AHRQ: Agency for Healthcare Research and Quality
CER: Comparative Effectiveness Review
CGI-S: Clinical Global Impressions of Severity
CI: Confidence interval
DASS: Depression Anxiety Stress Scales
EMG: Electromyography
EMS: Electrical muscle stimulation
HADS: Hospital Anxiety and Depression Scale
HRQOL: Health-related quality of life
HVLA: High-velocity low-amplitude
IFT: Interferential therapy
JLEQ: Japan Low Back Pain Evaluation Questionnaire
LBP: Low back pain
LBPOI: Low Back Pain Outcome Instrument
LBRS: Low back pain rating scale
LLLT: Low-level laser therapy
MBR: Multidisciplinary biopsychosocial rehabilitation
MCE: Motor control exercise
MCS: Mental component score of the SF-36
MD: Mean difference
NRS: Numeric rating scale
NSAID: Nonsteroidal anti-inflammatory drug
ODI: Oswestry Disability Index
PCS scores: Pain Catastrophizing Scale
PICOTS: Population, intervention, comparator, outcomes, timing, settings, and study designs
QOL: Quality of life
RCT: Randomized controlled trial
RDQ: Roland-Morris Disability Questionnaire
RR: Relative risk
SARI: Serotonin antagonist and reuptake inhibitors
SF-36: Short Form-36
SMD: Standardized mean difference
SMT: Spinal manipulation therapy
SNRI: Serotonin-norepinephrine reuptake inhibitors
SOE: Strength of evidence
SSRI: Selective serotonin reuptake inhibitor
TENS: Transcutaneous electrical nerve stimulation
TEP: Technical Expert Panel
VAS: Visual analogue scale
WMD: Weighted mean difference