# References

1 Wassef M, Blei F, Adams D, et al. Vascular anomalies classification: recommendations from the International Society for the Study of Vascular Anomalies. Pediatrics. Jul. 2015;136(1):e203-14. [pmid: 26055853].
2 Kilcline C, Frieden IJ. Infantile hemangiomas: how common are they? A systematic review of the medical literature. Pediatr Dermatol. Mar–Apr. 2008;25(2):168-73. [pmid: 18429772].
3 Hoornweg MJ, Smeulders MJ, van der Horst CM. Prevalence and characteristics of haemangiomas in young children. Ned Tijdschr Geneeskd. Oct. 29. 2005;149(44):2455-8. [pmid: 16285361].
4 Jacobs AH, Walton RG. The incidence of birthmarks in the neonate. Pediatrics. Aug. 1976;58(2):218-22. [pmid: 951136].
5 Iacobas I, Burrows PE, Frieden IJ, et al. LUMBAR: association between cutaneous infantile hemangiomas of the lower body and regional congenital anomalies. J Pediatr. Nov. 2010;157(5):795-801.e1–7. [pmid: 20598318].
6 Christison-Lagay ER, Burrows PE, Alomari A, et al. Hepatic hemangiomas: subtype classification and development of a clinical practice algorithm and registry. J Pediatr Surg. Jan. 2007;42(1):62-7. discussion 7–8. [pmid: 17208542].
7 Stockman A, Boralevi F, Taieb A, et al. SACRAL syndrome: spinal dysraphism, anogenital, cutaneous, renal and urologic anomalies, associated with an angioma of lumbosacral localization. Dermatology. 2007;214(1):40-5. [pmid: 17191046].
8 Enjolras O, Mulliken JB. The current management of vascular birthmarks. Pediatr Dermatol. Dec. 1993;10(4):311-3. [pmid: 8302734].
9 Chang LC, Haggstrom AN, Drolet BA, et al. Growth characteristics of infantile hemangiomas: implications for management. Pediatrics. Aug. 2008;122(2):360-7. [pmid: 18676554].
10 Ceisler EJ, Santos L, Blei F. Periocular hemangiomas: what every physician should know. Pediatr Dermatol. Jan–Feb. 2004;21(1):1-9. [pmid: 14871317].
11 Kim HJ, Colombo M, Frieden IJ. Ulcerated hemangiomas: clinical characteristics and response to therapy. J Am Acad Dermatol. Jun. 2001;44(6):962-72. [pmid: 11369908].
12 Chamlin SL, Haggstrom AN, Drolet BA, et al. Multicenter prospective study of ulcerated hemangiomas. J Pediatr. Dec. 2007;151(6):684-9. 9.e1. [pmid: 18035154].
13 Hartemink DA, Chiu YE, Drolet BA, et al. PHACES syndrome: a review. Int J Pediatr Otorhinolaryngol. Feb. 2009;73(2):181-7. [pmid: 19101041].
14 Tawfik AA, Alsharnoubi J. Topical Timolol Solution Versus Laser in Treatment of Infantile Hemangioma: A Comparative Study. Pediatr Dermatol. 2015. Mar. 5. [pmid: 25740672].
15 Drolet BA, Frommelt PC, Chamlin SL, et al. Initiation and use of propranolol for infantile hemangioma: report of a consensus conference. Pediatrics. Jan. 2013;131(1):128-40. [pmid: 23266923].
16 Sans V, de la Roque ED, Berge J, et al. Propranolol for severe infantile hemangiomas: follow-up report. Pediatrics. Sep. 2009;124(3):e423-31. [pmid: 19706583].
17 Hogeling M, Adams S, Wargon O. A randomized controlled trial of propranolol for infantile hemangiomas. Pediatrics. Aug. 2011;128(2):e259-66. [pmid: 21788220].
18 Georgountzou A, Karavitakis E, Klimentopoulou A, et al. Propranolol treatment for severe infantile hemangiomas: a single-centre 3-year experience. Acta Paediatr. Oct. 2012;101(10):e469-74. [pmid: 22804809].
19 Leaute-Labreze C, Dumas de la Roque E, Hubiche T, et al. Propranolol for severe hemangiomas of infancy. N Engl J Med. Jun. 12. 2008;358(24):2649-51. [pmid: 18550886].
20 Chang E, Boyd A, Nelson CC, et al. Successful treatment of infantile hemangiomas with interferon-alpha-2b. J Pediatr Hematol Oncol. May–Jun. 1997;19(3):237-44. [pmid: 9201147].
21 Metry DW, Hebert AA. Benign cutaneous vascular tumors of infancy: when to worry, what to do. Arch Dermatol. Jul. 2000;136(7):905-14. [pmid: 10890993].
22 Darrow DH, Greene AK, Mancini AJ, et al. Diagnosis and management of infantile hemangioma. Pediatrics. 2015. in press.
23 Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(14)-EHC063-EF. Rockville, MD. Agency for Healthcare Research and Quality. January. 2014. Chapters available at: www.effectivehealthcare.ahrq.gov.
24 Mulliken JB, Glowacki J. Hemangiomas and vascular malformations in infants and children: a classification based on endothelial characteristics. Plast Reconstr Surg. Mar. 1982;69(3):412-22. [pmid: 7063565].
25 Viswanathan M, Ansari MT, Berkman ND, et al. Assessing the Risk of Bias of Individual Studies in Systematic Reviews of Health Care Interventions. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Rockville (MD). 2008.
26 Wells G, et al. The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomised studies in meta-analyses. Available at http://www.ohri.ca/programs/clinical_epidemiology/oxford.asp.
27 Whiting PF, Rutjes AW, Westwood ME, et al. QUADAS-2: a revised tool for the quality assessment of diagnostic accuracy studies. Ann Intern Med. Oct. 18. 2011;155(8):529-36. [pmid: 22007046].
28 McMaster Centre for Evidence-based Practice. McMaster Quality Assessment Scale of Harms (McHarm) for primary studies. Hamilton ON. McMaster University. 2008.
29 Berkman ND, Lohr KN, Ansari MT, et al. Grading the strength of a body of evidence when assessing health care interventions: an EPC update. J Clin Epidemiol. 2014. Dec. 20. [pmid: 25721570].
30 Chiller KG, Passaro D, Frieden IJ. Hemangiomas of infancy: clinical characteristics, morphologic subtypes, and their relationship to race, ethnicity, and sex. Arch Dermatol. Dec. 2002;138(12):1567-76. [pmid: 12472344].
31 Haggstrom AN, Drolet BA, Baselga E, et al. Prospective study of infantile hemangiomas: clinical characteristics predicting complications and treatment. Pediatrics. Sep. 2006;118(3):882-7. [pmid: 16950977].
32 Li J, Chen X, Zhao S, et al. Demographic and clinical characteristics and risk factors for infantile hemangioma: a Chinese case-control study. Arch Dermatol. Sep. 2011;147(9):1049-56. [pmid: 21576550].
33 Stier MF, Glick SA, Hirsch RJ. Laser treatment of pediatric vascular lesions: Port wine stains and hemangiomas. J Am Acad Dermatol. Feb. 2008;58(2):261-85. [pmid: 18068263].
34 Bruckner AL, Frieden IJ. Hemangiomas of infancy. J Am Acad Dermatol. Apr. 2003;48(4):477-93. quiz 94–6. [pmid: 12664009].
35 Finn MC, Glowacki J, Mulliken JB. Congenital vascular lesions: clinical application of a new classification. J Pediatr Surg. Dec. 1983;18(6):894-900. [pmid: 6663421].
36 Tollefson MM, Frieden IJ. Early growth of infantile hemangiomas: what parents’ photographs tell us. Pediatrics. Aug. 2012;130(2):e314-20. [pmid: 22826568].
37 Brandling-Bennett HA, Metry DW, Baselga E, et al. Infantile hemangiomas with unusually prolonged growth phase: a case series. Arch Dermatol. Dec. 2008;144(12):1632-7. [pmid: 19075148].
38 Couto RA, Maclellan RA, Zurakowski D, et al. Infantile hemangioma: clinical assessment of the involuting phase and implications for management. Plast Reconstr Surg. Sep. 2012;130(3):619-24. [pmid: 22575857].
39 Chen TS, Eichenfield LF, Friedlander SF. Infantile hemangiomas: an update on pathogenesis and therapy. Pediatrics. Jan. 2013;131(1):99-108. [pmid: 23266916].
40 Akyuz C, Yaris N, Kutluk MT, et al. Management of cutaneous hemangiomas: a retrospective analysis of 1109 cases and comparison of conventional dose prednisolone with high-dose methylprednisolone therapy. Pediatr Hematol Oncol. Jan–Feb. 2001;18(1):47-55. [pmid: 11205840].
41 Sundine MJ, Wirth GA. Hemangiomas: an overview. Clin Pediatr (Phila). Apr. 2007;46(3):206-21. [pmid: 17416876].
42 Bowers RE, Graham EA, Tomlinson KM. The natural history of the strawberry nevus. Archives of Dermatology. 1960;82(5):667-80.
43 Liang MG, Frieden IJ. Infantile and congenital hemangiomas. Semin Pediatr Surg. Aug. 2014;23(4):162-7. [pmid: 25241092].
44 Jacobs AH. Strawberry hemangiomas; the natural history of the untreated lesion. Calif Med. Jan. 1957;86(1):8-10. [pmid: 13383382].
45 Bauland CG, Luning TH, Smit JM, et al. Untreated hemangiomas: growth pattern and residual lesions. Plast Reconstr Surg. Apr. 2011;127(4):1643-8. [pmid: 21460670].
46 Enjolras O, Riche MC, Merland JJ, et al. Management of alarming hemangiomas in infancy: a review of 25 cases. Pediatrics. Apr. 1990;85(4):491-8. [pmid: 2097998].
47 Luu M, Frieden IJ. Haemangioma: clinical course, complications and management. Br J Dermatol. Jul. 2013;169(1):20-30. [pmid: 23701395].
48 Maguiness SM, Frieden IJ. Current management of infantile hemangiomas. Semin Cutan Med Surg. Jun. 2010;29(2):106-14. [pmid: 20579599].
49 Frieden IJ, Eichenfield LF, Esterly NB, et al. Guidelines of care for hemangiomas of infancy. American Academy of Dermatology Guidelines/Outcomes Committee. J Am Acad Dermatol. Oct. 1997;37(4):631-7. [pmid: 9344205].
50 Bauland CG, Smit JM, Ketelaars R, et al. Management of haemangiomas of infancy: a retrospective analysis and a treatment protocol. Scand J Plast Reconstr Surg Hand Surg. 2008;42(2):86-91. [pmid: 18335352].
51 Lee AH, Hardy KL, Goltsman D, et al. A retrospective study to classify surgical indications for infantile hemangiomas. J Plast Reconstr Aesthet Surg. Sep. 2014;67(9):1215-21. [pmid: 24923525].
52 Frieden IJ, Haggstrom AN, Drolet BA, et al. Infantile hemangiomas: current knowledge, future directions. Proceedings of a research workshop on infantile hemangiomas, April 7–9, 2005, Bethesda, Maryland, USA. Pediatr Dermatol. Sep–Oct. 2005;22(5):383-406. [pmid: 16190987].
53 Cohen-Barak E, Rozenman D, Shani Adir A. Infantile haemangiomas and quality of life. Arch Dis Child. Sep. 2013;98(9):676-9. [pmid: 23864355].
54 Hoornweg MJ, Grootenhuis MA, van der Horst CM. Health-related quality of life and impact of haemangiomas on children and their parents. J Plast Reconstr Aesthet Surg. Oct. 2009;62(10):1265-71. [pmid: 18602360].
55 Wananukul S. Clinical manifestation and management of hemangiomas of infancy. J Med Assoc Thai. Jun. Suppl 1. 2002;85:S280-5. [pmid: 12188424].
56 Pandey A, Gangopadhyay AN, Sharma SP, et al. Conservative management of ulcerated haemangioma--twenty years experience. Int Wound J. Feb. 2009;6(1):59-62. [pmid: 19291117].
57 Holland KE, Drolet BA. Approach to the patient with an infantile hemangioma. Dermatol Clin. Apr. 2013;31(2):289-301. [pmid: 23557656].
58 Gontijo B. Complications of infantile hemangiomas. Clin Dermatol. Jul–Aug. 2014;32(4):471-6. [pmid: 25017458].
59 Haggstrom AN, Lammer EJ, Schneider RA, et al. Patterns of infantile hemangiomas: new clues to hemangioma pathogenesis and embryonic facial development. Pediatrics. Mar. 2006;117(3):698-703. [pmid: 16510649].
60 Muzaffar F. Clinical profile and morphologic types of infantile hemangioma. A study of 252 children. Journal of Pakistan Association of Dermatologists. 2005;15(2):119-24.
61 Hermans DJ, Boezeman JB, Van de Kerkhof PC, et al. Differences between ulcerated and non-ulcerated hemangiomas, a retrospective study of 465 cases. Eur J Dermatol. Mar–Apr. 2009;19(2):152-6. [pmid: 19106042].
62 Waner M, North PE, Scherer KA, et al. The nonrandom distribution of facial hemangiomas. Arch Dermatol. Jul. 2003;139(7):869-75. [pmid: 12873881].
63 Maguiness SM, Hoffman WY, McCalmont TH, et al. Early white discoloration of infantile hemangioma: a sign of impending ulceration. Arch Dermatol. Nov. 2010;146(11):1235-9. [pmid: 21079059].
64 Bramhall RJ, Quaba A. A review of 58 patients with periorbital haemangiomas to determine appropriate cases for intervention. J Plast Reconstr Aesthet Surg. 2008;61(2):138-49. [pmid: 17981104].
65 Schwartz SR, Blei F, Ceisler E, et al. Risk factors for amblyopia in children with capillary hemangiomas of the eyelids and orbit. J aapos. Jun. 2006;10(3):262-8. [pmid: 16814181].
66 Rahbar R, Nicollas R, Roger G, et al. The biology and management of subglottic hemangioma: past, present, future. Laryngoscope. Nov. 2004;114(11):1880-91. [pmid: 15510009].
67 Orlow SJ, Isakoff MS, Blei F. Increased risk of symptomatic hemangiomas of the airway in association with cutaneous hemangiomas in a “beard” distribution. J Pediatr. Oct. 1997;131(4):643-6. [pmid: 9386676].
68 Drolet BA, Chamlin SL, Garzon MC, et al. Prospective study of spinal anomalies in children with infantile hemangiomas of the lumbosacral skin. J Pediatr. Nov. 2010;157(5):789-94. [pmid: 20828712].
69 Tubbs RS, Wellons JC 3rd, Iskandar BJ, et al. Isolated flat capillary midline lumbosacral hemangiomas as indicators of occult spinal dysraphism. J Neurosurg. Feb. 2004;100(2 Suppl Pediatrics):86-9. [pmid: 14758934].
70 Kassarjian A, Zurakowski D, Dubois J, et al. Infantile hepatic hemangiomas: clinical and imaging findings and their correlation with therapy. AJR Am J Roentgenol. Mar. 2004;182(3):785-95. [pmid: 14975986].
71 Horii KA, Drolet BA, Frieden IJ, et al. Prospective study of the frequency of hepatic hemangiomas in infants with multiple cutaneous infantile hemangiomas. Pediatr Dermatol. May–Jun. 2011;28(3):245-53. [pmid: 21517952].
72 Dickie B, Dasgupta R, Nair R, et al. Spectrum of hepatic hemangiomas: management and outcome. J Pediatr Surg. Jan. 2009;44(1):125-33. [pmid: 19159729].
73 Metry DW, Haggstrom AN, Drolet BA, et al. A prospective study of PHACE syndrome in infantile hemangiomas: demographic features, clinical findings, and complications. Am J Med Genet A. May. 1. 2006;140(9):975-86. [pmid: 16575892].
74 Haggstrom AN, Garzon MC, Baselga E, et al. Risk for PHACE syndrome in infants with large facial hemangiomas. Pediatrics. Aug. 2010;126(2):e418-26. [pmid: 20643720].
75 Metry D, Frieden IJ, Hess C, et al. Propranolol use in PHACE syndrome with cervical and intracranial arterial anomalies: collective experience in 32 infants. Pediatr Dermatol. Jan–Feb. 2013;30(1):71-89. [pmid: 22994362].
76 Fawcett SL, Grant I, Hall PN, et al. Vincristine as a treatment for a large haemangioma threatening vital functions. Br J Plast Surg. Mar. 2004;57(2):168-71. [pmid: 15037175].
77 Puttgen KB. Diagnosis and management of infantile hemangiomas. Pediatr Clin North Am. Apr. 2014;61(2):383-402. [pmid: 24636652].
78 Canty KM, Horii KA, Ahmad H, et al. Multiple cutaneous and hepatic hemangiomas in infants. South Med J. Mar. 2014;107(3):159-64. [pmid: 24937333].
79 Hughes JA, Hill V, Patel K, et al. Cutaneous haemangioma: prevalence and sonographic characteristics of associated hepatic haemangioma. Clin Radiol. Mar. 2004;59(3):273-80. [pmid: 15037141].
80 Mai HM, Zheng JW, Wang YA, et al. CD133 selected stem cells from proliferating infantile hemangioma and establishment of an in vivo mice model of hemangioma. Chin Med J (Engl). Jan. 2013;126(1):88-94. [pmid: 23286484].
81 Boon LM, Burrows PE, Paltiel HJ, et al. Hepatic vascular anomalies in infancy: a twenty-seven-year experience. J Pediatr. Sep. 1996;129(3):346-54. [pmid: 8804322].
82 Vredenborg AD, Janmohamed SR, de Laat PC, et al. Multiple cutaneous infantile haemangiomas and the risk of internal haemangioma. Br J Dermatol. Jul. 2013;169(1):188-91. [pmid: 23421718].
83 Iyer CP, Stanley P, Mahour GH. Hepatic hemangiomas in infants and children: a review of 30 cases. Am Surg. May. 1996;62(5):356-60. [pmid: 8615561].
84 Stanley P, Geer GD, Miller JH, et al. Infantile hepatic hemangiomas. Clinical features, radiologic investigations, and treatment of 20 patients. Cancer. Aug. 15. 1989;64(4):936-49. [pmid: 2663135].
85 Lopriore E, Markhorst DG. Diffuse neonatal haemangiomatosis: new views on diagnostic criteria and prognosis. Acta Paediatr. Jan. 1999;88(1):93-7. [pmid: 10090556].
86 Berman B, Lim H. Concurrent cutaneous and hepatic hemangiomata in infancy: report of a case and a review of the literature. J Dermatol Surg Oncol. Nov. 1978;4(11):869-73. [pmid: 711970].
87 Blei F, Guarini A. Current workup and therapy of infantile hemangiomas. Clin Dermatol. Jul–Aug. 2014;32(4):459-70. [pmid: 25017457].
88 TM O, Alexander RE, Lando T, et al. Segmental hemangiomas of the upper airway. Laryngoscope. Nov. 2009;119(11):2242-7. [pmid: 19806648].
89 TM O, Scheuermann-Poley C, Tan M, et al. Distribution, clinical characteristics, and surgical treatment of lip infantile hemangiomas. JAMA Facial Plast Surg. Jul–Aug. 2013;15(4):292-304. [pmid: 23752875].
90 Sherrington CA, Sim DK, Freezer NJ, et al. Subglottic haemangioma. Arch Dis Child. May. 1997;76(5):458-9. [pmid: 9196368].
91 Vlastarakos PV, Papacharalampous GX, Chrysostomou M, et al. Propranolol is an effective treatment for airway haemangiomas: a critical analysis and meta-analysis of published interventional studies. Acta Otorhinolaryngol Ital. Aug. 2012;32(4):213-21. [pmid: 23093810].
92 Léauté-Labrèze C, Hoeger P, Mazereeuw-Hautier J, et al. A randomized, controlled trial of oral propranolol in infantile hemangioma. N Engl J Med. 2015;372(8):735-46. [pmid: 25693013].
93 Zaher H, Rasheed H, Esmat S, et al. Propranolol and infantile hemangiomas: different routes of administration, a randomized clinical trial. Eur J Dermatol. Sep–Oct. 2013;23(5):646-52. [pmid: 24135427].
94 Sondhi V, Patnaik SK. Propranolol for infantile hemangioma (PINCH): an open-label trial to assess the efficacy of propranolol for treating infantile hemangiomas and for determining the decline in heart rate to predict response to propranolol. J Pediatr Hematol Oncol. Oct. 2013;35(7):493-9. [pmid: 23929318].
95 Thayal PK, Bhandari PS, Sarin YK. Comparison of efficacy of intralesional bleomycin and oral propanolol in management of hemangiomas. Plast Reconstr Surg. Apr. 2012;129(4):733e-5e. [pmid: 22456397].
96 Bertrand J, McCuaig C, Dubois J, et al. Propranolol versus prednisone in the treatment of infantile hemangiomas: a retrospective comparative study. Pediatr Dermatol. Nov–Dec. 2011;28(6):649-54. [pmid: 21995756].
97 Price CJ, Lattouf C, Baum B, et al. Propranolol vs corticosteroids for infantile hemangiomas: a multicenter retrospective analysis. Arch Dermatol. Dec. 2011;147(12):1371-6. [pmid: 21844428].
98 Bauman NM, McCarter RJ, Guzzetta PC, et al. Propranolol vs prednisolone for symptomatic proliferating infantile hemangiomas: a randomized clinical trial. JAMA Otolaryngol Head Neck Surg. Apr. 2014;140(4):323-30. [pmid: 24526257].
99 Leaute-Labreze C, Dumas de la Roque E, Nacka F, et al. Double-blind randomized pilot trial evaluating the efficacy of oral propranolol on infantile haemangiomas in infants < 4 months of age. Br J Dermatol. Jul. 2013;169(1):181-3. [pmid: 23301692].
100 Malik MA, Menon P, Rao KL, et al. Effect of propranolol vs prednisolone vs propranolol with prednisolone in the management of infantile hemangioma: a randomized controlled study. J Pediatr Surg. Dec. 2013;48(12):2453-9. [pmid: 24314186].
101 Pope E, Chakkittakandiyil A, Lara-Corrales I, et al. Expanding the therapeutic repertoire of infantile haemangiomas: cohort-blinded study of oral nadolol compared with propranolol. Br J Dermatol. Jan. 2013;168(1):222-4. [pmid: 22762503].
102 Abarzua-Araya A, Navarrete-Dechent CP, Heusser F, et al. Atenolol versus propranolol for the treatment of infantile hemangiomas: a randomized controlled study. J Am Acad Dermatol. Jun. 2014;70(6):1045-9. [pmid: 24656727].
103 Yu L, Li S, Su B, et al. Treatment of superficial infantile hemangiomas with timolol: Evaluation of short-term efficacy and safety in infants. Exp Ther Med. August. 2013;6(2):388-90. [pmid: 24137194].
104 Chan H, McKay C, Adams S, et al. RCT of timolol maleate gel for superficial infantile hemangiomas in 5- to 24-week-olds. Pediatrics. Jun. 2013;131(6):e1739-47. [pmid: 23650294].
105 Qiu Y, Ma G, Yang J, et al. Imiquimod 5% cream versus timolol 0.5% ophthalmic solution for treating superficial proliferating infantile haemangiomas: a retrospective study. Clin Exp Dermatol. Dec. 2013;38(8):845-50. [pmid: 23627540].
106 Park KH, Jang YH, Chung HY, et al. Topical timolol maleate 0.5% for infantile hemangioma; it’s effectiveness and/or adjunctive pulsed dye laser - single center experience of 102 cases in Korea. J Dermatolog Treat. Dec. 29. 2014:1-3. [pmid: 24328994].
107 Pope E, Krafchik BR, Macarthur C, et al. Oral versus high-dose pulse corticosteroids for problematic infantile hemangiomas: a randomized, controlled trial. Pediatrics. Jun. 2007;119(6):e1239-47. [pmid: 17485449].
108 Jalil S, Akhtar J, Ahmed S. Corticosteroids therapy in the management of infantile cutaneous hemangiomas. J Coll Physicians Surg Pak. Oct. 2006;16(10):662-5. [pmid: 17007757].
109 Gangopadhyay AN, Sharma SP, Gopal SC, et al. Local steroid therapy in cutaneous hemangiomas. Indian Pediatr. Jan. 1996;33(1):31-3. [pmid: 8772948].
110 Chowdri NA, Darzi MA, Fazili Z, et al. Intralesional corticosteroid therapy for childhood cutaneous hemangiomas. Ann Plast Surg. Jul. 1994;33(1):46-51. [pmid: 7944196].
111 Morrell AJ, Willshaw HE. Normalisation of refractive error after steroid injection for adnexal haemangiomas. Br J Ophthalmol. May. 1991;75(5):301-5. [pmid: 2036349].
112 Sloan GM, Reinisch JF, Nichter LS, et al. Intralesional corticosteroid therapy for infantile hemangiomas. Plast Reconstr Surg. Mar. 1989;83(3):459-67. [pmid: 2919200].
113 Greene AK, Couto RA. Oral prednisolone for infantile hemangioma: efficacy and safety using a standardized treatment protocol. Plast Reconstr Surg. Sep. 2011;128(3):743-52. [pmid: 21572374].
114 Chantharatanapiboon W. Intralesional corticosteroid therapy in hemangiomas: clinical outcome in 160 cases. J Med Assoc Thai. Oct. Suppl 3. 2008;91:S90-6. [pmid: 19253502].
115 Chen MT, Yeong EK, Horng SY. Intralesional corticosteroid therapy in proliferating head and neck hemangiomas: a review of 155 cases. J Pediatr Surg. Mar. 2000;35(3):420-3. [pmid: 10726680].
116 Boon LM, MacDonald DM, Mulliken JB. Complications of systemic corticosteroid therapy for problematic hemangioma. Plast Reconstr Surg. Nov. 1999;104(6):1616-23. [pmid: 10541160].
117 Sadan N, Wolach B. Treatment of hemangiomas of infants with high doses of prednisone. J Pediatr. Jan. 1996;128(1):141-6. [pmid: 8551406].
118 Kushner BJ. The treatment of periorbital infantile hemangioma with intralesional corticosteroid. Plast Reconstr Surg. Oct. 1985;76(4):517-26. [pmid: 4034770].
119 Sharma LK, Dalal SS. Corticosteroid therapy in the treatment of cutaneous hemangioma of infancy and childhood. Indian J Pediatr. Mar–Apr. 1983;50(403):153-6. [pmid: 6618575].
120 Pandey A, Gangopadhyay AN, Gopal SC, et al. Twenty years’ experience of steroids in infantile hemangioma--a developing country’s perspective. J Pediatr Surg. Apr. 2009;44(4):688-94. [pmid: 19361627].
121 Janmohamed SR, Madern GC, Nieuwenhuis K, et al. Evaluation of intra-lesional corticosteroids in the treatment of periocular haemangioma of infancy: still an alternative besides propranolol. Pediatr Surg Int. Apr. 2012;28(4):393-8. [pmid: 22200732].
122 Pandey A, Gangopadhyay AN, Sharma SP, et al. Evaluation of topical steroids in the treatment of superficial hemangioma. Skinmed. Jan–Feb. 2010;8(1):9-11. [pmid: 20839418].
123 Couto JA, Greene AK. Management of problematic infantile hemangioma using intralesional triamcinolone: efficacy and safety in 100 infants. J Plast Reconstr Aesthet Surg. Nov. 2014;67(11):1469-74. [pmid: 25104131].
124 Ke Y, Hao R, He Y, et al. The value of color Doppler imaging and intralesional steroid injection in pediatric orbital capillary hemangioma. J Chin Med Assoc. May. 2014;77(5):258-64. [pmid: 24694673].
125 Saleh KH. Steroids in complicated hemangioma. Iranian Red Crescent Medical Journal. 2009;11(2):217.
126 Kushner BJ. Infantile orbital hemangiomas. International Pediatrics. 1990;5(3):249-57.
127 Garzon MC, Lucky AW, Hawrot A, et al. Ultrapotent topical corticosteroid treatment of hemangiomas of infancy. J Am Acad Dermatol. Feb. 2005;52(2):281-6. [pmid: 15692474].
128 Samimi DB, Alabiad CR, Tse DT. An anatomically based approach to intralesional corticosteroid injection for eyelid capillary hemangiomas. Ophthalmic Surg Lasers Imaging. May–Jun. 2012;43(3):190-5. [pmid: 22432604].
129 Blei F, Chianese J. Corticosteroid toxicity in infants treated for endangering hemangiomas: experience and guidelines for monitoring. International Pediatrics. 1999;14:146-53.
130 Awadein A, Fakhry MA. Evaluation of intralesional propranolol for periocular capillary hemangioma. Clin Ophthalmol. 2011;5(1):1135-40. [pmid: 21887095].
131 Hoornweg MJ, Saeed P, Tanck MW, et al. Comparison of intralesional corticosteroid and propranolol treatment of periorbital infantile hemangiomas: an outcome study of 61 cases. Eur J Ophthalmol. Nov–Dec. 2014;24(6):940-7. [pmid: 24729139].
132 Rossler J, Schill T, Bahr A, et al. Propranolol for proliferating infantile haemangioma is superior to corticosteroid therapy--a retrospective, single centre study. J Eur Acad Dermatol Venereol. Sep. 2012;26(9):1173-5. [pmid: 22035186].
133 Rossler J, Wehl G, Niemeyer CM. Evaluating systemic prednisone therapy for proliferating haemangioma in infancy. Eur J Pediatr. Jul. 2008;167(7):813-5. [pmid: 17676341].
134 Flo-Pred [package insert]. Hawthorne, NY. Taro Pharmaceuticals U.S.A., Inc. 2011.
135 Orapred ODT [package insert]. Bridgetown, Barbados. Concordia Pharmaceuticals Inc. 2013.
136 Rayos [package insert]. Deerfield, IL. Horizon Pharma Inc. 2014.
137 Depo-Medrol [package insert]. New York, NY. Pharmacia and Upjohn Co. 2014.
138 Solu-Medrol [package insert]. New York, NY. Pharmacia & Upjohn Co. 2014.
139 Celestone Soluspan [package insert]. Whitehouse Station, NJ. Merck Sharp Dohme. 2015.
140 Medrol [package insert]. New York, NY. Pharmacia and Upjohn Company. 2013.
141 Aristospan [package insert]. Princeton, NJ. Sandoz Inc. 2014.
142 Kenalog-10 [package insert]. Princeton, NJ. Bristol-Myers Squibb Company. 2014.
143 Elocon [package insert]. Whitehouse Station, NJ. Merck Sharp & Dohme Corp. 2012.
144 Chambers CB, Katowitz WR, Katowitz JA, et al. A controlled study of topical 0.25% timolol maleate gel for the treatment of cutaneous infantile capillary hemangiomas. Ophthal Plast Reconstr Surg. Mar–Apr. 2012;28(2):103-6. [pmid: 22410658].
145 Hermans DJ, van Beynum IM, Schultze Kool LJ, et al. Propranolol, a very promising treatment for ulceration in infantile hemangiomas: a study of 20 cases with matched historical controls. J Am Acad Dermatol. May. 2011;64(5):833-8. [pmid: 21353329].
146 de Graaf M, Raphael MF, Breugem CC, et al. Treatment of infantile haemangiomas with atenolol: comparison with a historical propranolol group. J Plast Reconstr Aesthet Surg. Dec. 2013;66(12):1732-40. [pmid: 24011909].
147 De Graaf M, Araphael M, Breugem C, et al. Treatment of infantile hemangiomas with atenolol or propranolol: Cohort study with historical control group. European Journal of Pediatric Dermatology. March. 2012;22(1):12.
148 de Graaf M, Breur JM, Raphael MF, et al. Adverse effects of propranolol when used in the treatment of hemangiomas: a case series of 28 infants. J Am Acad Dermatol. Aug. 2011;65(2):320-7. [pmid: 21601311].
149 Perkins JA, Chen BS, Saltzman B, et al. Propranolol therapy for reducing the number of nasal infantile hemangioma invasive procedures. JAMA Otolaryngol Head Neck Surg. Mar. 2014;140(3):220-7. [pmid: 24557492].
150 Reddy KK, Blei F, Brauer JA, et al. Retrospective study of the treatment of infantile hemangiomas using a combination of propranolol and pulsed dye laser. Dermatol Surg. Jun. 2013;39(6):923-33. [pmid: 23458381].
151 Xiao Q, Li Q, Zhang B, et al. Propranolol therapy of infantile hemangiomas: efficacy, adverse effects, and recurrence. Pediatr Surg Int. Jun. 2013;29(6):575-81. [pmid: 23519547].
152 Hassan BA, Shreef KS. Propranolol in treatment of huge and complicated infantile hemangiomas in egyptian children. Dermatol Res Pract. 2014;2014(541810).
153 Szychta P, Stewart K, Anderson W. Treatment of infantile hemangiomas with propranolol: clinical guidelines. Plast Reconstr Surg. Apr. 2014;133(4):852-62. [pmid: 24352207].
154 Vercellino N, Romanini MV, Pelegrini M, et al. The use of propranolol for complicated infantile hemangiomas. Int J Dermatol. Sep. 2013;52(9):1140-6. [pmid: 23829783].
155 Yuan WL, Jin ZL, Wei JJ, et al. Propranolol given orally for proliferating infantile haemangiomas: analysis of efficacy and serological changes in vascular endothelial growth factor and endothelial nitric oxide synthase in 35 patients. Br J Oral Maxillofac Surg. Oct. 2013;51(7):656-61. [pmid: 23291092].
156 Talaat AA, Elbasiouny MS, Elgendy DS, et al. Propranolol treatment of infantile hemangioma: clinical and radiologic evaluations. J Pediatr Surg. Apr. 2012;47(4):707-14. [pmid: 22498385].
157 Zaher H, Rasheed H, Hegazy RA, et al. Oral propranolol: an effective, safe treatment for infantile hemangiomas. Eur J Dermatol. Jul–Aug. 2011;21(4):558-63. [pmid: 21697036].
158 Holmes WJ, Mishra A, Gorst C, et al. Propranolol as first-line treatment for rapidly proliferating infantile haemangiomas. J Plast Reconstr Aesthet Surg. Apr. 2011;64(4):445-51. [pmid: 20797926].
159 Semkova K, Kazandjieva J. Topical timolol maleate for treatment of infantile haemangiomas: preliminary results of a prospective study. Clin Exp Dermatol. Mar. 2013;38(2):143-6. [pmid: 22731954].
160 Bonifazi E, Milano A, Colonna V. Evaluation of safety and efficacy of a galenic preparation of 1% propranolol in 89 cases of cutaneous infantile hemangioma. European Journal of Pediatric Dermatology. April–June. 2013;23(2):93-104.
161 Chakkittakandiyil A, Phillips R, Frieden IJ, et al. Timolol maleate 0.5% or 0.1% gel-forming solution for infantile hemangiomas: a retrospective, multicenter, cohort study. Pediatr Dermatol. Jan–Feb. 2012;29(1):28-31. [pmid: 22150436].
162 Snir M, Reich U, Siegel R, et al. Refractive and structural changes in infantile periocular capillary haemangioma treated with propranolol. Eye (Lond). Dec. 2011;25(12):1627-34. [pmid: 21921959].
163 Jian D, Chen X, Babajee K, et al. Adverse effects of propranolol treatment for infantile hemangiomas in China. J Dermatolog Treat. Oct. 2014;25(5):388-90. [pmid: 23216314].
164 Bertrand J, Sammour R, McCuaig C, et al. Propranolol in the treatment of problematic infantile hemangioma: review of 35 consecutive patients from a vascular anomalies clinic. J Cutan Med Surg. Sep–Oct. 2012;16(5):317-23. [pmid: 22971306].
165 Zvulunov A, McCuaig C, Frieden IJ, et al. Oral propranolol therapy for infantile hemangiomas beyond the proliferation phase: a multicenter retrospective study. Pediatr Dermatol. Mar–Apr. 2011;28(2):94-8. [pmid: 21362031].
166 Saint-Jean M, Leaute-Labreze C, Mazereeuw-Hautier J, et al. Propranolol for treatment of ulcerated infantile hemangiomas. J Am Acad Dermatol. May. 2011;64(5):827-32. [pmid: 21353332].
167 Schiestl C, Neuhaus K, Zoller S, et al. Efficacy and safety of propranolol as first-line treatment for infantile hemangiomas. Eur J Pediatr. Apr. 2011;170(4):493-501. [pmid: 20936416].
168 Puttgen KB, Summerer B, Schneider J, et al. Cardiovascular and blood glucose parameters in infants during propranolol initiation for treatment of symptomatic infantile hemangiomas. Ann Otol Rhinol Laryngol. Sep. 2013;122(9):550-4. [pmid: 24224397].
169 Liu LS, Sokoloff D, Antaya RJ. Twenty-four-hour hospitalization for patients initiating systemic propranolol therapy for infantile hemangiomas--is it indicated?. Pediatr Dermatol. Sep–Oct. 2013;30(5):554-60. [pmid: 23829941].
170 Hong P, Tammareddi N, Walvekar R, et al. Successful discontinuation of propranolol for infantile hemangiomas of the head and neck at 12 months of age. Int J Pediatr Otorhinolaryngol. Jul. 2013;77(7):1194-7. [pmid: 23706952].
171 Ma X, Zhao T, Xiao Y, et al. Preliminary experience on treatment of infantile hemangioma with low-dose propranolol in China. Eur J Pediatr. May. 2013;172(5):653-9. [pmid: 23340697].
172 Hermans DJ, Bauland CG, Zweegers J, et al. Propranolol in a case series of 174 patients with complicated infantile haemangioma: indications, safety and future directions. Br J Dermatol. Apr. 2013;168(4):837-43. [pmid: 23278381].
173 Park YW, Yeom KB, Choi JW, et al. Effect of propranolol on the treatment of infantile hemangiomas: a single tertiary center 3-year experience. J Dermatolog Treat. Oct. 2014;25(5):391-5. [pmid: 23273264].
174 Gan LQ, Ni SL, Tan Q, et al. A retrospective study of propranolol therapy in 109 infants with infantile hemangioma. Pediatr Dermatol. Mar–Apr. 2013;30(2):270-2. [pmid: 23252446].
175 Phillips RJ, Penington AJ, Bekhor PS, et al. Use of propranolol for treatment of infantile haemangiomas in an outpatient setting. J Paediatr Child Health. Oct. 2012;48(10):902-6. [pmid: 22897120].
176 Zegpi-Trueba MS, Abarzua-Araya A, Silva-Valenzuela S, et al. Oral propranolol for treating infantile hemangiomas: a case series of 57 patients. Actas Dermosifiliogr. Oct. 2012;103(8):708-17. [pmid: 22853960].
177 Celik A, Tiryaki S, Musayev A, et al. Propranolol as the first-line therapy for infantile hemangiomas: preliminary results of two centers. J Drugs Dermatol. Jul. 2012;11(7):808-11. [pmid: 22777220].
178 Balma-Mena A, Chakkittakandiyil A, Weinstein M, et al. Propranolol in the management of infantile hemangiomas: clinical response and predictors. J Cutan Med Surg. May–Jun. 2012;16(3):169-73. [pmid: 22713439].
179 Lv MM, Fan XD, Su LX. Propranolol for problematic head and neck hemangiomas: an analysis of 37 consecutive patients. Int J Pediatr Otorhinolaryngol. Apr. 2012;76(4):574-8. [pmid: 22326207].
180 Schupp CJ, Kleber JB, Gunther P, et al. Propranolol therapy in 55 infants with infantile hemangioma: dosage, duration, adverse effects, and outcome. Pediatr Dermatol. Nov–Dec. 2011;28(6):640-4. [pmid: 21995836].
181 Fuchsmann C, Quintal MC, Giguere C, et al. Propranolol as first-line treatment of head and neck hemangiomas. Arch Otolaryngol Head Neck Surg. May. 2011;137(5):471-8. [pmid: 21576558].
182 Cushing SL, Boucek RJ, Manning SC, et al. Initial experience with a multidisciplinary strategy for initiation of propranolol therapy for infantile hemangiomas. Otolaryngol Head Neck Surg. Jan. 2011;144(1):78-84. [pmid: 21493392].
183 Sadykov RR, Podmelle F, Sadykov RA, et al. Use of propranolol for the treatment infantile hemangiomas in the maxillofacial region. Int J Oral Maxillofac Surg. Jul. 2013;42(7):863-7. [pmid: 23618833].
184 Bagazgoitia L, Torrelo A, Gutierrez JC, et al. Propranolol for infantile hemangiomas. Pediatr Dermatol. Mar–Apr. 2011;28(2):108-14. [pmid: 21385205].
185 Blatt J, Morrell DS, Buck S, et al. beta-blockers for infantile hemangiomas: a single-institution experience. Clin Pediatr (Phila). Aug. 2011;50(8):757-63. [pmid: 21525081].
186 Xu G, Lv R, Zhao Z, et al. Topical propranolol for treatment of superficial infantile hemangiomas. J Am Acad Dermatol. Dec. 2012;67(6):1210-3. [pmid: 22516113].
187 Kunzi-Rapp K. Topical propranolol therapy for infantile hemangiomas. Pediatr Dermatol. Mar–Apr. 2012;29(2):154-9. [pmid: 22141326].
188 Raphael MF, Breugem CC, Vlasveld FA, et al. Is cardiovascular evaluation necessary prior to and during beta-blocker therapy for infantile hemangiomas?: A cohort study. J Am Acad Dermatol. Mar. 2015;72(3):465-72. [pmid: 25592625].
189 Xu DP, Cao RY, Xue L, et al. Treatment of severe infantile hemangiomas with propranolol: an evaluation of the efficacy and effects of cardiovascular parameters in 25 consecutive patients. J Oral Maxillofac Surg. Mar. 2015;73(3):430-6. [pmid: 25544304].
190 Solman L, Murabit A, Gnarra M, et al. Propranolol for infantile haemangiomas: single centre experience of 250 cases and proposed therapeutic protocol. Arch Dis Child. Dec. 2014;99(12):1132-6. [pmid: 25123404].
191 El Ezzi O, Hohlfeld J, de Buys Roessingh A. Propranolol in infantile haemangioma: simplifying pretreatment monitoring. Swiss Med Wkly. 2014;144:w13943. [pmid: 24610228].
192 Sagi L, Zvulunov A, Lapidoth M, et al. Efficacy and safety of propranolol for the treatment of infantile hemangioma: a presentation of ninety-nine cases. Dermatology. 2014;228(2):136-44. [pmid: 24556822].
193 Andersen IG, Rechnitzer C, Charabi B. Effectiveness of propanolol for treatment of infantile haemangioma. Dan Med J. Feb. 2014;61(2):A4776. [pmid: 24495884].
194 Lynch M, Lenane P, O’Donnell BF. Propranolol for the treatment of infantile haemangiomas: our experience with 44 patients. Clin Exp Dermatol. Mar. 2014;39(2):142-5. [pmid: 24289272].
195 Giachetti A, Garcia-Monaco R, Sojo M, et al. Long-term treatment with oral propranolol reduces relapses of infantile hemangiomas. Pediatr Dermatol. Jan–Feb. 2014;31(1):14-20. [pmid: 24283619].
196 May JE, Liew SH. A new treatment pathway for propranolol use in infantile haemangiomas. J Plast Reconstr Aesthet Surg. Mar. 2014;67(3):e91-2. [pmid: 24268691].
197 Wang L, Xia Y, Zhai Y, et al. Topical propranolol hydrochloride gel for superficial infantile hemangiomas. J Huazhong Univ Sci Technolog Med Sci. Dec. 2012;32(6):923-6. [pmid: 23271298].
198 Chen ZG, Zheng JW, Yuan ML, et al. A novel topical nano-propranolol for treatment of infantile hemangiomas. Nanomedicine. 2015. Mar. 16. [pmid: 25791814].
199 Chu DH, Castelo-Soccio L, Wan J, et al. Retrospective analysis of beta-blocker instituted for treatment of hemangiomas (RABBIT study). Clin Pediatr (Phila). Oct. 2014;53(11):1084-90. [pmid: 24849505].
200 Schneider M, Cremer HJ, Ruef P. A retrospective analysis of systemic propranolol for the treatment of complicated infantile haemangiomas. Acta Paediatr. Sep. 2014;103(9):977-83. [pmid: 24837972].
201 Chai Q, Chen WL, Huang ZQ, et al. Preliminary experiences in treating infantile hemangioma with propranolol. Ann Plast Surg. Feb. 2014;72(2):169-72. [pmid: 21629056].
202 Muzaffar F, Shah GN. Propranolol for the treatment of infantile hemangioma: Our experience at The Children’s Hospital, Lahore. Journal of Pakistan Association of Dermatologists. 2014;24(4):312-8.
203 Martinez Roca C, Rodriguez Ruiz M, Vilaboa Pedrosa C, et al. Oral propranolol in the treatment of infantile hemangioma: A case series of 50 infants. European Journal of Pediatric Dermatology. April–June. 2014;24(2):86-90.
204 Schneider M, Reimer A, Cremer H, et al. Topical treatment with propranolol gel as a supplement to the existing treatment of hemangiomas. World J Pediatr. Nov. 2014;10(4):313-7. [pmid: 25515804].
205 Manunza F, Syed S, Laguda B, et al. Propranolol for complicated infantile haemangiomas: a case series of 30 infants. Br J Dermatol. Feb. 1. 2010;162(2):466-8. [pmid: 20055816].
206 Hemangeol [package insert]. Parsippany, NJ. Pierre Fabre Pharmaceuticals, Inc. 2014.
207 Propranolol Hydrochloride Solution [package insert]. Columbus, OH. Roxane Laboratories, Inc. 2012.
208 Inderal LA [package insert]. Cranford, NJ. Akrimax Pharmaceuticals, LLC. 2012.
209 Propranolol Hydrochloride Tablet [package insert]. Eatontown, NJ. Heritage Pharmaceuticals Inc. 2013.
210 Kessels JP, Hamers ET, Ostertag JU. Superficial hemangioma: pulsed dye laser versus wait-and-see. Dermatol Surg. Mar. 2013;39(3 Pt 1):414-21. [pmid: 23279058].
211 Kono T, Sakurai H, Groff WF, et al. Comparison study of a traditional pulsed dye laser versus a long-pulsed dye laser in the treatment of early childhood hemangiomas. Lasers Surg Med. Feb. 2006;38(2):112-5. [pmid: 16374781].
212 Batta K, Goodyear HM, Moss C, et al. Randomised controlled study of early pulsed dye laser treatment of uncomplicated childhood haemangiomas: results of a 1-year analysis. Lancet. Aug. 17. 2002;360(9332):521-7. [pmid: 12241656].
213 Tay YK, Tan SK. Treatment of infantile hemangiomas with the 595-nm pulsed dye laser using different pulse widths in an Asian population. Lasers Surg Med. Feb. 2012;44(2):93-6. [pmid: 22241650].
214 Nicolai T, Fischer-Truestedt C, Reiter K, et al. Subglottic hemangioma: a comparison of CO2 laser, Neodym-Yag laser, and tracheostomy. Pediatr Pulmonol. Mar. 2005;39(3):233-7. [pmid: 15635618].
215 Raulin C, Greve B. Retrospective clinical comparison of hemangioma treatment by flashlamp-pumped (585 nm) and frequency-doubled Nd:YAG (532 nm) lasers. Lasers Surg Med. 2001;28(1):40-3. [pmid: 11430441].
216 Chang CJ, Kelly KM, Nelson JS. Cryogen spray cooling and pulsed dye laser treatment of cutaneous hemangiomas. Ann Plast Surg. Jun. 2001;46(6):577-83. [pmid: 11405354].
217 Achauer BM, Vander Kam VM. Capillary hemangioma (strawberry mark) of infancy: comparison of argon and Nd:YAG laser treatment. Plast Reconstr Surg. Jul. 1989;84(1):60-9. discussion 70. [pmid: 2734405].
218 Vlachakis I, Arbiros I, Velaoras K, et al. Different modes cooling the epidermis with ice during Nd:YAG laser treatment of hemangiomas in children. Med Laser Appl. May. 2004;19(1):19-23.
219 Ryzhevskiy DV, Trubin VV, Durnovo EA. The use of selective photothermolysis with sclerosing to treat congenital and neonatal vascular maxillofacial hyperplasia in children. Sovremennye Tehnologii v Medicine. 2014;6(4):145-9.
220 Goelz R, Moll M, Meisner C, et al. Prospective controlled study to evaluate cryocontact therapy for infantile haemangioma in preterm infants. Arch Dis Child Fetal Neonatal Ed. Jul. 2014;99(4):F345-6. [pmid: 24668831].
221 Li DN, Gold MH, Sun ZS, et al. Treatment of infantile hemangioma with optimal pulse technology. J Cosmet Laser Ther. Jun. 2010;12(3):145-50. [pmid: 20482239].
222 David LR, Malek MM, Argenta LC. Efficacy of pulse dye laser therapy for the treatment of ulcerated haemangiomas: a review of 78 patients. Br J Plast Surg. Jun. 2003;56(4):317-27. [pmid: 12873458].
223 Kwon SH, Choi JW, Byun SY, et al. Effect of early long-pulse pulsed dye laser treatment in infantile hemangiomas. Dermatol Surg. Apr. 2014;40(4):405-11. [pmid: 24460784].
224 Rizzo C, Brightman L, Chapas AM, et al. Outcomes of childhood hemangiomas treated with the pulsed-dye laser with dynamic cooling: a retrospective chart analysis. Dermatol Surg. Dec. 2009;35(12):1947-54. [pmid: 19889007].
225 Poetke M, Philipp C, Berlien HP. Flashlamp-pumped pulsed dye laser for hemangiomas in infancy: treatment of superficial vs mixed hemangiomas. Arch Dermatol. May. 2000;136(5):628-32. [pmid: 10815856].
226 Morelli JG, Tan OT, Yohn JJ, et al. Treatment of ulcerated hemangiomas infancy. Arch Pediatr Adolesc Med. Oct. 1994;148(10):1104-5. [pmid: 7921107].
227 Di Maio L, Baldi A, Dimaio V, et al. Use of flashlamp-pumped pulsed dye laser in the treatment of superficial vascular malformations and ulcerated hemangiomas. In Vivo. Jan–Feb. 2011;25(1):117-23. [pmid: 21282744].
228 Chen W, Liu S, Yang C, et al. Clinical efficacy of the 595 nm pulsed dye laser in the treatment of childhood superficial hemangioma - analysis of 10-year application in Chinese patients. J Dermatolog Treat. Feb. 2015;26(1):54-8. [pmid: 23697537].
229 Hohenleutner S, Badur-Ganter E, Landthaler M, et al. Long-term results in the treatment of childhood hemangioma with the flashlamp-pumped pulsed dye laser: an evaluation of 617 cases. Lasers Surg Med. 2001;28(3):273-7. [pmid: 11295764].
230 Chen W, Yang C, Liu S, et al. Curative effect study of pulsed dye laser in the treatment of 43 patients with hand infantile hemangioma. Eur J Dermatol. Jan–Feb. 2014;24(1):76-9. [pmid: 24413474].
231 Preeyanont P, Nimsakul N. The Nd:YAG laser treatment of hemangioma. J Clin Laser Med Surg. Aug. 1994;12(4):225-9. [pmid: 10147482].
232 Chang CJ. Long term follow-up of intralesional laser photocoagulation (ILP) for hemangioma patients. Laser Therapy. 2011;20(4):255-63. [pmid: 24155535].
233 Waldschmidt J, Giest H, Meyer L. Endoscopic laser application in 56 children with hemangiomas of the larynx and trachea. Med Laser Appl. 08. Dec. 2005;20(4):297-302.
234 Vlachakis I, Gardikis S, Michailoudi E, et al. Treatment of hemangiomas in children using a Nd:YAG laser in conjunction with ice cooling of the epidermis: techniques and results. BMC Pediatr. Apr. 12. 2003;3:2. [pmid: 12697072].
235 Kaune KM, Lauerer P, Kietz S, et al. Combination therapy of infantile hemangiomas with pulsed dye laser and Nd:YAG laser is effective and safe. J Dtsch Dermatol Ges. Jun. 2014;12(6):473-8. [pmid: 24825388].
236 Su W, Ke Y, Xue J. Beneficial effects of early treatment of infantile hemangiomas with a long-pulse Alexandrite laser. Lasers Surg Med. Mar. 2014;46(3):173-9. [pmid: 24391080].
237 Healy G, McGill T, Friedman EM. Carbon dioxide laser in subglottic hemangioma. An update. Ann Otol Rhinol Laryngol. Jul–Aug. 1984;93(4 Pt 1):370-3. [pmid: 6431866].
238 Wu JK, Rohde CH. Purse-string closure of hemangiomas: early results of a follow-up study. Ann Plast Surg. May. 2009;62(5):581-5. [pmid: 19387166].
239 Chen W, Li J, Yang Z, et al. SMAS fold flap and ADM repair of the parotid bed following removal of parotid haemangiomas via pre- and retroauricular incisions to improve cosmetic outcome and prevent Frey’s syndrome. J Plast Reconstr Aesthet Surg. Aug. 2008;61(8):894-9. discussion 9–900. [pmid: 18504166].
240 Li WY, Chaudhry O, Reinisch JF. Guide to early surgical management of lip hemangiomas based on our experience of 214 cases. Plast Reconstr Surg. Nov. 2011;128(5):1117-24. [pmid: 21738083].
241 Kulbersh J, Hochman M. Serial excision of facial hemangiomas. Arch Facial Plast Surg. May–Jun. 2011;13(3):199-202. [pmid: 21576667].
242 Arneja JS, Mulliken JB. Resection of amblyogenic periocular hemangiomas: indications and outcomes. Plast Reconstr Surg. Jan. 2010;125(1):274-81. [pmid: 20048618].
243 Hamou C, Diner PA, Dalmonte P, et al. Nasal tip haemangiomas: guidelines for an early surgical approach. J Plast Reconstr Aesthet Surg. Jun. 2010;63(6):934-9. [pmid: 19540825].
244 Chen WL, Zhang B, Li JS, et al. Liquid nitrogen cryotherapy of lip mucosa hemangiomas under inhalation general anesthesia with sevoflurane in early infancy. Ann Plast Surg. Feb. 2009;62(2):154-7. [pmid: 19158525].
245 Claude O, Picard A, O’Sullivan N, et al. Use of ultrasonic dissection in the early surgical management of periorbital haemangiomas. J Plast Reconstr Aesthet Surg. Dec. 2008;61(12):1479-85. [pmid: 18037085].
246 McHeik JN, Renauld V, Duport G, et al. Surgical treatment of haemangioma in infants. Br J Plast Surg. Dec. 2005;58(8):1067-72. [pmid: 16039624].
247 Demiri EC, Pelissier P, Genin-Etcheberry T, et al. Treatment of facial haemangiomas: the present status of surgery. Br J Plast Surg. Dec. 2001;54(8):665-74. [pmid: 11728108].
248 Zide BM, Glat PM, Stile FL, et al. Vascular lip enlargement: Part I. Hemangiomas--tenets of therapy. Plast Reconstr Surg. Dec. 1997;100(7):1664-73. [pmid: 9393462].
249 Baraldini V, Coletti M, Cigognetti F, et al. Haemostatic squeezing and purse-string sutures: optimising surgical techniques for early excision of critical infantile haemangiomas. J Pediatr Surg. Feb. 2007;42(2):381-5. [pmid: 17270553].
250 Batta K, Goodyear H, Moss C, et al. Randomized controlled study of early pulsed dye laser treatment of uncomplicated infantile haemangiomas: results of a 5-year analysis. British Journal of Dermatology. 2008;159(Suppl 1):113. [pmid: 18510676].
251 Daramola OO, Chun RH, Nash JJ, et al. Surgical treatment of infantile hemangioma in a multidisciplinary vascular anomalies clinic. Int J Pediatr Otorhinolaryngol. Oct. 2011;75(10):1271-4. [pmid: 21803434].
252 Murphy RK, Reynolds MR, Mansur DB, et al. Gamma knife surgery for a hemangioma of the cavernous sinus in a child. J Neurosurg Pediatr. Jan. 2013;11(1):74-8. [pmid: 23082966].
253 Xu SQ, Jia RB, Zhang W, et al. Beta-blockers versus corticosteroids in the treatment of infantile hemangioma: an evidence-based systematic review. World J Pediatr. Aug. 2013;9(3):221-9. [pmid: 23929254].
254 Izadpanah A, Izadpanah A, Kanevsky J, et al. Propranolol versus corticosteroids in the treatment of infantile hemangioma: a systematic review and meta-analysis. Plast Reconstr Surg. Mar. 2013;131(3):601-13. [pmid: 23142941].
255 Wat H, Wu DC, Rao J, et al. Application of intense pulsed light in the treatment of dermatologic disease: a systematic review. Dermatol Surg. Apr. 2014;40(4):359-77. [pmid: 24495252].
256 Prasetyono TO, Djoenaedi I. Efficacy of intralesional steroid injection in head and neck hemangioma: a systematic review. Ann Plast Surg. Jan. 2011;66(1):98-106. [pmid: 21042190].
257 Leonardi-Bee J, Batta K, O’Brien C, et al. Interventions for infantile haemangiomas (strawberry birthmarks) of the skin. Cochrane Database Syst Rev. 2011;(5).
258 Gunturi N, Ramgopal S, Balagopal S, et al. Propranolol therapy for infantile hemangioma. Indian Pediatr. Mar. 2013;50(3):307-13. [pmid: 23680605].
259 Marqueling AL, Oza V, Frieden IJ, et al. Propranolol and infantile hemangiomas four years later: a systematic review. Pediatr Dermatol. Mar–Apr. 2013;30(2):182-91. [pmid: 23405852].
260 Peridis S, Pilgrim G, Athanasopoulos I, et al. A meta-analysis on the effectiveness of propranolol for the treatment of infantile airway haemangiomas. Int J Pediatr Otorhinolaryngol. Apr. 2011;75(4):455-60. [pmid: 21333364].
261 Lou Y, Peng WJ, Cao Y, et al. The effectiveness of propranolol in treating infantile haemangiomas: a meta-analysis including 35 studies. Br J Clin Pharmacol. Jul. 2014;78(1):44-57. [pmid: 24033819].
262 Spiteri Cornish K, Reddy AR. The use of propranolol in the management of periocular capillary haemangioma--a systematic review. Eye (Lond). Oct. 2011;25(10):1277-83. [pmid: 21738233].
263 Mawn LA. Infantile hemangioma: treatment with surgery or steroids. Am Orthopt J. 2013;63:6-13. [pmid: 24260801].