# Methods

In this chapter, we document the procedures that this Evidence-based Practice Center (EPC) used to produce a comparative effectiveness review (CER) on approaches to treatment of infantile hemangioma (IH). These procedures follow the methods outlined in the Agency for Healthcare Research and Quality (AHRQ) Effective Health Care Program “Methods Guide for Effectiveness and Comparative Effectiveness Reviews.”23

## Topic Refinement and Review Protocol

The topic for this report was nominated by the American Academy of Pediatrics in a public process using the Effective Health Care Program Web site. Working from the nomination, we drafted the initial Key Questions (KQ) and Contextual Questions (CQ) and analytic framework and refined them with input from key informants representing the fields of pediatrics, dermatology, otolaryngology, vascular anomalies, surgery, and patient advocacy. All members of the research team were required to submit information about potential conflicts of interest before initiation of the work. No members of the review team had any conflicts.

After review from the AHRQ, the questions and framework were posted online for public comment. No changes to the questions or framework were recommended. We also developed population, interventions, outcomes, timing, and settings (PICOTS) criteria for intervention KQ.

We identified technical experts on the topic to provide assistance during the project. The Technical Expert Panel (TEP), representing the fields of pediatrics, pediatric dermatology, otolaryngology, surgery, vascular anomalies, hematology/oncology, and pediatric cardiology, contributed to the AHRQ’s broader goals of (1) creating and maintaining science partnerships as well as public-private partnerships and (2) meeting the needs of an array of potential users of its products. Thus, the TEP was both an additional resource and a sounding board during the project. The TEP included seven members serving as technical or clinical experts. To ensure robust, scientifically relevant work, TEP members participated in conference calls and discussions through e-mail to:

- Help to refine the analytic framework and KQ at the beginning of the project; and
- Discuss inclusion/exclusion criteria.

The final protocol was posted to the AHRQ Effective Health Care web site and registered in the PROSPERO international register of systematic reviews (ID#: CRD42015015765).

## Literature Search Strategy

### Search Strategy

To ensure comprehensive retrieval of relevant studies of therapies for children with IH, we used three key databases: the MEDLINE^®^ medical literature database via the PubMed^®^ interface, the Cumulative Index of Nursing and Allied Health Literature (CINAHL^®^), and EMBASE (Excerpta Medica Database), an international biomedical and pharmacological literature database via the Ovid^®^ interface. Search strategies for Key Questions applied a combination of controlled vocabulary (Medical Subject Headings [MeSH], CINAHL medical headings, and Emtree headings) to focus specifically on management of IH and harms of interventions. We restricted literature searches for Key Questions to studies published from 1982 to the present to reflect the use of more standardized classification schema for IH.24 We searched the same databases without date restrictions to identify contextual information.

We only included studies published in English as a review of non-English citations retrieved by our MEDLINE search identified few studies of relevance. Appendix A lists our search terms and strategies and the yield from each database for both Key and Contextual Questions. Searches were last executed in June 2015.

We carried out hand searches of the reference lists of recent systematic reviews or meta-analyses of therapies for IH. The investigative team also scanned the reference lists of studies included after the full-text review phase for additional studies that potentially could meet our inclusion criteria.

### Grey Literature

AHRQ’s Scientific Resource Center requested Scientific Information Packets (SIPs) from companies that produce medications for management of infantile hemangioma (e.g., beta-blockers including propranolol, atenolol, and timolol; corticosteroids including prednisolone and dexamethasone; imiquimod; interferon-alpha-2b; captopril; bleomycin; vinblastine; sodium tetradecyl sulfate; becaplermin); and devices for IH including pulsed dye lasers, Argon lasers, and neodymium yttrium aluminum garnet (Nd:YAG) lasers and searched for regulatory data for medications. We also searched ClinicalTrials.gov to assess reporting bias and to identify any study results that may not have been identified in our other database searches. We also searched the Web sites of relevant organizations and associations (e.g., American Academy of Pediatrics, Vascular Birthmarks Foundation) to identify relevant contextual information. We searched the U.S. Food and Drug Administration web site and package insert data for information on harms of medications for IH. We applied the inclusion criteria described above and in Table 1 to studies identified via our grey literature searches.

Table 1 Inclusion criteria

Category | Criteria
Study population | Newborns, infants, and children up to 18 years of age with infantile hemangiomas or suspected infantile hemangiomas
Publication languages | English only
Publication year | 1966-present (CQ 1 and 2) 1982-present (KQ 1, 2, 3, 4)
Admissible evidence | [underlined: Admissible designs] Original research studies providing sufficient detail regarding methods and results to enable use and aggregation of the data and results Contextual Questions (CQ):; - Systematic and non-systematic reviews, articles reporting on the history of IH diagnosis or treatment, practice guidelines, meta-analyses, RCTs, case series with at least 25 children with IH, and any comparative studies; Comparative Effectiveness Key Questions (KQ):; - Imaging accuracy: RCTs and any comparative studies; - Benefits of interventions: RCTs and any comparative studies; - Harms of interventions: RCTs, any comparative studies, and case series with at least 25 children with infantile hemangiomas
Other criteria | Studies must address one or more of the following:; - Diagnostic imaging (e.g., magnetic resonance imaging, computed tomography, magnetic resonance angiography, echocardiography, ultrasound, endoscopy); - Surgical interventions (e.g., cryotherapy, resection, embolization, radiofrequency ablation therapy) or laser interventions (e.g., pulsed dye, fractionated laser, argon, carbon dioxide, neodymium (Nd): YAG, erbium); - Pharmacologic interventions (e.g., beta-blockers, corticosteroids, immunomodulators, immunosuppressants, angiotensin-converting enzyme inhibitors, antiangiogenic agents, antineoplastics); - Data (including harms) related to diagnostic modalities or interventions for infantile hemangiomas for the following outcomes:; Imaging studies; – Ability to identify presence, number, and extent of hemangiomas and associated structural anomalies (sensitivity and specificity); – Harms; Surgical or pharmacologic intervention studies; – Size/volume of hemangioma; – Impact on vision; – Aesthetic appearance as assessed by clinician or parent; – Degree of ulceration; – Quality of life; – Harms; Relevant outcomes must be able to be abstracted from data in the papers Data must be presented in the aggregate (vs. individual participant data)

CQ = contextual question, IH = infantile hemangioma, KQ = Key Question, Nd:YAG- = neodymium yttrium aluminum garnet, RCT = randomized controlled trial

### Inclusion and Exclusion Criteria

Table 1 lists the inclusion/exclusion criteria we used based on our understanding of the literature, key informant and public comment during the topic-refinement phase, input from the TEP, and established principles of systematic review methods. We limited our searches for comparative effectiveness questions to studies published in English and from 1982 to the present for studies of the effectiveness of treatments. We also excluded studies evaluating multiple lesion types (e.g., cavernous hemangioma, hemangioblastoma, vascular malformations, noninvoluting congenital hemangiomas) unless we could clearly extract data pertaining to children with IH or if the majority of children had IH. We included studies with populations including individuals over age 18 if the majority of the participants were under age 18 or the mean age range was within 0 to 18 years. To be included for KQ3 studies had to note explicitly that all children had received prior treatment with beta-blockers or steroids and were therefore receiving a second-line treatment following those agents. We also included case series with at least 25 children with IH to address harms but not effectiveness. We selected the lower bound of 25 as a conservative value based on a preliminary review of case series.

### Study Selection

Once we identified articles through the electronic database searches and hand-searching, we examined abstracts of articles to determine whether studies met our criteria. Two reviewers separately evaluated the abstracts of studies identified in our searches for Key Questions for inclusion or exclusion, using an Abstract Review Form (Appendix B). If one reviewer concluded that the article could be eligible for the review based on the abstract, we retained it. Following abstract review, two reviewers independently assessed the full text of each included study using a standardized form (Appendix B) that included questions stemming from our inclusion/exclusion criteria. Disagreements between reviewers were resolved by a senior reviewer. Reviewers could flag studies that potentially addressed a Contextual Question identified in the screening process for Key Questions.

We also screened studies identified in our separate database searches for studies potentially addressing Contextual Questions. We did not conduct dual screening of studies identified in our searches for Contextual Questions. If one reviewer determined that a study could be eligible, we assessed its relevance to the Contextual Questions. Excluded studies had no further analysis.

All abstract and full text reviews were conducted using the DistillerSR online screening application (Evidence Partners Incorporated, Ottawa, Ontario). Appendix C includes a list of excluded studies and the reasons for exclusion. Data extracted for each study are available via the Systematic Review Data Repository (http://srdr.ahrq.gov/).

### Data Extraction

The staff members and clinical experts (including one otolaryngologist, one pediatric hematologist/oncologist, one pediatrician, one nurse practitioner, and two epidemiologists) who conducted this review jointly developed the data extraction forms for the Key Questions. We designed form to provide sufficient information to enable readers to understand the studies and to determine their quality; we gave particular emphasis to essential information related to our Key Questions. We used two templates to facilitate the extraction of data based on study type; one form was designed for case series that reported harms data and one to accommodate all types of comparative studies for effectiveness and harms data.

The team was trained to extract data by extracting several articles into the template and then reconvening as a group to discuss the utility of the template. We repeated this process through several iterations until we decided that the templates included the appropriate categories for gathering the information contained in the articles and for potential meta-analyses. Team data extractors shared the task of initially entering information into the evidence tables. A second team member also reviewed the articles and edited all initial table entries for accuracy, completeness, and consistency. A senior reviewer reconciled disagreements concerning the information reported.

The full research team met regularly during the article extraction period and discussed issues related to the data extraction process (e.g., determining instances of IH vs. other lesions). In addition to outcomes related to imaging or intervention effectiveness (sensitivity and specificity, change in lesion size, resolution, aesthetic appearance, ulceration, vision changes, quality of life), we extracted all data available on harms. Harms encompass the full range of specific negative effects, including the narrower definition of adverse events.

### Data Synthesis

We summarized data for Key Questions qualitatively using summary tables where meta-analyses were not possible. We provided a narrative summary of relevant papers for contextual questions.

We identified sufficient data to address the effectiveness of pharmacologic interventions using quantitative meta-analysis methods. Studies were included in the network meta-analysis subset provided that they satisfied the following additional inclusion criteria:

- Outcomes were reported quantitatively, using an objective metric for reporting intervention effects that could be converted into a proportion of IH clearance.
- One or more study arms evaluated a single intervention; study arms in which two or more treatments were applied were excluded.
- Reported outcomes were accompanied by an associated measure of variation or precision.
- Non-control pharmacologic treatments could be reasonably classified into one of the following classes of agents: oral, intralesional, or topical propranolol; intralesional triamcinolone; topical or ophthalmic timolol; and oral steroid.
- Studies evaluated IH in multiple locations (vs. specific anatomic areas) as most studies included IH in multiple areas.

In addition to the diverse suite of interventions, outcomes were reported in a variety of ways. Most identified an arbitrary threshold of IH clearance (e.g. >75%) as a positive outcome, or divided the continuous clearance measure into a small number of categories. Others reported visual analog scale scores, either for entire study arms or for individual patients within study arms. In order to incorporate as many quality studies as possible, by minimizing the number excluded due to technical constraints on statistical integration, we constructed a Bayesian latent variable model. This model allowed several different types of outcome data and a suite of pharmacologic interventions to be analyzed in the same model, thereby maximizing the power for estimating parameters precisely. The estimands of interest were the expected proportion of clearance for each intervention agent, along with associated posterior uncertainty. A full description of the meta-analytic methods is reported in Appendix D.

## Quality (Risk of Bias) Assessment of Individual Studies

We used separate tools appropriate for specific study designs to assess quality of individual studies meeting eligibility criteria for our Key Questions: questions adapted from the RTI item bank to assess randomized controlled trials (RCTs),25 the Newcastle-Ottawa Quality Assessment Scale for cohort studies,26 the QUADAS tool for diagnostic imaging studies,27 and a tool adapted from questions outlined in the RTI item bank and the McMaster McHarms tool to assess reporting of harms.28

Questions from the RTI item bank evaluate domains including selection bias, performance bias, attrition bias, detection bias, and reporting bias. We used the Newcastle-Ottawa Quality Assessment Scale to assess the quality of nonrandomized studies. It assesses three broad perspectives: the selection of study groups, the comparability of study groups, and the ascertainment of either the exposure or outcome of interest for case-control or cohort studies, respectively. The QUADAS tool considers questions related to participant characteristics, comparisons with a gold standard, and interpretation of the screening test. The harms assessment tool addresses questions related to pre-specification and reporting of harms.

Quality assessment of each study was conducted independently by two team members using the forms presented in Appendix B. Any discrepancies were adjudicated by the two team members or a senior investigator. Investigators did not rely on the study design as described by authors of individual papers; rather, the methods section of each paper was reviewed to determine which rating tool to employ, and we used the algorithm in Appendix E to aid in determining study design. The results of these tools were then translated to “good,” “fair,” and “poor” quality ratings as described below. Appendix F reports quality scoring for each study. We did not assess the quality of papers identified for Contextual Questions.

### Determining Quality Ratings

- We required that RCTs receive a positive score (i.e., low risk of bias for RCTs) on roughly 80 percent (11 of 13) of the questions used to assess quality to receive a rating of good/low risk of bias. RCTs had to receive eight to ten positive scores to receive a rating of fair/moderate risk of bias, and studies with ≤ seven positive ratings were considered poor quality/high risk of bias. We considered a score of “unclear” for a question as a negative score. We assessed the risk of bias for each major outcome of relevance reported but report an overall assessment unless the risk of bias varied by outcome.
- We required that cohort studies receive positive scores (stars) on all elements, including use of blinded outcome assessors, and be prospective to receive a rating of good, ≤ 2 negative ratings for fair, and > 2 negative scores for a rating of poor quality.
- For imaging studies we required that studies receive positive scores on all questions to receive a rating of good. We considered studies with ≤ three negative ratings as fair quality and those with more than four as poor quality.
- We required that studies assessed for harms reporting receive at least 3.5 of a possible four points available to receive a rating of “good.” We gave partial points to studies that reported monitoring for changes in blood pressure, heart rate, or hypoglycemia. Studies with 2.5 to three positive responses were considered fair quality and those with ≤ two positive responses were deemed to be poor quality.

## Strength of the Body of Evidence

We applied explicit criteria for rating the overall strength of the evidence for each key intervention-outcome pair for which the overall risk of bias was not overwhelmingly high. We rated the strength of the evidence for the final outcomes of interest for our Key Questions (Figures 1–3) and for clinically important harms. We used established concepts of the quantity of evidence (e.g., numbers of studies, aggregate ending-sample sizes), the quality of evidence (from the quality ratings on individual articles), and the coherence or consistency of findings across similar and dissimilar studies and in comparison to known or theoretically sound ideas of clinical or behavioral knowledge.

The strength of evidence evaluation that we used is described in the Effective Health Care Program’s “Methods Guide for Effectiveness and Comparative Effectiveness Reviews”23 and in the updated strength of evidence guide,29 which emphasizes five major domains: study limitations (low, medium, high level of limitation), consistency (inconsistency not present, inconsistency present, unknown or not applicable), directness (direct, indirect), precision (precise, imprecise), and reporting bias. Study limitations are derived from the quality assessment of the individual studies that addressed the Key Questions and specific outcome under consideration. Each key outcome for each comparison of interest is given an overall evidence grade based on the ratings for the individual domains.

The overall strength of evidence was graded as outlined in Table 2. Two senior staff members independently graded the body of evidence; disagreements were resolved as needed through discussion or third-party adjudication. We recorded strength of evidence assessments in tables, summarizing results for each outcome. We considered case series in the assessment of strength of the evidence for harms.

Table 2 Strength of evidence grades and definitions^*^

Grade | Definition
High | We are very confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has few or no deficiencies. We believe that the findings are stable, i.e., another study would not change the conclusions.
Moderate | We are moderately confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has some deficiencies. We believe that the findings are likely to be stable, but some doubt remains.
Low | We have limited confidence that the estimate of effect lies close to the true effect for this outcome. The body of evidence has major or numerous deficiencies (or both). We believe that additional evidence is needed before concluding either that the findings are stable or that the estimate of effect is close to the true effect.
Insufficient | We have no evidence, we are unable to estimate an effect, or we have no confidence in the estimate of effect for this outcome. No evidence is available or the body of evidence has unacceptable deficiencies, precluding reaching a conclusion.

* Excerpted from Berkman et al. 2014^29^

## Applicability

We assessed the applicability of findings reported in the included literature addressing our Key Questions to the general population of children with IH by determining the population, intervention, comparator, and setting in each study and developing an overview of these elements for each intervention category. We anticipated that areas in which applicability would be especially important to describe would include the diagnostic criteria for IH, age at treatment initiation, and the anatomic location and morphology of IH. Applicability tables for each intervention are in Appendix G.

## Peer Review and Public Commentary

Researchers and clinicians with expertise in managing IH and individuals representing stakeholder and user communities provided external peer review of this report; AHRQ, a statistical expert, and an associate editor also provided comments. The draft report was posted on the AHRQ Web site for 4 weeks to elicit public comment. We addressed all reviewer comments, revised the text as appropriate, and documented changes and revisions to the report in a disposition of comments report that will be made available 3 months after AHRQ posts the final review on the AHRQ Web site.